# 4 Discussion

## Summary of Review Findings

Table 3 summarizes the evidence reviewed for this update. We identified no studies of screening versus no screening for celiac disease in the target populations for this review (adults, adolescents, and children age 3 years or older). Although serologic tests for celiac disease used in screening appear to be highly accurate, almost all studies on diagnostic accuracy evaluated populations with symptoms of celiac disease or whose symptom status was not reported. Two studies that specifically evaluated patients at high risk for celiac disease based on family history or presence of conditions associated with celiac disease reported lower sensitivity and inconsistent specificity.^37, 40^

Table 3 Summary of Evidence

Included studies | Summary of findings | Consistency | Applicability | Limitations | Overall quality
Key Question 1. What is the effectiveness of screening versus not screening for celiac disease in asymptomatic adults, adolescents, or children on morbidity, mortality, or quality of life?
No studies | - | - | - | - | -
Key Question 2. What is the effectiveness of targeted versus universal screening for celiac disease in asymptomatic adults, adolescents, or children on morbidity, mortality, or quality of life? (Targeted screening refers to testing in patients with family history or other risk factors for celiac disease.)
No studies | - | - | - | - | -
Key Question 3. What are the harms of screening for celiac disease?
No studies | - | - | - | - | -
Key Question 4. What is the accuracy of screening tests for celiac disease?
1 systematic review (of 56 studies and 12 other systematic reviews) | One good-quality systematic review found that tTG antibody tests were associated with high sensitivity and specificity in populations not restricted to asymptomatic persons. Based on new studies, the pooled sensitivity in the systematic review was 92.8% (95% CI, 90.3% to 94.8%) and specificity was 97.9% (95% CI, 96.4% to 98.8%), for a positive likelihood ratio of 45.1 (95% CI, 25.1 to 75.5) and negative likelihood ratio of 0.07 (95% CI, 0.05 to 0.10). EMA antibody tests were also associated with strong likelihood ratios. | Consistent | Moderate | Only 2 studies are of asymptomatic persons | Fair
2 studies (n=220) conducted in asymptomatic persons | Limited evidence from 2 studies of serologic testing in asymptomatic, high-risk children and younger adults reported lower sensitivity (57% to 71%); specificity ranged from 83% to 98%. | - | High Non-U.S. setting | Imprecision | Poor
Key Question 5. Does treatment of screen-detected celiac disease lead to improved morbidity, mortality, or quality of life compared with no treatment?
1 trial (n=40 randomized from screening pool of 3,031) | One small (n=40), fair-quality trial of screen-detected, asymptomatic adults found that a gluten-free diet was associated with small improvements in gastrointestinal symptoms (<1 point on a 7-point scale) versus no gluten-free diet after 1 year, but there were no changes on most quality of life outcomes. | - | High Non-U.S. setting | Imprecision | Poor
Key Question 6. Does treatment of screen-detected celiac disease lead to improved morbidity, mortality, or quality of life compared with treatment initiated after clinical diagnosis?
No studies | - | - | - | - | -
Key Question 7. What are the harms associated with treatment of celiac disease?
1 trial (n=40 randomized from screening pool of 3,031) | The trial included for key question 5 reported no withdrawals “as a result of major symptoms or complications.” We identified no other study on harms of gluten-free vs. nongluten-free diet in persons with screen-detected celiac disease. | - | High Non-U.S. setting | Imprecision | Poor

Abbreviations: CI=confidence interval; EMA=endomysial antibody; tTG=tissue transglutaminase.

Only one randomized trial evaluated the effectiveness of gluten-free versus no gluten-free diet in asymptomatic persons with screen-detected celiac disease.^59^ It found that initiation of a gluten-free diet in screen-detected, asymptomatic adults was associated with improved gastrointestinal symptoms, though effects were relatively small (<1 point on a 7-point scale). There were no effects on most measures of quality of life; no harms resulting in withdrawal from the diet occurred. In this study, patients had a first-degree relative with celiac disease and were diagnosed on the basis of serologic testing. Histologic findings of celiac disease were not required for entry, though most patients had some degree of villous atrophy at baseline. Nonetheless, it is possible that this trial could have underestimated benefits of treatment for histologic-proven celiac disease. Three small studies on effects of a gluten-free diet in persons with asymptomatic celiac disease were excluded because they did not include a gluten-containing diet control group.^61-63^ There were no clear effects on quality of life, though one study^62^ found increased worry about health following initiation of a gluten-free diet and one study^63^ reported small improvements in gastrointestinal symptoms.

No study compared the effectiveness of targeted versus universal screening or evaluated effects of immediate initiation of a gluten-free diet versus delaying until the development of symptoms in asymptomatic persons diagnosed with celiac disease.

## Limitations

The major limitation of this review is the lack of evidence to address the key questions. There were no studies on screening versus no screening, only two studies on diagnostic accuracy of serologic testing in asymptomatic populations, and only one trial of treatment in asymptomatic, screen-detected persons with celiac disease. Although numerous studies evaluated the diagnostic accuracy of tests for celiac disease in patients who were not asymptomatic, the applicability of findings to screening settings is uncertain. Meta-analysis was not possible, and we could not formally assess for publication bias. We restricted inclusion to English-language articles but found no non-English–language articles on benefits or harms of screening or treatment that appeared to meet inclusion criteria. Although some non-English–language articles assessed diagnostic accuracy, none were clearly conducted in asymptomatic populations.

## Emerging Issues/Next Steps

An emerging issue is the development and uptake of methods for diagnosing celiac disease that do not require histologic confirmation. The proportion of patients who are diagnosed with celiac disease or initiate a gluten-free diet based on serologic testing alone is unknown but may be increasing in clinical practice, despite clinical practice guideline recommendations for histologic confirmation.

A related issue is how to classify and manage persons with positive serologic findings but negative or nondiagnostic findings on biopsy. The likelihood that such patients will go on to develop overt celiac disease requires further investigation, and has important implications for management.

A recent randomized trial that screened persons with a first- or second-degree relative with celiac disease and randomized patients to immediate notification and initiation of a gluten-free diet versus no notification or initiation of a gluten-free diet was terminated.^75^ We were unable to determine reasons for study termination.

Although there continues to be research on pharmacologic treatments for celiac disease,^76-79^ such treatments are considered an adjunct to a gluten-free diet, which remains the mainstay of therapy.

## Relevance for Priority Populations

In the United States, celiac disease is uncommon among racial/ethnic minorities, although it does occur. In an NHANES study, the prevalence of tTG IgA test results were 0.8 percent (27/3,430) among non-Hispanic whites, 0.07 percent (1/1,394) among non-Hispanic blacks, 0.03 percent (1/2,519) among other Hispanics/not Mexican Americans, and 0.2 percent (1/455) among other race/ethnicity categories.^4^

The only randomized trial of treatment with a gluten-free diet among asymptomatic screen-detected persons was restricted to persons younger than age 18 years or older than age 75 years.^80^ Although celiac disease is most commonly diagnosed between ages 40 and 60 years,^13, 14^ it can affect adolescents and children as well as older adults.^81, 82^

## Future Research

Additional research is needed to address all of the key questions addressed in this report. For screening, trials of screening versus no screening that evaluate clinical outcomes are needed. Trials that target high-risk populations, based on family history or presence of conditions associated with celiac disease, would be likely to provide a higher yield of screen-detected persons than trials that screen lower- or average-risk persons, and might be more informative for an initial screening study. Additional studies are needed to determine the accuracy of serologic testing in asymptomatic persons. Trials are also needed on the effects of initiation of a gluten-free diet versus no gluten-free diet in screen-detected persons, and the effects of immediate initiation on diagnosis versus delayed initiation until the development of symptoms. The in-progress Celiac Disease and Diabetes-Dietary Intervention and Evaluation Trial (Celiac Disease-DIET), which involves screening for asymptomatic celiac disease in children and adults with type 1 diabetes mellitus followed by randomization to a gluten-free or no gluten-free diet, is designed to assess outcomes (including diabetes control, bone mineral density, and health-related quality of life) over 1 year, and should help clarify effects of screening in higher-risk persons.^83^ Ideally, future studies would be carried out long enough to determine effects on long-term outcomes related to nutritional deficiencies such as osteoporotic fractures, cancer, and mortality. Because of the uncertain natural history of positive serologic findings without histologic changes, trials should focus on patients with histologic findings of celiac disease, or report analyses stratified according to baseline histologic findings. Trials should evaluate populations across the age spectrum, including children, adolescents, and adults, as celiac disease can be diagnosed in any of these age groups.

Research is also needed to better understand the natural history of subclinical and silent celiac disease, including the proportion of patients who develop symptoms, the proportion who develop complications, and the proportion in whom serologic and/or histologic findings resolve without treatment.

## Conclusions

More research is needed to understand the effectiveness of screening for and treatment of celiac disease in asymptomatic adults, adolescents, and children, and optimal screening strategies.