# 3 Results

## Key Question 1 What Is the Effectiveness of Screening Versus Not Screening for Celiac Disease in Asymptomatic Adults, Adolescents, or Children on Morbidity, Mortality, or Quality of Life?

We identified no studies on the effectiveness of screening versus no screening for celiac disease in asymptomatic adults, adolescents, or children on morbidity, mortality, or quality of life.

## Key Question 2 What Is the Effectiveness of Targeted Versus Universal Screening for Celiac Disease in Asymptomatic Adults, Adolescents, or Children on Morbidity, Mortality, or Quality of Life?

We identified no studies on the effectiveness of targeted screening of persons with a family history or other risk factors for celiac disease versus universal screening for celiac disease in asymptomatic adults, adolescents, or children on morbidity, mortality, or quality of life.

## Key Question 3 What Are the Harms of Screening for Celiac Disease?

We identified no trials on the harms of screening versus no screening for celiac disease.

## Key Question 4 What Is the Accuracy of Screening Tests for Celiac Disease?

### Summary

One good-quality systematic review found that tTG antibody tests were associated with high sensitivity and specificity in populations not restricted to asymptomatic persons. Based on new studies, the pooled sensitivity in the systematic review was 92.8 percent (95% CI, 90.3% to 94.8%) and specificity was 97.9 percent (95% CI, 96.4% to 98.8%), for a positive likelihood ratio (PLR) of 45.1 (95% CI, 25.1 to 75.5) and negative likelihood ratio (NLR) of 0.07 (95% CI, 0.05 to 0.10). EMA tests were also associated with strong likelihood ratios. Limited evidence from two studies of serologic testing in asymptomatic, high-risk children and younger adults reported lower sensitivity (57% to 71%); specificity ranged from 83 to 98 percent.

### Evidence

A recent good-quality systematic review on the diagnostic accuracy of tests for celiac disease included 56 original studies and 12 prior systematic reviews (Appendixes B1 and B2).^35^ Sample sizes ranged from 62 to more than 12,000 subjects. Three primary studies focused on diagnostic accuracy of testing in children and/or adolescents,^36-38^ six evaluated a mixed population of children and adults,^39-44^ and the remainder focused on adults. One study was conducted in the United States,^45^ five studies in the Middle East,^40, 42, 46-48^ one in India,^49^ one in Argentina,^50^ and the rest in Europe.^36-39, 41, 43, 44, 51-58^ Tests evaluated included tTG, EMA, DGP, and video capsule endoscopy. Only two studies reported diagnostic accuracy in asymptomatic persons (Appendixes B3 and B4).^37, 40^

Overall, including studies of persons with symptoms or in whom symptom status was not described, the systematic review found high strength of evidence that the tTG IgA test was associated with high (>90%) sensitivity and specificity and the EMA IgA test was associated with high specificity, based on consistent results from prior systematic reviews and new studies. For the tTG IgA test, the pooled sensitivity, based on new studies, was 92.8 percent (95% CI, 90.3% to 94.8%) and specificity was 97.9% (95% CI, 96.4% to 98.8%), for a PLR of 45.1 (95% CI, 25.1 to 75.5) and NLR of 0.07 (95% CI, 0.05 to 0.10). For the EMA IgA test, the pooled sensitivity, based on new studies, was 73.0 percent (95% CI, 61.0% to 83.0%) and specificity was 99.0 percent (95% CI, 98.0% to 99.0%), for a PLR of 65.6 (95% CI, 35.6 to 120.8) and NLR of 0.28 (95% CI, 0.17 to 0.41). Results for the DGP IgA test indicated somewhat weaker likelihood ratios; the pooled sensitivity was 87.8 percent (95% CI, 85.6% to 89.9%) and specificity was 94.1 percent (95% CI, 92.5% to 95.5%), for a PLR of 13.3 (95% CI, 9.6 to 18.4) and NLR of 0.12 (95% CI, 0.08 to 0.18). For video capsule endoscopy, the pooled sensitivity was 89.0 percent (95% CI, 82.0% to 94.0%) and specificity was 95.0 percent (95% CI, 89.0% to 99.0%), for a PLR of 12.9 (95% CI, 2.9 to 57.6) and NLR of 0.16 (95% CI, 0.10 to 0.25).

Three studies in the systematic review compared the accuracy of tests by age group.^38, 41, 57^ Sensitivity and specificity were generally similar across age groups, with the exception of one study that reported specificity of 26 percent for the DGP IgA test among those age 18 years or younger.^38^ Sensitivity was somewhat lower in adults than in children, but differences were slight.

Only two studies included in the systematic review reported diagnostic accuracy in asymptomatic persons (Appendixes B3 and B4).^37, 40^ A small (n=62), fair-quality study of patients in Iraq with type 1 diabetes mellitus (mean age, 23 years) without symptoms or a family history of celiac disease evaluated tTG IgA, tTG IgG, EMA IgA, AGA IgA, and AGA IgG assays.^40^ The prevalence of celiac disease, based on biopsy, was 11.3 percent (7/62); sensitivity ranged from 57 percent for the tTG IgG test to 71 percent for the tTG Ig A and EMA IgA tests, resulting in positive predictive values of 50.0 to 71.4 percent; specificity was similar across tests, ranging from 93 to 98 percent, for negative predictive values of 94.4 to 96.4 percent.

Another fair-quality study reported diagnostic accuracy of the combination of tTG IgA and EMA IgA tests in a subgroup of 158 asymptomatic Czech children and adolescents ages 16 months to 19 years at higher risk for celiac disease because they had a first-degree relative with celiac disease or had an associated disease, such as type 1 diabetes mellitus or autoimmune thyroiditis.^37^ The prevalence of Marsh 2 or 3 small-bowel mucosal villous atrophy was 78.5 percent (124/158), with sensitivity of 67 percent and specificity of 83 percent for the combination of tTG IgA levels more than 10 times the upper limit of normal and a positive EMA IgA test. Results were not reported for the subgroup of patients with Marsh 3 biopsy findings. Sensitivity was 70 percent and specificity was 81 percent for patients with a first-degree relative with celiac disease (n=32); sensitivity was 64 percent and specificity was 93 percent for patients with type 1 diabetes mellitus (n=40).

## Key Question 5 Does Treatment of Screen-Detected Celiac Disease Lead to Improved Morbidity, Mortality, or Quality of Life Compared With No Treatment?

### Summary

One small (n=40), fair-quality trial of screen-detected, asymptomatic adults found that a gluten-free diet was associated with small improvements in gastrointestinal symptoms (<1 point on a 7-point scale) versus no gluten-free diet after 1 year, but there were no changes on most quality of life outcomes. No other study evaluated the effects of a gluten-free versus no gluten-free diet on clinical outcomes.

### Evidence

One fair-quality trial (n=40) evaluated a gluten-free versus normal gluten–containing diet among screen-detected adults who were asymptomatic relatives of persons with celiac disease (Appendixes B5 and B6).^59^ Median age of participants was 42 years. Diagnosis of celiac disease was based on a positive serum EMA test. Although biopsy was performed, histopathologic findings of celiac disease were not required for study entry, and biopsy results were blinded from study researchers until completion of the trial. At baseline, the mean villous height to crypt depth ratio was 1.0 in the gluten-free diet group and 0.8 in the nongluten-free diet group; two patients in each group had a normal villous height to crypt depth (>2.0).

At 1 year, subjects on a gluten-free diet reported significant improvements in total gastrointestinal symptoms compared with those on a nongluten-free diet, based on the overall Gastrointestinal Symptoms Ratings Scale (difference in mean change, -0.4 on a 7-point scale [95% CI, -0.7 to -0.1]), as well as on the diarrhea (difference in mean change, -0.6 [95% CI, -1.1 to 0.0]), indigestion (difference in mean change, -0.7 [95% CI, -1.1 to -0.2]), and reflux subscales (difference in mean change, -0.5 [95% CI, -0.9 to -0.1]), with no differences on the constipation or abdominal pain subscales. The gluten-free diet group also reported greater improvement on the anxiety subscale of the Psychological General Well-Being Scale (difference in mean change, 1.6 on a 6-point scale [95% CI, 0.4 to 2.8]), with no differences on the depression, well-being, self-control, general health, or vitality subscales. There were no differences in any subscales of the Short-Form 36 Survey aside from social functioning, which was worse in the gluten-free diet group (difference in mean change, -8.3 [95% CI, -15.8 to -0.8]). There were no differences between groups in intermediate outcomes such as mean blood hemoglobin level, mean serum total iron level, mean body mass index, mean percent total body fat, or mean lumbar spine or femoral neck bone mineral density. After 2 years, more than 90 percent of subjects reported adherence to the gluten-free diet, and improvements in histopathologic findings were observed in the gluten-free diet group at 1 year compared with the nongluten-free diet group.

An earlier, small (n=23) trial conducted at the same center did not meet inclusion criteria.^60^ Although it randomized patients identified through EMA testing to a gluten-free or normal diet, 87 percent (20/23) of patients had moderate or severe symptoms. All patients had nondiagnostic (Marsh 1 or 2) histologic findings on small bowel biopsy. Over the course of 1 year, a gluten-free diet was associated with significantly improved subjective clinical symptom ratings, with all patients' ratings changing from severe/moderate to slight/no symptoms (p<0.05), compared with no changes on a nongluten-free diet.

Three small (n=14 to 32) studies evaluated effects of a gluten-free diet in asymptomatic adults with celiac disease but did not meet inclusion criteria because they did not have a nongluten-free diet control group.^61-63^ Each study evaluated effects before initiation of a gluten-free diet and at 1 to 2 years. Following initiation of a gluten-free diet, one study found worse perceived health and more concern about health,^62^ one study found no differences in measures of quality or life or general health,^61^ and one study found small improvements in gastrointestinal symptoms but no differences in quality of life.^63^

## Key Question 6 Does Treatment of Screen-Detected Celiac Disease Lead to Improved Morbidity, Mortality, or Quality of Life Compared With Treatment Initiated After Clinical Diagnosis?

We identified no studies on the effectiveness of treatment of screen-detected celiac disease compared with treatment initiated after clinical diagnosis on morbidity, mortality or quality of life.

## Key Question 7 What Are the Harms Associated With Treatment of Celiac Disease?

The trial of a gluten-free diet by Kurppa and colleagues (included for key question 5) reported no withdrawals “as a result of major symptoms or complications.”^59^ We identified no other study on harms of gluten-free versus nongluten-free diet in persons with screen-detected celiac disease.

## Contextual Question 1 Among Patients Without Overt Symptoms, What Is the Prevalence of Celiac Disease in Children, Adolescents, and Adults in the United States?

Reliable data regarding the prevalence of subclinical and silent celiac disease in the United States are not available. Most prevalence studies of the general population were not designed to determine whether participants had symptoms potentially attributable to celiac disease or whether they were truly asymptomatic. In a large (n=7,798) NHANES study of persons age 6 years or older, the prevalence of celiac disease, as defined by a positive tTG IgA and EMA IgA test, was 0.71 percent among the general population, 0.76 percent among those age 20 years or older, 0.62 percent among women, and 1.01 percent among non-Hispanic whites.^4^ Study participants were asked whether they had previously been diagnosed with celiac disease and whether they were on a gluten-free diet but were not interviewed regarding symptoms that could be attributed to celiac disease. Other studies of the general adult U.S. population found a celiac disease prevalence of 0.2 to 0.9 percent, based on positive serologic tests, specifically initial tTG antibody tests followed by EMA testing.^3, 5, 64^ None of these studies reported whether participants had symptoms that could be caused by celiac disease. Some studies from Europe reported the proportion of patients with celiac disease who were asymptomatic. In an Italian retrospective study of 549 patients with celiac disease diagnosed by intestinal biopsy, 45.7 percent presented with classical celiac disease and 6.6 percent were asymptomatic.^19^ Another Italian study found that of 770 patients with celiac disease, 79 percent presented with classical celiac disease and 21 percent presented with atypical or silent celiac disease.^65^

Presumably, many cases of celiac disease detected by screening would be subclinical or silent. However, a limitation of many studies is that diagnosis of celiac disease was based on positive results on combinations of serologic tests without histologic confirmation. However, serologic tests are associated with a small proportion of false positives in symptomatic persons. At a given diagnostic accuracy, the positive predictive value of serologic tests will be lower in populations with a lower prevalence of celiac disease.^16, 24^

Even when intestinal biopsy is performed, distinguishing between persons with false-positive serologic findings and persons with subclinical celiac disease can be a challenge, because biopsy findings may be subtle or absent due to patchy disease or inadequate sampling.^16^ Most studies reported high concordance between positive serology and intestinal biopsy. However, in a study of 1,461 Estonians ages 15 to 95 years who were screened for celiac disease with AGA IgA testing, 3.5 percent (52 persons) had positive serology, but none were symptomatic or had biopsy results consistent with celiac disease.^66^ Among 20 screen-detected adults in Northern Ireland with positive celiac disease serology who agreed to have intestinal biopsy, only three had villous atrophy. Of these, one was asymptomatic and two later endorsed symptoms attributed to celiac disease.^67^

## Contextual Question 2 What Is the Natural History of Subclinical or Silent Celiac Disease?

Data regarding the proportion of persons with silent or subclinical celiac disease who later develop symptomatic celiac disease are limited. In a study of stored sera from young adults at Warren Air Force Base collected from 1948 to 1954, none of the 14 subjects with undiagnosed celiac disease, based on serologic tests, received a clinical diagnosis of celiac disease within 45 years of followup.^5^ A study of adults in Maryland based on 3,511 matched samples of stored sera from 1974 and 1989 found that among 18 cases diagnosed with celiac disease, based on positive EMA IgA and positive/borderline results for tTG IgA, two persons received a clinical diagnosis of celiac disease at a mean followup of 31.1 years.^64^ In a study of 16,847 adults age 50 years or older in Minnesota, 129 were found to have undiagnosed celiac disease, based on positive tTG IgA and EMA IgA tests.^3^ During a median followup of 10.3 years, 20 persons were clinically diagnosed with celiac disease. A study of 3,654 Finnish children without known celiac disease found that 1.5 percent (56 children) had positive tTG IgA and EMA IgA or IgG tests. Over 7 years of followup, 37 (about 1%) were diagnosed with celiac disease on the basis of biopsy, of which 10 remained clinically silent.^68^ A Dutch study of children ages 2 to 4 years diagnosed with celiac disease based on EMA antibodies and confirmatory biopsy through a screening program found that five of 12 asymptomatic children who did not initiate a gluten-free diet remained asymptomatic after 10 years of followup.^69^ The other seven children switched to a gluten-free diet due to the development of symptoms; symptoms resolved after initiation of the diet. Another study found that among children (mean age, 29 months) with potential celiac disease (serology positive/Marsh 0–1 histology), 86 percent (18/21) who continued a gluten-containing diet become antibody negative, 9 percent (2/21) had fluctuating antibodies, and 5 percent (1/21) developed overt celiac disease.^70^

Evidence is conflicting whether persons diagnosed with subclinical or silent celiac disease experience the same mortality risk as the general population.^3, 5, 20, 67, 71-74^ The Warren Air Force Base study discussed above found that all-cause mortality was higher among persons with undiagnosed celiac disease (based on positive serology) after 45 years of followup than among seronegative controls within the same cohort.^5^ However, symptom status of persons with undiagnosed celiac disease was not reported. In a study of stored sera from German adults collected from 1989 to 1990, positive celiac disease serology was associated with increased risk of all-cause mortality compared with age- and sex-matched controls.^71^ Participants were asked about their general self-rated health status, but as in the other study, the prevalence of symptoms attributable to celiac disease was not reported.

A meta-analysis of observational studies reported somewhat conflicting results regarding effects of celiac disease diagnosed by serologic testing and association with increased risk of all-cause mortality and cancer compared with seronegative age- and sex-matched controls.^20^ In three studies, screen-detected celiac disease (diagnosed by serologic tests alone, symptoms not reported) was not associated with increased risk of all-cause or cancer mortality compared with age- and sex-matched controls.^3, 72, 73^ However, a fourth study found that latent celiac disease (positive serology and normal mucosa) was associated with an estimated excess mortality of 1.7 deaths per 1,000 person-years compared with age- and sex-matched controls in the general population (hazard ratio, 1.35 [95% CI, 1.14 to 1.58]).^74^ Symptom status was not reported, but the authors noted that clinical suspicion for celiac disease was the only major indication for small intestinal biopsy in Sweden, suggesting that persons may have been symptomatic.^74^ In another study of screen-detected celiac disease among adults in Northern Ireland, positive serologic tests for celiac disease were not associated with excess mortality risk compared with age-specific mortality in the general population.^67^

Some data suggest that subclinical or silent celiac disease is associated with lower risk of developing celiac disease complications than symptomatic disease (Table 2). An Italian retrospective study of 549 patients with celiac disease diagnosed by intestinal biopsy found that the complication rate among patients on a gluten-free diet (mean duration, 7 years [range, 1 to 15 years]) was 5.58 percent in those with classical celiac disease (n=251) and 1.53 percent in those with subclinical celiac disease (n=262, defined as the presence of gluten-sensitive enteropathy on biopsy with extraintestinal but no gastrointestinal symptoms).^19^ Complications included gastrointestinal adenocarcinoma, Sjögren's syndrome, jejunal enteropathy-associated T-cell lymphoma, myocardial infarction, sclerosing cholangitis, herpetiform dermatitis, gastric mucosa-associated lymphoid tissue lymphoma, ulcerative jejunitis, severe nonalcoholic steatohepatitis, recurrent abortion, and autoimmune thrombocytopenia. There was no statistical difference between the mean age of the two groups developing complications. No patient with silent disease (gluten-sensitive enteropathy on biopsy without symptoms) experienced complications. Another Italian study of 770 patients diagnosed with celiac disease (histologic confirmation) evaluated presentation patterns of patients who developed complicated versus noncomplicated celiac disease (p<0.001).^65^ Six patients with classic malabsorption symptoms at presentation developed complications compared with no patients with atypical and subclinical celiac disease over a mean of 5 years (p<0.001). Complications included enteropathy-associated T-cell lymphoma, small bowel carcinoma, and refractory celiac disease.

Table 2 Natural History of Celiac Disease

Author, year | Population Country N Age | Duration of followup | Definition of CD | Prevalence | | Health outcomes
Author, year | Population Country N Age | Duration of followup | Definition of CD | Classic CD | Nonclassic CD (including screen-detected) | Classic CD | Nonclassic CD (including screen-detected)
Systematic review, meta-analysis (17 studies)
Tio, 2012^20^ | Symptomatic and screen-detected CD patients U.S. and Europe N=313,827 Mean age NR | NR | Varied | NR | NR | All-cause mortality: OR, 1.24 (95% CI, 1.19-1.30) Mortality from non-Hodgkin lymphoma: OR, 2.61 (95% CI, 2.04-3.33) | All-cause mortality: OR, 1.16 (95% CI, 1.02-1.31) Mortality from non-Hodgkin lymphoma: OR, 2.55 (95% CI, 1.02-6.36)
Retrospective cohort studies with comparison groups
Canavan, 2011^72^ | Population-based sample of adults from 1990-1995 United Kingdom N=7,527 Mean age NR, range 45-76 years | Median, 16.8 years | Positive IgA EMA | NA | 1.16% | NA | All-cause mortality was 9.4 deaths per 1,000 person- years (95% CI, 5.4-16.1) After adjustment for age, sex, smoking, and socioeconomic status: 0.98 (95% CI, 0.57-1.69)
Godfrey, 2010^3^ | Population-based sample of adults from 1995-2001 U.S., Minnesota N=16,886 Median age 63, range 52-88 years | 10.3 years | Positive tTG IgA and positive EMA IgA | NA | 0.8% | NA | Hazard ratio for all-cause mortality: 0.8 (95% CI, 0.45-1.41) Hazard ratio for cancer mortality: 0.63 (95% CI, 0.16-2.48)
Johnston, 1998^67^ | Population-based sample of adults, 1983 Northern Ireland N=1,204 Mean age NR | Mean, 11.6 years (range, 11.3-11.9) | Positive IgA gliadin antibody, IgA antireticulin antibody, or EMA IgA | NA | 8.47% | NA | Relative risk of all-cause mortality: 0.92 (95% CI, 0.5-1.6) Relative risk of cancer mortality: 0.94 (95% CI, 0.3-2.4)
Lohi, 2009^73^ | Population-based sample of adults, 1978-1980 Finland N=6,987 Mean age 51, range 30-95 years | Up to 28 years | Positive tTG IgA or EMA IgA | NA | 1.1% EMA positive, 2.9% tTG positive | NA | Age- and sex-adjusted relative risk of overall mortality with positive EMA IgA: 0.78 (95% CI, 0.52-1.18) Age- and sex-adjusted relative risk of overall mortality with positive tTG IgA: 1.19 (95% CI, 0.99-1.42)
Ludvigsson, 2009^74^ | Adults who had small intestinal biopsy with CD or latent CD Sweden N=46,121 Median age 30 (with CD) and 36 (with latent CD) | 8.8 years (with CD), 6.7 years (with latent CD) | Villous atrophy on small intestinal biopsy | NR | NR | Hazard ratio for all-cause mortality in CD: 1.39 (95% CI, 1.33-1.45) | Hazard ratio for all-cause mortality in latent CD: 1.35 (95% CI, 1.14-1.58)
Metzger, 2006^71^ | Population-based sample of adults from 1989-1990 Southern Germany N=4,633 Mean age men, 57 years Mean age women, 53 years | Median, 7.95 years (range, 11 days-8.9 years) | Positive tTG IgA test | NA | 1.36% | NA | Age-adjusted hazard ratio for all-cause mortality: 2.53 (95% CI, 1.5-4.25) Age-adjusted hazard ratio for cancer mortality: 3.62 (95% CI, 1.67-7.81)
Rubio-Tapia, 2009^5^ | Healthy adults U.S., Warren AFB N=9,133 Mean age 21 years | 45 years | Positive tTG IgA or EMA IgA | NA | 0.2% | NA | Hazard ratio for all-cause mortality: 3.9 (95% CI, 2.0-7.5)
Tursi, 2009^19^ | CD patients on gluten-free diet enrolled 1993-2006 Italy N=549 Mean age NR | NR | Positive small bowel biopsy | 45.7% | 47.7% subclinical^*^ 6.6% silent | Rate of complications: 5.6% | Rate of complications: 1.5% subclinical 0% silent
Volta, 2014^65^ | Adults diagnosed with CD 1998-2012 Italy N=770 Median age 36 years | Mean, 5 years (range, 18 months-14 years) | Varied (combination of duodenal biopsy, serology, and HLA typing based on patient-specific factors) | 79% | 21% | Rate of complications (enteropathy-associated T-cell lymphoma, small bowel carcinoma, and refractory CD): 0.9%^†^ | Rate of complications (enteropathy-associated T-cell lymphoma, small bowel carcinoma, and refractory CD): 0%^†^

* Subclinical defined by presence of gluten-sensitive enteropathy with extraintestinal symptoms and no gastrointestinal symptoms.

† Difference between groups: p<0.001.

Abbreviations: AFB=Air Force Base; CD=celiac disease; CI=confidence interval; EMA=anti-endomysial antibody; HLA=human leukocyte antigen; IgA=immunoglobin A; NA=not applicable; NR=not reported; OR=odds ratio; tTG=tissue transglutaminase.