# 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^34^ the USPSTF and AHRQ determined the scope and key questions for this review. In conjunction with USPSTF members and the AHRQ Medical Officer, investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed (Figure).

Figure Analytic Framework

Abbreviation: KQ=key question.

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the populations, interventions and related harms, and outcomes. The population includes asymptomatic adults, adolescents, and children. An arrow from the population leads to screening, followed by normal or abnormal diagnosis. A subsequent arrow from the screening intervention assesses resulting harms. An arrow leading from abnormal screening results incorporates treatment and leads to the outcomes examined in the review, which are cancer incidence; gastrointestinal outcomes; mood and anxiety disorders; child growth outcomes; health outcomes resulting from nutritional deficiencies, including symptomatic or severe anemia; other morbidity outcomes; quality of life; and mortality. A subsequent arrow from treatment assesses resulting harms. An additional overarching arrow in the framework examines the effect of screening on outcomes.

### Key Questions

1. What is the effectiveness of screening versus not screening for celiac disease in asymptomatic adults, adolescents, or children on morbidity, mortality, or quality of life?
2. What is the effectiveness of targeted versus universal screening for celiac disease in asymptomatic adults, adolescents, or children on morbidity, mortality, or quality of life? (Targeted screening refers to testing in patients with family history or other risk factors for celiac disease.)
3. What are the harms of screening for celiac disease?
4. What is the accuracy of screening tests for celiac disease?
5. Does treatment of screen-detected celiac disease lead to improved morbidity, mortality, or quality of life compared with no treatment?
6. Does treatment of screen-detected celiac disease lead to improved morbidity, mortality, or quality of life compared with treatment initiated after clinical diagnosis?
7. What are the harms associated with treatment of celiac disease?

We also addressed two contextual questions requested by the USPSTF to help inform the report. Contextual questions address background areas identified by the USPSTF for informing its recommendations and are not reviewed using systematic review methodology, but rather summarize important contextual evidence.^34^

### Contextual Questions

1. Among patients without overt symptoms, what is the prevalence of celiac disease in children, adolescents, and adults in the United States?
2. What is the natural history of subclinical or silent celiac disease?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews and Ovid MEDLINE (to mid-June 2016) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). For screening and diagnosis, the population of interest was asymptomatic adults, adolescents, or children age 3 years or older without known celiac disease who had not sought evaluation for potential celiac disease, including persons at higher risk due to family history or presence of conditions associated with celiac disease. For treatment, the population of interest was persons with screen-detected celiac disease who were asymptomatic. We included studies of mildly symptomatic patients if no studies were available in asymptomatic populations. Screening tests were serologic tests or questionnaires. We included randomized trials, cohort studies, and case-control studies performed in primary care or primary care–applicable settings of screening versus no screening, targeted versus universal screening, treatment versus no treatment, and immediate versus delayed treatment that reported morbidity (including outcomes related to nutritional deficiencies, gastrointestinal symptoms), cancer incidence, mood and anxiety, child growth outcomes, infection rates, quality of life, or mortality. For diagnostic accuracy, we included cohort and cross-sectional studies that compared screening tests against endoscopy with biopsy as the reference standard. We excluded studies that focused on intermediate outcomes such as laboratory values for nutritional or other deficiencies and studies that evaluated diagnostic accuracy using a case-control design. To summarize the diagnostic accuracy of screening tests in populations that were not asymptomatic, we included good-quality systematic reviews. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about each article's study design, patient population, setting, screening method, treatment regimen, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Two investigators independently applied criteria developed by the USPSTF^34^ to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through consensus.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each key question (“good,” “fair,” or “poor”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence.^34^ There were too few studies to perform meta-analysis.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners, and posted for public comment.

## Response to Public Comments

The draft report was posted for public comment on the USPSTF Web site from May 3, 2016 to May 30, 2016, and few comments were received. No comments identified missing studies or errors in the evidence reviewed, resulting in no changes to the findings or conclusions of the report.