# 1 Introduction

## Purpose and Previous U.S. Preventive Services Task Force Recommendation

This report, commissioned by the Agency for Healthcare Research and Quality (AHRQ), will be used by the U.S. Preventive Services Task Force (USPSTF) to develop a recommendation on screening for celiac disease in adults, adolescents, and children age 3 years or older. This topic has not previously been reviewed by the USPSTF.

## Condition Definition

Celiac disease is a multisystem autoimmune disorder in genetically predisposed persons that is triggered by ingestion of dietary gluten. Gluten is a protein complex found in wheat, rye, and barley. In persons with celiac disease, ingestion of gluten causes immune-mediated inflammatory damage to the mucosa of the small intestine and subsequent malabsorption of nutrients. Celiac disease can manifest as both gastrointestinal and nongastrointestinal illness. Other names for the disorder include celiac sprue, gluten-sensitive enteropathy, and nontropical sprue.

## Prevalence

A challenge in estimating prevalence of celiac disease is that in a number of studies, diagnosis was based on serologic testing without histologic confirmation, potentially overestimating prevalence of celiac disease due to false-positive serologic tests. However, a systematic review of 38 studies in North America and Western Europe found that celiac disease prevalence was 0.15 to 1.87 percent in studies that included biopsy confirmation of positive serologic tests, and was similar (0.15% to 2.67%) in studies that did not perform biopsy confirmation in all patients; among the three U.S. studies, prevalence ranged from 0.40 to 0.95 percent in adults.^1^ In the largest multicenter U.S. study included in the systematic review, overall prevalence of celiac disease diagnosed by endomysial antibody (EMA)-positive serology and confirmed by biopsy (<30%) or human leukocyte antigen (HLA) haplotypes DQ2 and DQ8 among 4,126 average-risk persons was 0.75 percent, with prevalence of 0.95 percent among adults, 0.31 percent among children, 0.72 percent among women, and 0.78 percent among men.^2^ Prevalence among minority groups was 0.42 percent; results were not presented for specific minority groups. A screening study for celiac disease using stored sera from a population-based sample of adults age 50 years or older in Minnesota found that the prevalence of undiagnosed celiac disease was 0.8 percent, as defined by initial tissue transglutimase (tTG) immunoglobin (Ig)A testing followed by EMA tests.^3^ Median age of those diagnosed was 63 years and 51 percent were women. In a study of 7,798 persons age 6 years or older who participated in the 2009–2010 National Health and Nutrition Examination Survey (NHANES), the prevalence of celiac disease, as defined by positive serology or patient-self report, was 0.71 percent among the general population, 0.76 percent among those age 20 years or older, 0.62 percent among women, and 1.01 percent among non-Hispanic whites.^4^ Some data suggest that the prevalence of celiac disease in the United States has increased over the past several decades for reasons that are not well understood but may be related to changes in dietary gluten.^5-7^ (See Contextual Question 1 for prevalence of celiac disease among patients without overt symptoms.)

## Etiology, Natural History, and Burden of Disease

Celiac disease is caused by an immune response to dietary gluten in genetically susceptible persons. Specifically, persons with alleles that encode for HLA-DQ2 and DQ8 proteins are at risk for celiac disease. However, many persons with these alleles do not develop celiac disease, meaning that their presence is necessary but not sufficient for disease. Gliadin, the alcohol-soluble fraction of gluten, triggers both adaptive and innate immune system responses causing infiltration of inflammatory cells into the lamina propria and epithelium of the small intestine, resulting in villous atrophy.^8^ Inflammatory injury to the small intestine results in loss of absorptive surface area, reduction in digestive enzymes, and impaired absorption of micronutrients, including fat-soluble vitamins and iron. Although some research suggests an association between breastfeeding with delayed introduction of gluten into the infant diet and decreased risk of celiac disease,^9^ more recent literature has not found an association between breastfeeding and risk of celiac disease.^10, 11^ Gastrointestinal illness may increase the risk of celiac disease in infancy.^8^

Celiac disease affects both children and adults. Seroconversion to antibodies associated with celiac disease may occur at any time, and disease progression can take place over months or years.^12^ Data suggest that the average age at celiac disease diagnosis has increased and is now in the fourth to sixth decades of life.^13, 14^

The clinical presentation, severity of symptoms, and natural history of celiac disease varies among both adults and children. Classic celiac disease presents with symptoms of malabsorption, such as diarrhea, abdominal pain, and weight loss. In children, classic celiac disease is characterized by onset of gastrointestinal symptoms and impaired growth between ages 6 and 24 months, but this is now an uncommon presentation.^15^ Analysis of trends among 590 patients with biopsy-diagnosed celiac disease in New York from 1981 to 2004 found that the percentage presenting with diarrhea decreased from 91.3 percent before 1980 to 37.2 percent after 2000, perhaps due to increased awareness of celiac disease, increased screening in asymptomatic or mildly symptomatic persons, and/or ease of serologic testing.^13^ Celiac disease now presents more typically with nongastrointestinal, nonspecific manifestations of disease such as anemia, osteoporosis, chronic fatigue, peripheral neuropathy or ataxia, aphthous stomatitis, dermatitis herpetiformis, infertility, recurrent fetal loss, or short stature.^8^ Children may also experience pubertal delay and dental enamel defects.^15^

Another form of celiac disease is subclinical disease, or disease that is below the threshold of clinical detection (i.e., without signs or common symptoms sufficient to trigger testing for celiac disease).^16^ Persons with subclinical celiac disease may have nonspecific symptoms of celiac disease, such as fatigue, that are not recognized until initiation of a gluten-free diet. Asymptomatic, or silent, celiac disease refers to persons who have been diagnosed with celiac disease by serologic testing and intestinal biopsy but do not manifest any common symptoms or signs of celiac disease. Potential celiac disease refers to persons with and without symptoms who have positive serology but absent or mild intestinal damage on biopsy. Latent celiac disease, a less commonly used term, describes persons previously diagnosed with celiac disease who have normal intestinal mucosa while on a gluten-free diet or those with normal intestinal mucosa while on a gluten-containing diet who later develop celiac disease.^16, 17^ The natural history of subclinical, asymptomatic, potential, and latent celiac disease is not well-defined, and it is not entirely clear if they represent progressive stages of celiac disease or distinct subtypes.^18^ In an Italian retrospective study of 549 patients with celiac disease, 45.7 percent showed classical, 47.7 percent subclinical, and 6.6 percent silent forms of celiac disease at the time of diagnosis.^19^ (See Contextual Question 2 for additional details regarding the natural history of subclinical or silent celiac disease.)

Some evidence suggests that celiac disease is associated with excess mortality, which is primarily attributed to increased risk for intestinal adenocarcinoma and enteropathy-associated T-cell lymphoma.^8, 20^ A recent meta-analysis of observational studies from the United States and Europe showed an increased risk for all-cause mortality in persons with celiac disease (odds ratio [OR], 1.24 [95% confidence interval (CI), 1.19 to 1.30]).^20^ In a subgroup analysis, patients identified by positive serology alone were also at an increased risk of all-cause mortality (OR, 1.16 [95% CI, 1.02 to 1.31]) and non-Hodgkin lymphoma (OR, 2.55 [95% CI, 1.02 to 6.36]). However, some data suggest that asymptomatic or silent celiac disease is not associated with increased mortality or other complications of celiac disease. A retrospective study of 549 patients with celiac disease diagnosed by intestinal biopsy found that the rate of complications on a gluten-free diet for a mean duration of 7 years, including malignancy, was highest among those with classic celiac disease (5.58%); no patients with silent disease experienced complications.^19^

Nonceliac gluten sensitivity (NCGS) refers to a condition in which persons with symptoms such as abdominal pain and bloating improve with removal of exposure to gluten but do not have diagnostic features of celiac disease and are not thought to be at increased risk of nutritional deficiency states or other complications associated with celiac disease.^17^ Because NCGS is defined based on the presence of symptoms rather than on diagnostic tests, it does not meet criteria for screening and is therefore outside the scope of this review. NCGS is associated with a broad range of symptoms that may manifest as heterogeneous subtypes.^21^ A recent double-blinded trial of persons thought to have NCGS found no difference in symptoms following randomization and exposure to high-gluten, low-gluten, or nongluten diets, potentially calling into question the underlying concept for this condition.^22^

## Risk Factors

A positive family history is a risk factor for celiac disease. The frequency of celiac disease is higher among first- and second-degree relatives of persons with celiac disease, although prevalence estimates range from 5 to 20 percent.^2, 4, 23^ Frequency of celiac disease is also higher among persons with other autoimmune diseases, such as type 1 diabetes mellitus, inflammatory luminal gastrointestinal disorders, Down syndrome, Turner's syndrome, IgA deficiency, and IgA nephropathy.^3, 4, 9, 23^

As discussed previously, celiac disease is more commonly diagnosed among adults ages 40 to 60 years and among non-Hispanic whites. Data regarding risk of celiac disease among women is mixed, but several large-scale prevalence studies found that rates of celiac disease are similar among men and women.^2-4^ The major genetic risk factor for celiac disease is inheritance of HLA-DQ2 and DQ8 alleles, which is more likely among first- and second-degree relatives of persons with diagnosed celiac disease.^2^

## Rationale for Screening/Screening Strategies

Studies in the United States and Europe suggest that celiac disease may be underdiagnosed, based on the prevalence of positive serologic tests (initial tTG antibody tests followed by EMA testing for those with positive or borderline findings) in persons not previously diagnosed with celiac disease.^24^ Evidence also suggests that diagnosis of celiac disease is often delayed. A survey of 1,612 patients with celiac disease in the United States found that symptoms were present for a mean of 11 years before diagnosis.^25^ Screening might enable earlier initiation of treatment and reduce the burden of morbidity and mortality associated with untreated celiac disease.^9^

Clinical practice guidelines recommend an algorithmic approach to diagnostic testing for celiac disease, starting with the tTG IgA test and further testing based on the probability of disease.^26, 27^ The tTG IgA test is the standard method of testing for celiac disease in persons older than age 2 years. The reported sensitivity of the tTG IgA test is about 95 percent and specificity is 95 percent or greater.^26^ In patients in whom celiac disease is suspected but IgA deficiency is a consideration, total IgA levels are measured. Alternatively, IgA testing as well as tTG immunoglobulin G (IgG) and/or IgG deamidated gliadin peptide (DGP) tests can be obtained in such patients. Clinical practice guidelines in the United States and Europe recommend intestinal biopsy to confirm the diagnosis of celiac disease (e.g., based on presence of villous atrophy classified as grade 3 or higher on Marsh criteria) and to distinguish celiac disease from other disorders affecting the small intestine.^26, 27^ Intestinal biopsy may also be performed if clinical suspicion for celiac disease is high but serologic tests are negative. It has been suggested that a combination of serologic tests could be used to establish celiac disease diagnosis as an alternative to biopsy,^26, 27^ but it is unclear how frequently celiac disease is diagnosed in the absence of biopsy in current clinical practice.^28^ Rarely, capsule endoscopy is used to establish a diagnosis of celiac disease in patients who are unwilling or unable to undergo upper endoscopy with intestinal biopsy. HLA-DQ2/DQ8 genotyping is not used routinely to diagnose celiac disease but may be used to rule out the disease in cases with equivocal serologic tests and/or small-bowel histologic findings.

Many persons initiate a gluten-free diet prior to consultation with a health care provider, which complicates the diagnosis of celiac disease and may result in false-negative antibody tests or biopsies. Serologic testing may still be obtained depending on the duration of gluten-free diet, or deferred until gluten has been reintroduced into the diet. HLA-DQ2/DQ8 genotyping is sometimes used to exclude celiac disease before having patients undergo a gluten challenge.^26^

Antigliadin antibodies (AGAs) were previously routinely used to diagnose celiac disease but are no longer recommended due to inferior sensitivity and specificity compared with newer serologic tests. Likewise, intestinal permeability tests, D-xylose, and small bowel follow-through are not recommended to diagnose celiac disease.^26^

## Interventions/Treatment

The mainstay of treatment for celiac disease is lifelong adherence to a gluten-free diet.^29^ Short-term vitamin and mineral repletion may also be recommended. Removal of gluten from the diet reverses disease manifestations in a majority of patients.^9^ However, complete removal of gluten from the diet is a challenge, as gluten is present in a wide variety of foods, and gluten-free foods can be difficult to obtain and expensive. Nonadherence among patients is also common. A systematic review reported rates of strict adherence to a gluten-free diet of 42 to 91 percent, depending on the definition of adherence and method of ascertainment.^30^ Adherence was lowest among ethnic minorities and persons diagnosed in childhood, and rates of adherence were similar among screen-detected and symptomatic patients. Patients who do not respond to a gluten-free diet are often evaluated for concurrent lactose or other carbohydrate intolerance, pancreatic insufficiency, inflammatory bowel disease, and functional gastrointestinal disorders.^9^

Refractory celiac disease occurs in a minority of patients and is characterized by ongoing symptoms of malabsorption despite adherence to a gluten-free diet for 6 to12 months. These patients may receive treatment with corticosteroids and other immunosuppressive agents such as azathioprine, 6-mercaptopurine, or cyclosporine. Data regarding the effectiveness of these agents is limited to observational studies.^9^

## Current Clinical Practice/Recommendations of Other Groups

Clinical practice guidelines recommend testing for celiac disease among persons with signs and symptoms of malabsorption as well as certain populations of asymptomatic persons at increased risk for celiac disease (Table 1).^26, 31-33^ Reliable data on the frequency of screening for celiac disease in clinical practice is not available.^12, 24^

Table 1 Recommendations of Other Groups

Organization | Screening/Testing Recommendation for Celiac Disease
American College of Gastroenterology^26^ | - Persons with signs/symptoms of malabsorption; - Symptomatic persons with type 1 diabetes mellitus; - Asymptomatic persons with elevated serum aminotransferase; - Symptomatic and asymptomatic first-degree relatives of patients with celiac disease
National Institute for Health and Care Excellence, United Kingdom^31^ | - Persons with any of the following:; ○ Persistent unexplained abdominal or gastrointestinal symptoms; ○ Faltering growth; ○ Prolonged fatigue; ○ Unexpected weight loss; ○ Severe or persistent mouth ulcers; ○ Unexplained iron, vitamin B12, or folate deficiency; ○ Type 1 diabetes, at diagnosis; ○ Autoimmune thyroid disease, at diagnosis; ○ Irritable bowel syndrome (in adults); - First-degree relatives of persons with celiac disease; - Consider serologic testing for persons with any of the following:; ○ Metabolic bone disorder (reduced bone mineral density or osteomalacia); ○ Unexplained neurological symptoms (particularly peripheral neuropathy or ataxia); ○ Unexplained subfertility or recurrent miscarriage; ○ Persistently raised liver enzymes with unknown cause; ○ Dental enamel defects; ○ Down syndrome; ○ Turner syndrome
North American Society for Pediatric Gastroenterology, Hepatology, and Nutrition^33^ | - Asymptomatic children age ≥3 years with type 1 diabetes mellitus, autoimmune thyroiditis, Down syndrome, Turner syndrome, Williams syndrome, and selective IgA deficiency; - Asymptomatic children age ≥3 years who are first-degree relatives of patients with celiac disease; - Children with failure to thrive, persistent diarrhea, and other gastrointestinal symptoms; - Children with dermatitis herpetiformis, dental enamel hypoplasia of permanent teeth, osteoporosis, short stature, delayed puberty, and iron-deficiency anemia resistant to oral iron
Ontario Health Technology Advisory Committee^32^ | - Persons with signs/symptoms of malabsorption; - Persons with unexplained iron-deficiency anemia unresponsive to iron supplementation; - Persons with dermatitis herpetiformis

Abbreviation: IgA=immunoglobin A.

The complex clinical spectrum of celiac disease complicates diagnosis and management. Due to recent media attention to gluten and its potential adverse effects on health, many persons start a gluten-free diet without medical advice.^12^ Some experience improvement in gastrointestinal symptoms that are attributed to celiac disease. As discussed previously, clinical improvement on a gluten-free diet is not diagnostic of celiac disease, as many other forms of gluten reaction have been described. Symptomatic improvement may also be due to a placebo effect or to other healthful changes that occur in conjunction with a modified diet.