# Appendix B Evidence and Quality Tables

## Appendix B1 Systematic Review of Diagnostic Accuracy Studies

Study, year | Aims | Databases searched; Literature search dates; Other data sources | Eligibility criteria | Patients/studies | Characteristics of identified articles: study designs | Characteristics of identified articles: populations
Maglione, 2016^35^ | To assess the evidence on the comparative accuracy and safety of tests used to diagnose celiac disease, including serologic tests, HLA typing, video capsule endoscopy, and endoscopic duodenal biopsy. | Databases: PubMed, Embase, Cochrane Library, and Web of Science Search dates: 1990 to 2015 Additional data sources: Unpublished data were requested by the AHRQ-funded Scientific Resource Center and from manufacturers of all serologic tests | Controlled trials, prospective and retrospective cohorts, case-control studies, and case series that used endoscopy with duodenal biopsy as the reference standard, applied the index test and reference standard in all subjects, enrolled a consecutive or random sample, and included ≥300 patients (unless it assessed a special population), and reported sensitivity and specificity (or data that allowed calculation) | 56 studies and 12 prior systematic reviews (27 studies and 10 systematic reviews addressed comparative diagnostic accuracy; 23 of the studies were newly published and not included in the systematic reviews) Sample sizes ranged from 62 to >12,000 | Systematic reviews: 10 Controlled trials: 0 Cohorts: 16 Case-control: 7 | 1 study in US, 3 in UK, 5 in the Middle East, 1 in India, and rest in continental Europe Race/ethnicity rarely described All studies included symptomatic patients or those with risk factors or family history of celiac disease 6 studies were conducted in children and/or adolescents, and an additional 3 studies included a mixed population of children and adults

Study, year | Characteristics of identified articles: interventions | Pooled results | Conclusion | Quality
Maglione, 2016^35^ | Video capsule endoscopy: 2 systematic reviews tTG: 3 systematic reviews and 16 original studies (3 in special populations) EMA: 2 systematic reviews and 5 original studies DGP: 3 systematic reviews and 2 original studies HLA typing: no evidence in general population (2 studies in special populations) Algorithms: 8 original studies | Video capsule endoscopy Sensitivity: 89.0% (95% CI, 82.0%-94.0%) Specificity: 95.0% (95% CI, 89.0%-99.0%) LR+: 12.9 (95% CI, 2.9-57.6) LR-: 0.16 (95% CI, 0.10-0.25) tTG Sensitivity: 92.8% (95% CI, 90.3%-94.8%) Specificity: 97.9% (95% CI, 96.4%-98.8%) LR+: 45.1 (95% CI, 25.1-75.5) LR-: 0.07 (95% CI, 0.05-0.10) EMA Sensitivity: 73.0% (95% CI, 61.0%-83.0%) Specificity: 99.0% (95% CI, 98.0%-99.0%) LR+: 65.6 (95% CI, 35.6-120.8) LR-: 0.28 (95% CI, 0.17-0.41) DGP Sensitivity: 87.8% (95% CI, 85.6%-89.9%) Specificity: 94.1% (95% CI, 92.5%-95.5%) LR+: 13.3 (95% CI, 9.6-18.4) LR-: 0.12 (95% CI, 0.08-0.18) HLA typing No evidence Algorithms using ≥1 tests Insufficient evidence due to heterogeneity | tTG, EMA, DGP, and video capsule endoscopy are all highly accurate. Additional studies are needed on accuracy of algorithms and accuracy of testing in special populations. | Good

Abbreviations: AHRQ=Agency for Healthcare Research and Quality; CD=celiac disease; DGP=deamidated gliadin peptide; EMA=endomysial antibody; HLA=human leukocyte antigen; tTG=tissue transglutaminase; UK=United Kingdom; US=United States.

## Appendix B2 Quality Assessment of Systematic Review of Diagnostic Accuracy Studies

Study, Year | Search dates | Search methods reported | Comprehensive search | Inclusion criteria reported | Selection bias avoided | Validity criteria reported | Validity assessed appropriately | Methods used to combine studies reported | Findings combined appropriately | Conclusions supported by data | Quality
Maglione, 2016^35^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

## Appendix B3 Diagnostic Accuracy Studies in Asymptomatic Populations

Study, Year | Type of study | Screening tests | Reference standard | Setting | Screener | Age of enrollees | N | Proportion with condition | Subjects
Mansour, 2011^40^ | Cross-sectional | tTG IgA, tTG IgG, EMA IgA, AGA IgA, and AGA IgG | Biopsy | University Hospital Iraq | NR | Mean age, 23.4 years (range, 8 to 42 years) | 62 | Marsh 3 a-c: 11.3% (7/62) | Type 1 diabetes patients with no symptoms associated with celiac disease and no family history of celiac disease or thyroid disorders
Nevoral, 2014^37^ | Cross-sectional | tTG IgA and EMA IgA | Biopsy | Single pediatric department Czech Republic | NR | Range, 16 months-19 years | 345 (158 asymptomatic) | Marsh 2 or 3: Asymptomatic, 78.5% (124/158) All children, 76% (263/345) | Children and adolescents examined for suspected celiac disease

Study, Year | Sensitivity | Specificity | AUROC | Quality
Mansour, 2011^40^ | tTG IgA: 71% tTG IgG: 57% EMA IgA: 71% AGA IgA: 57% AGA IgG: 57% | tTG IgA: 93% tTG IgG: 93% EMA IgA: 96% AGA IgA: 98% AGA IgG: 98% | NR | Fair
Nevoral, 2014^37^ | tTG IgA >10 ULN and positive EMA test: 67% Subgroups First-degree relatives (n=32): 70% Type 1 diabetes mellitus (n=40): 64% | tTG IgA >10 ULN and positive EMA test: 83% Subgroups First-degree relatives (n=32): 81% Type 1 diabetes mellitus (n=40): 93% | NR | Fair

Abbreviations: AGA=antigliadin antibodies; AUROC=area under the receiver operating curve; EMA=endomysial antibody; IgA=immunoglobulin A; IgG=immunoglobulin G; NR=not reported; tTG=tissue transglutaminase; ULN=upper limit of normal.

## Appendix B4 Quality Assessment of Diagnostic Accuracy Studies in Asymptomatic Populations

Study, year | Appropriate spectrum of patients | Adequate sample size (>500) | Credible reference standard used | Reference standard applied to all patients | Screening test adequately described | Reference standard interpreted independently | Quality
Mansour, 2011^40^ | Unclear | No | Yes; biopsy | Yes | Yes | Unclear | Fair
Nevoral, 2014^37^ | Unclear | No | Yes; biopsy | Yes | Yes | Unclear | Fair

## Appendix B5 Randomized, Controlled Trial of Treatment

Author, year | Study design | No. of centers, Country | Study duration Mean followup | Interventions | Patient characteristics | Inclusion/Exclusion criteria | Number screened Number eligible Number enrolled Number analyzed Withdrawals Loss to followup
Kurppa, 2014^59^ | RCT | 1 center Finland | 1 year followup | A. Gluten diet (n=20) B. Gluten-free diet (GFD) group (n=20) Note: 1 person in group A started a gluten-free diet soon after randomization, but was analyzed in the gluten group due to the intention-to-treat analysis. | A vs. B Median age (range): 42 (23-62) vs. 42 (21-74) % female: 25% vs. 45% Hypothyroidism: 10% vs. 5% Other chronic condition: 35% vs. 35% Osteoporotic fracture: 0% vs. 0% Females: Infertility or frequent miscarriages: 20% vs. 11% Median age at menarche (range): 13 (13-15) vs. 13 (9-14) years | Targeted screening (recruited relatives of celiac patients). Included EMA-positive adults (ages 18-75 years) who considered themselves asymptomatic (defined as an absence of: abdominal pain [>3 episodes over ≥3 months interfering with function], constipation [<3 bowel movements per week or difficulty during defecation], and diarrhea [≥3 loose stools/day], and extraintestinal symptoms such as joint pain, blistering rash or unexplained neurologic symptoms, and alarm symptoms including unexplained severe weight loss, vomiting, frequent or continuous fever, or rectal bleeding). Celiac disease was defined as the presence of positive EMA and gluten-dependent enteropathy. Excluded those with a previous diagnosis of celiac disease, age <18 years, evident clinical symptoms, dietary gluten restriction, severe contemporary illness or immunosuppressive medication, or ongoing or planned pregnancy. | Screened: 3,031 at- risk volunteers Eligible: 40 Enrolled: 40 Analyzed: 40 Withdrawals or loss to followup: None

Author, year | Outcomes assessed | Clinical health outcomes | Clinical health outcomes: subgroups | Adverse events | Quality rating | Funding source
Kurppa, 2014^59^ | Serology Celiac-related genotyping Gastrointestinal Symptoms Rating Scale (GSRS): 7-point Likert scale, higher score indicates more severe symptoms Psychological General Well-Being (PGWB): 6-point Likert scale, higher score indicates better health-related quality of life Short-Form 36-Item Health Survey (SF-36): 0-100, higher score indicates better health-related quality of life Visual Analogue Scale (VAS): 0-100, higher score indicates better subjective perception of health Laboratory parameters Bone mineral density Body composition Small bowel mucosal morphology and inflammation | [underlined: Gastrointestional symptoms after 1 year, difference in mean change (95% CI):] GSRS Total, -0.4 (-0.7 to -0.1); p=0.003, favors GFD GSRS Diarrhea, -0.6 (-1.1 to 0.0); p=0.052, favors GFD GSRS Indigestion, -0.7 (-1.1 to -0.2); p=0.006, favors GFD GSRS Constipation, -0.1 (-0.5 to 0.3); p=0.325 GSRS Abdominal pain, -0.2 (-0.5 to 0.2); p=0.126 GSRS Reflux, -0.5 (-0.9 to -0.1); p=0.050, favors GFD [underlined: Psychological general well-being, after 1 year, difference in mean change (95% CI):] PGWB Anxiety, 1.6 (0.4 to 2.8); p=0.025, favors GFD PGWB Depression, 0.3 (-0.5 to 1.2); p=0.281 PGWB Well-being, 0.5 (-1.0 to 2.0); p=0.700 PGWB Self-control, 0.3 (-0.7 to 1.4); p=0.775 PGWB General health, 0.7 (-1.0 to 2.4); p=0.532 PGWB Vitality, 0.4 (-1.5 to 2.2); p=0.670 [underlined: SF-36, after 1 year, difference in mean change (95% CI):] SF-36 Physical functioning, -2.8 (-8.2 to 2. 6), p=0.299 SF-36 Role limitations due to physical problems, 2.3 (-12.4 to 17); p= 0.749 SF-36 Role limitations due to emotional problems, 7.2 (-12.6 to 27); p=0.464 SF-36 Vitality, 6.0 (-4.3 to 16.4); p=0.245 SF-36 Mental health, 2.6 (-3.8 to 8.9); p=0.414 SF-36 Social functioning, -8.3 (-15.8 to -0.8); p=0.031, favors gluten group SF-36 Bodily pain, 0.8 (-9.8 to 11.4); p=0.881 SF-36 General health, 2.8 (-7.1 to 12.7); p=0.568 VAS: Improved in the GFD group (p=0.017) [underlined: Laboratory parameters]: Mean blood hemoglobin (SD), g/dL: A. Baseline: 14.3 ± 1.4, Change after 1 year: -0.2 ± 0.6 B. Baseline: 14.4 ± 1.6, Change after 1 year: -0.2 ± 0.7 Mean difference between groups, 0.0 (95% CI, -0.4 to 0.4); p=0.902 Mean serum total iron (SD), micromol/L: A. Baseline: 17.3 ± 5.7, Change after 1 year: 2.8 ± 6.8 B. Baseline: 20.0 ± 8.6, Change after 1 year: 0.3 ± 7.2 Mean difference between groups, -2.5 (95% CI, -7.0 to 2.1); p=0.288 [underlined: Body composition]: Mean BMI (SD), kg/m^2^: A. Baseline: 26.4 ± 3.7, Change after 1 year: -0.3 ± 1.0 B. Baseline: 27.0 ± 6.8, Change after 1 year: 0.0 ± 1.2 Mean difference between groups, 0.3 (95% CI, -0.5 to 1.0); p=0.451 Mean % total body fat (SD): A. Baseline: 28.9 ± 8.2, Change after 1 year: -0.6 ± 2.4 B. Baseline: 34.0 ± 8.9, Change after 1 year: -1.2 ± 3.4 Mean difference between groups, -0.5 (95% CI, -2.4 to 1.4); p=0.600 [underlined: BMD:] Mean lumbar spine (SD), g/cm^2^: A. Baseline: 1.17 ± 0.21, Change after 1 year, -0.01 ± 0.03 B. Baseline: 1.17 ± 0.19, Change after 1 year, 0.00 ± 0.02 Mean difference between groups, 0.01 (95% CI, -0.01 to 0.02); p=0.338 Mean femur neck (SD), g/cm^2^: A. Baseline: 1.00 ± 0.12, Change after 1 year: -0.1 ± 0.03 B. Baseline: 0.97 ± 0.14 Change after 1 year: 0.00 ± 0.02 Mean difference between groups, 0.01 (95% CI, -0.01 to 0.03); p=0.182 | NA | No withdrawals “as a result of major symptoms or complications” | Fair | Academy of Finland Research Council for Health, the Competitive Research Funding of the Pirkanmaa Hospital District, the Sigrid Juselius Foundation, the Finnish Foundation for Gastroenterological Research, the Yrjo Jahnsson Foundation, the Finnish Medical Foundation, the Foundation for Pediatric Research, and the Finnish Celiac Society.

Abbreviations: BMD=bone mineral density; BMI=body mass index; CI=confidence interval; EMA=endomysial antibody; GFD=gluten-free diet; GSRS=Gastrointenstinal Symptoms Rating Scale; HRQOL=health-related quality of life; NA=not applicable; PGWB=Psychological General Well-Being; RCT=randomized, controlled trial; SD=standard deviation; SF-36=Short-Form 36-Item Health Survey; VAS=visual analogue scale.

## Appendix B6 Quality Assessment of Randomized, Controlled Trial of Treatment

Author, year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and withdrawals reported? | Loss to followup: differential/ high? | Analyze people in the groups in which they were randomized? | Quality
Kurppa, 2014^59^ | Yes | Yes | Mostly | Yes | Yes | Not possible | Not possible | Yes | No/No | Yes | Fair