# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Screening Effectiveness and Harms

[underlined: Database: Ovid MEDLINE and Ovid OLDMEDLINE]

1. Celiac Disease/
2. (celiac adj1 (disease or sprue)).mp.
3. 1 or 2
4. Mass Screening/
5. 3 and 4
6. screening.ti,ab.
7. 3 and 6
8. 5 or 7
9. limit 8 to humans
10. limit 9 to English language
11. limit 9 to abstracts
12. 10 or 11
13. limit 12 to (clinical trial, all or comparative study or controlled clinical trial or randomized controlled trial)
14. 12 and (random$ or control$ or cohort).mp.
15. 13 or 14
16. meta-analysis.mp. or exp Meta-Analysis/
17. (cochrane or medline).tw.
18. search$.tw.
19. 16 or 17 or 18
20. “Review Literature as Topic”/ or systematic review.mp.
21. 19 or 20
22. 12 and 21
23. limit 12 to (meta analysis or systematic reviews)
24. limit 12 to evidence based medicine reviews
25. or/22-24
26. 15 or 25

[underlined: Database: EBM Reviews - Cochrane Central Register of Controlled Trials]

1. Celiac Disease/
2. (celiac adj1 (disease or sprue)).mp.
3. 1 or 2
4. Mass Screening/
5. 3 and 4
6. screening.ti,ab.
7. 3 and 6
8. 5 or 7
9. limit 8 to English language

### Diagnostic Accuracy

[underlined: Database: Ovid MEDLINE and Ovid OLDMEDLINE]

1. Celiac Disease/
2. (celiac adj1 (disease or sprue)).mp.
3. 1 or 2
4. Immunoglobulin A/
5. Transglutaminases/
6. (IgA or TTG).mp.
7. or/4-6
8. 3 and 7
9. 8 and screen$.mp.
10. “Sensitivity and Specificity”/
11. (specificity or accurac$ or “predictive value”).tw.
12. (sensitiv$ or diagnostic).mp.
13. or/10-12
14. 3 and 13
15. 14 and screen$.mp.
16. 9 or 15
17. limit 16 to English language
18. limit 16 to abstracts
19. 17 or 18
20. limit 19 to humans

[underlined: Database: EBM Reviews - Cochrane Central Register of Controlled Trials]

1. Celiac Disease/
2. (celiac adj1 (disease or sprue)).mp.
3. 1 or 2
4. Immunoglobulin A/
5. Transglutaminases/
6. (IgA or TTG).mp.
7. or/4-6
8. 3 and 7
9. 8 and screen$.mp.
10. “Sensitivity and Specificity”/
11. (specificity or accurac$ or “predictive value”).tw.
12. (sensitiv$ or diagnostic).mp.
13. or/10-12 (
14. 3 and 13
15. 14 and screen$.mp.
16. 9 or 15
17. limit 16 to english language
18. limit 16 to abstracts
19. 17 or 18

### Treatment Effectiveness and Harms

[underlined: Database: Ovid MEDLINE and Ovid OLDMEDLINE]

1. Celiac Disease/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention & Control, Therapy]
2. (celiac adj1 (disease or sprue)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
3. 2 and (dh or dt or pc or th).fs.
4. 1 or 3
5. Diet, Gluten-Free/
6. Celiac Disease/
7. 5 and 6
8. 4 or 7
9. limit 8 to (clinical trial or comparative study or controlled clinical trial or randomized controlled trial)
10. 8 and (random$ or control$ or cohort).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
11. 9 or 10
12. limit 8 to (meta analysis or systematic reviews)
13. limit 8 to evidence based medicine reviews
14. meta-analysis.mp. or exp Meta-Analysis/
15. (cochrane or medline).tw.
16. search$.tw.
17. 14 or 15 or 16
18. “Review Literature as Topic”/ or systematic review.mp.
19. 17 or 18
20. 8 and 19
21. 11 or 12 or 13 or 20
22. limit 21 to English language
23. limit 21 to abstracts
24. 22 or 23
25. limit 24 to humans

[underlined: Database: EBM Reviews - Cochrane Central Register of Controlled Trials]

1. Celiac Disease/
2. (celiac adj1 (disease or sprue)).mp.
3. Diet, Gluten-Free/
4. 1 or 2 or 3

### Systematic Reviews (all Key Questions)

[underlined: Databases: EBM Reviews - Cochrane Database of Systematic Reviews, EBM Reviews - ACP Journal Club, EBM Reviews - Database of Abstracts of Reviews of Effects, EBM Reviews - Cochrane Central Register of Controlled Trials, EBM Reviews - Cochrane Methodology Register, EBM Reviews - Health Technology Assessment, EBM Reviews - NHS Economic Evaluation Database]

1. (celiac or coeliac).ti.
2. 1 and gluten.mp.

## Appendix A2 Inclusion and Exclusion Criteria

| Include | Exclude
Populations | KQs 1–3: Asymptomatic adults, adolescents, or children age ≥3 years without known celiac disease who have not sought evaluation for potential celiac disease (some “asymptomatic” individuals may have mild, nonspecific symptoms); studies of asymptomatic patients at higher risk (including patients with type 1 diabetes) KQ 4: Asymptomatic adults, adolescents, or children age ≥3 years without known celiac disease; studies of asymptomatic patients at higher risk (including patients with type 1 diabetes) KQs 5–7: Patients with screen-detected celiac disease (if evidence in such patients is unavailable or very limited, patients with mild celiac disease will be included); studies of asymptomatic patients at higher risk (including patients with type 1 diabetes) | KQs 1–3: Symptomatic persons seeking evaluation for potential celiac disease
Interventions | KQs 1, 2: Serologic screening (tTG IgA or other commonly used tests) KQ 3: Serologic screening (tTG IgA or other commonly used tests); diagnostic testing KQ 4: Serologic screening (tTG IgA or other commonly used tests); questionnaires KQs 5–7: Gluten-free diet | KQ 4: Screening with biopsy only in patients with positive serology
Comparators | KQ 1: Screening vs. no screening KQ 2: Targeted vs. universal screening KQ 4: Endoscopy with biopsy KQ 5: Screen-detected treatment vs. no treatment KQ 6: Screen-detected celiac disease vs. disease detected after clinical diagnosis
Outcomes | KQs 1, 2, 5, 6: Morbidity (including outcomes related to nutritional deficiencies, such as symptomatic or severe anemia [i.e., requiring treatment]), gastrointestinal outcomes (e.g., diarrhea, cramping, bloating), cancer incidence, mood and anxiety disorders, child growth outcomes, infection rates, and quality of life; mortality KQ 3: Labeling, complications/harms from workup/biopsy, and overdiagnosis KQ 4: Sensitivity, specificity, positive and negative predictive values, area under the receiver operating curve, and other measures of diagnostic test accuracy KQ 7: Any harms of treatment | KQs 1, 2, 5, 6: Laboratory values for nutritional or other deficiencies
Settings | KQs 1–3: Primary care | KQs 1–3: Specialty clinics
Study designs | KQs 1–3, 7: Randomized, controlled trials; controlled observational studies; systematic reviews KQ 4: Studies evaluating diagnostic accuracy of serologic screening or questionnaires compared with intestinal biopsy; systematic reviews KQs 5, 6: Randomized, controlled trials; systematic reviews | KQ 4: Case-control studies

Abbreviations: IgA=immunoglobulin A; KQ=key question; tTG= tissue transglutaminase.

## Appendix A3 Literature Flow Diagram

^*^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^†^ Other sources include prior reports, reference lists of relevant articles, and systematic reviews

This figure is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 3,036 abstracts of potentially relevant articles were identified through MEDLINE and Cochrane databases and other sources, while 217 articles were reviewed at the full-text level after excluding 2,819 nonrelevant abstracts and background articles. From the 217 articles reviewed for inclusion, 213 were excluded due to: wrong population (32), wrong intervention (7), wrong outcome (2), wrong comparison (23), wrong study design for key question (77), not a study (letter, editorial, nonsystematic review article [15]), systematic review used as source document only to identify individual studies (2), and study already in included systematic review (55). Four studies were included. For key questions 1, 2, 3, and 6, no studies were included. For key question 4, 1 systematic review (including 2 studies of asymptomatic persons) was included. For key question 5, 1 trial was included. For key question 7, 1 trial was included.

## Appendix A4 Excluded Studies List

Arguelles-Grande C, Tennyson CA, Lewis SK, . Variability in small bowel histopathology reporting between different pathology practice settings: impact on the diagnosis of coeliac disease. J Clin Pathol. 2012;65(3):242-7. Excluded: Individual study in included systematic review.22081783
Atay O, Mahajan L, Kay M, . Risk of capsule endoscope retention in pediatric patients: a large single-center experience and review of the literature. J Pediatr Gastroenterol Ntr. 2009;49(2):196-201. Excluded: Individual study in included systematic review.
Barada K, Habib RH, Malli A, . Prediction of celiac disease at endoscopy. Endoscopy. 2014;46(2):110-9. Excluded: Individual study in included systematic review.24477366
Basso D, Guariso G, Bozzato D, . New screening tests enrich anti-transglutaminase results and support a highly sensitive two-test based strategy for celiac disease diagnosis. Clin Chim Acta. 2011;412(17-18):1662-7. Excluded: Individual study in included systematic review.21640087
Bonamico M, Mariani P, Thanasi E, . Patchy villous atrophy of the duodenum in childhood celiac disease. J Pediatr Gastroenterol Nutr. 2004;38(2):204-7. Excluded: Individual study in included systematic review.14734885
Bonamico M, Thanasi E, Mariani P, . Duodenal bulb biopsies in celiac disease: a multicenter study. J Pediatr Gastroenterol Nutr. 2008;47(5):618-22. Excluded: Individual study in included systematic review.18979585
Bruins MJ. The clinical response to gluten challenge: a review of the literature. Nutrients. 2013;5(11):4614-41. Excluded: Individual study in included systematic review.24284613
Caruso R, Marafini I, Del Vecchio Blanco G, . Sampling of proximal and distal duodenal biopsies in the diagnosis and monitoring of celiac disease. Dig Liver Dis. 2014;46(4):323-9. Excluded: Individual study in included systematic review.24394601
Cekin AH, Cekin Y, Sezer C. Celiac disease prevalence in patients with iron deficiency anemia. Turk J Gastroenterol. 2012;23(5):490-5. Excluded: Individual study in included systematic review.23161292
Cooper SJ, Lovatt TJ. Highs and lows of coeliac screening. Br J Biomed Sci. 2009;66(2):79-84. Excluded: Wrong study design for Key Question.19637648
Dahlbom I, Korponay-Szabo IR, Kovacs JB, . Prediction of clinical and mucosal severity of coeliac disease and dermatitis herpetiformis by quantification of IgA/IgG serum antibodies to tissue transglutaminase. J Pediatr Gastroenterol Ntr. 2010;50(2):140-6. Excluded: Individual study in included systematic review.
Dahle C, Hagman A, Ignatova S, . Antibodies against deamidated gliadin peptides identify adult coeliac disease patients negative for antibodies against endomysium and tissue transglutaminase. Ailment Pharmacol Ther. 2010;32(2):254-60. Excluded: Individual study in included systematic review.
DeGaetani M, Tennyson CA, Lebwohl B, . Villous atrophy and negative celiac serology: a diagnostic and therapeutic dilemma. Am J Gastroenterol. 2013;108(5):647-53. Excluded: Individual study in included systematic review.23644957
Dickey W, McMillan SA, McCrum EE, . Association between serum levels of total IgA and IgA class endomysial and antigliadin antibodies: implications for coeliac disease screening. Eur J Gastroenterol Hepatol. 1997;9(6):559-62. Excluded: Wrong study design for Key Question.9222726
Dieterich W, Laag E, Schopper H, . Autoantibodies to tissue transglutaminase as predictors of celiac disease. Gastroenterology. 1998;115(6):1317-21. Excluded: Wrong population.9834256
Diosdado B, Wapenaar MC, Franke L, . A microarray screen for novel candidate genes in coeliac disease pathogenesis. Gut. 2004;53(7):944-51. Excluded: Wrong intervention.15194641
Dogan Y, Yildirmaz S, Ozercan IH. Prevalence of celiac disease among first-degree relatives of patients with celiac disease. J Pediatr Gastroenterol Nutr. 2012;55(2):205-8. Excluded: Wrong study design for Key Question.22241509
Dutta AK, Chacko A, Avinash B. Suboptimal performance of IgG anti-tissue transglutaminase in the diagnosis of celiac disease in a tropical country. Dig Dis Sci. 2010;55(3):698-702. Excluded: Individual study in included systematic review.19333755
Edlinger-Horvat C, Fidler D, Huber W-D, . Serological screening for undiagnosed coeliac disease in male adolescents in lower Austria: a population based study. Eur J Pediatr. 2005;164(1):52-3. Excluded: Wrong study design for Key Question.15583917
El-Matary W, Huynh H, Vandermeer B. Diagnostic characteristics of given video capsule endoscopy in diagnosis of celiac disease: a meta-analysis. J Laparoendosc Adv Surg Tech A. 2009;Part A. 19(6):815-20. Excluded: Individual study in included systematic review.19405806
Emami MH, Karimi S, Kouhestani S. Is routine duodenal biopsy necessary for the detection of celiac disease in patients presenting with iron deficiency anemia? Int J Prev Med. 2012;3(4):273-7. Excluded: Individual study in included systematic review.22624084
Ensari A, Marsh MN, Morgan S, . Diagnosing coeliac disease by rectal gluten challenge: a prospective study based on immunopathology, computerized image analysis and logistic regression analysis. Clin Sci (Colch). 2001;101(2):199-207. Excluded: Wrong population.11473497
Esteve M, Rosinach M, Fernandez-Banares F, . Spectrum of gluten-sensitive enteropathy in first-degree relatives of patients with coeliac disease: clinical relevance of lymphocytic enteritis. Gut. 2006;55(12):1739-45. Excluded: Wrong study design for Key Question.16709658
Evans KE, Aziz I, Cross SS, . A prospective study of duodenal bulb biopsy in newly diagnosed and established adult celiac disease. Am J Gastroenterol. 2011;106(10):1837-742. Excluded: Individual study in included systematic review.21606978
Farre C, Humbert P, Vilar P, . Serological markers and HLA-DQ2 haplotype among first-degree relatives of celiac patients. Catalonian Coeliac Disease Study Group. Digest Dis Sci. 1999;44(11):2344-9. Excluded: Wrong study design for Key Question.10573385
Farrell RJ, Kelly CP. Diagnosis of celiac sprue. Am J Gastroenterol. 2001;96(12):3237-46. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).11774931
Fasano A, Berti I, Gerarduzzi T, . Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Arch Intern Med. 2003;163(3):286-92. Excluded: Wrong study design for Key Question.12578508
Ferre-Lopez S, Ribes-Koninckx C, Genzor C, . Immunochromatographic sticks for tissue transglutaminase and antigliadin antibody screening in celiac disease. Clin Gastroenterol Hepatol. 2004;2(6):480-4. Excluded: Wrong study design for Key Question.15181616
Ferretti J, Mazure R, Tanoue P, . Analysis of the structure and strength of bones in celiac disease patients. Am J Gastroenterol. 2003;98(2):382-90. Excluded: Wrong study design for Key Question.12591059
Fiore CE, Pennisi P, Ferro G, . Altered osteoprotegerin/RANKL ratio and low bone mineral density in celiac patients on long-term treatment with gluten-free diet. Horm Metab Res. 2006;38(6):417-22. Excluded: Wrong comparator.16823725
Ford AC, Chey WD, Talley NJ, . Yield of diagnostic tests for celiac disease in individuals with symptoms suggestive of irritable bowel syndrome: systematic review and meta-analysis. Arch Intern Med. 2009;169(7):651-8. Excluded: Individual study in included systematic review.19364994
Freitag T, Schuppan D. Screening for coeliac disease antigen source and performance of the anti-tissue transglutaminase ELISA. Dig Liver Dis. 2004;36(10):658-60. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).15506663
Friis SU, Gudmand-Hoyer E. Screening for coeliac disease in adults by simultaneous determination of IgA and IgG gliadin antibodies. Scand J Gastroenterol. 1986;21(9):1058-62. Excluded: Wrong study design for Key Question.3810005
Galli G, Esposito G, Lahner E, . Histological recovery and gluten-free diet adherence: A prospective 1-year follow-up study of adult patients with coeliac disease. Aliment Pharmacol Ther. 2014;40(6):639-47. Excluded: Wrong study design for Key Question.25066096
Garrote JA, Sorell L, Alfonso P, . A novel visual immunoassay for coeliac disease screening. Eur J Clin Invest. 1999;29(8):697-9. Excluded: Wrong population.10457154
Gheita TA, Fawzy SM, Nour El-Din AM, . Asymptomatic celiac sprue in juvenile rheumatic diseases children. Int J Rheum Dis. 2012;15(2):220-6. Excluded: Wrong population.22212536
Ghozzi M, Sakly W, Mankai A, . Screening for celiac disease, by endomysial antibodies, in patients with unexplained articular manifestations. Rheumatol Int. 2014;34(5):637-42. Excluded: Wrong comparator.24292850
Giersiepen K, Lelgemann M, Stuhldreher N, . Accuracy of diagnostic antibody tests for coeliac disease in children: summary of an evidence report. J Pediatr Gastroenterol Ntr. 2012;54(2):229-41. Excluded: Individual study in included systematic review.
Gillett HR, Freeman HJ. Comparison of IgA endomysium antibody and IgA tissue transglutaminase antibody in celiac disease. Can J Gastroenterol. 2000;14(8):668-71. Excluded: Wrong population.11185530
Giordano L, Valotti M, Bosetti A, . Celiac disease-related antibodies in Italian children with epilepsy. Pediatr Neurol. 2009;41(1):34-6. Excluded: Wrong population.19520271
Goh VL, Estrada DE, Lerer T, . Effect of gluten-free diet on growth and glycemic control in children with type 1 diabetes and asymptomatic celiac disease. J Pediatr Endocrinol. 2010;23(11):1169-73. Excluded: Wrong study design for Key Question.
Gomez JC, Selvaggio G, Pizarro B, . Value of a screening algorithm for celiac disease using tissue transglutaminase antibodies as first level in a population-based study. Am J Gastroenterol. 2002;97(11):2785-90. Excluded: Wrong comparator.12425549
Gomez V, Cheesman AR, Heckman MG, . Safety of capsule endoscopy in the octogenarian as compared with younger patients. Gastrointest Endosc. 2013;78(5):744-9. Excluded: Individual study in included systematic review.23790756
Gonczi J, Skerritt JH, Mitchell JD. A reliable screening test for coeliac disease: enzyme-linked immunosorbent assay to detect anti-gliadin antibodies in serum. Aust N Z J Med. 1991;21(5):723-31. Excluded: Wrong population.1759921
Gonzalez D, Mazure R, Mautalen C, . Body composition and bone mineral density in untreated and treated patients with celiac disease. Bone. 1995;16(2):231-4. Excluded: Wrong study design for Key Question.7756052
Grainge MJ, West J, Solaymani-Dodaran M, . The long-term risk of malignancy following a diagnosis of coeliac disease or dermatitis herpetiformis: a cohort study. Aliment Pharmacol Ther. 2012;35(6):730-9. Excluded: Wrong study design for Key Question.22288441
Greco L, Troncone R, De Vizia B, . Discriminant analysis for the diagnosis of childhood celiac disease. J Pediatr Gastroenterol Nutr. 1987;6(4):538-42. Excluded: Wrong study design for Key Question.3430260
Green PH. Mortality in celiac disease, intestinal inflammation, and gluten sensitivity. JAMA. 2009;302(11):1225-6. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).19755704
Grodzinsky E, Hed J, Lieden G, . Presence of IgA and IgG antigliadin antibodies in healthy adults as measured by micro-ELISA. Effect of various cutoff levels on specificity and sensitivity when diagnosing coeliac disease. Int Arch Allergy Appl Immunol. 1990;92(2):119-23. Excluded: Wrong study design for Key Question.2242925
Grodzinsky E, Hed J, Skogh T. IgA antiendomysium antibodies have a high positive predictive value for celiac disease in asymptomatic patients. Allergy. 1994;49(8):593-7. Excluded: Wrong study design for Key Question.7653735
Grodzinsky E, Ivarsson A, Juto P, . New automated immunoassay measuring immunoglobulin A antigliadin antibodies for prediction of celiac disease in childhood. Clin Diagn Lab Immunol. 2001;8(3):564-70. Excluded: Wrong population.11329459
Grodzinsky E, Jansson G, Skogh T, . Anti-endomysium and anti-gliadin antibodies as serological markers for coeliac disease in childhood: a clinical study to develop a practical routine. Acta Paediatrica. 1995;84(3):294-8. Excluded: Wrong population.7780251
Gross S, Bakker SF, van Bodegraven AA, . Increased IgA glycoprotein-2 specific antibody titres in refractory celiac disease. J Gastrointestin Liver Dis. 2014;23(2):127-33. Excluded: Wrong comparator.24949603
Guandalini S, Assiri A. Celiac disease: a review. [Review]. Jama, Pediatr. 2014;168(3):272-8. Excluded: Wrong study design for Key Question.24395055
Hadjivassiliou M, Kandler RH, Chattopadhyay AK, . Dietary treatment of gluten neuropathy. Muscle Nerve. 2006;34(6):762-6. Excluded: Wrong study design for Key Question.17013890
Hall NJ, Rubin G, Charnock A. Systematic review: adherence to a gluten-free diet in adult patients with coeliac disease. Aliment Pharmacol Ther. 2009;30(4):315-30. Excluded: Individual study in included systematic review.19485977
Hallert C, Granno C, Hulten S, . Living with coeliac disease: controlled study of the burden of illness. Scand J Gastroenterol. 2002;37(1):39-42. Excluded: Wrong comparator.11843033
Hallert C, Svensson M, Tholstrup J, . Clinical trial: B vitamins improve health in patients with coeliac disease living on a gluten-free diet. Aliment Pharmacol Ther. 2009;29(8):811-6. Excluded: Wrong comparator.19154566
Harewood GC, Murray JA. Diagnostic approach to a patient with suspected celiac disease: a cost analysis. Digest Dis Sci. 2001;46(11):2510-4. Excluded: Wrong comparator.11713962
Harrison E, Li K-K, Petchey M, . Selective measurement of anti-tTG antibodies in coeliac disease and IgA deficiency: an alternative pathway. Postgrad Med J. 2013;89(1047):4-7. Excluded: Individual study in included systematic review.22872871
Heil PM, Volc-Platzer B, Karlhofer F, . Transglutaminases as diagnostically relevant autoantigens in patients with gluten sensitivity. J Dtsch Dermatol Ges. 2005;3(12):974-8. Excluded: Wrong study design for Key Question.16405713
Hill I. What are the sensitivity and specificity of serologic tests for celiac disease? Do sensitivity and specificity vary in different populations? Gastroenterology. 2005;128(4 Suppl 1):S25-32. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).15825123
Hill ID. Screening for celiac disease. J Pediatr Gastroenterol Nutr. 2013;57(4):414-5. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).
Hizli S, Karabulut H, Ozdemir O, . Sensorineural hearing loss in pediatric celiac patients. Int J Pediatr Otorhinolaryngol. 2011;75(1):65-8. Excluded: Wrong comparator.21067821
Hjelle AM, Apalset E, Mielnik P, . Celiac disease and risk of fracture in adults--a review. Osteoporos Int. 2014;25(6):1667-76. Excluded: Wrong study design for Key Question.24691647
Hoffenberg EJ, Bao F, Eisenbarth GS, . Transglutaminase antibodies in children with a genetic risk for celiac disease. J Pediatr. 2000;137(3):356-60. Excluded: Wrong comparator.10969260
Hogen Esch CE, Csizmadia GDS, van Hoogstraten IMW, . Childhood coeliac disease: towards an improved serological mass screening strategy. Aliment Pharmacol Ther. 2010;31(7):760-6. Excluded: Wrong study design for Key Question.20047580
Hojsak I, Mozer-Glassberg Y, Segal Gilboa N, . Celiac disease screening assays for children younger than 3 years of age: the performance of three serological tests. Digest Dis Sci. 2012;57(1):127-32. Excluded: Wrong population.21847565
Holding S, Wilson F, Spradbery D. Clinical evaluation of the BioPlex 2200 Celiac IgA and IgG Kits - a novel multiplex screen incorporating an integral check for IgA deficiency. J Immunol Methods. 2014;405:29-34. Excluded: Wrong study design for Key Question.24424297
Hope BC, Ameratunga R, Austin PM, . Diagnostic utility of modified gliadin peptide antibody assays in New Zealand children. J Pediatr Gastroenterol Nutr. 2013;57(1):43-8. Excluded: Wrong population.23403444
Hopper AD, Cross SS, Sanders DS. Patchy villous atrophy in adult patients with suspected gluten-sensitive enteropathy: is a multiple duodenal biopsy strategy appropriate? Endoscopy. 2008;40(3):219-24. Excluded: Individual study in included systematic review.18058655
Hopper AD, Hadjivassiliou M, Hurlstone DP, . What is the role of serologic testing in celiac disease? A prospective, biopsy-confirmed study with economic analysis. Clin Gastroenterol Hepatol. 2008;6(3):314-20. Excluded: Wrong population.18328437
Iagnocco A, Ceccarelli F, Mennini M, . Subclinical synovitis detected by ultrasound in children affected by coeliac disease: a frequent manifestation improved by a gluten-free diet. Clin Exp Rheumatol. 2014;32(1):137-42. Excluded: Wrong population.24447910
Iovino P, Pascariello A, Russo I, . Difficult diagnosis of celiac disease: diagnostic accuracy and utility of chromo-zoom endoscopy. Gastrointest Endosc. 2013;77(2):233-40. Excluded: Wrong population.23200727
Johnston SD, Rodgers C, Watson RG. Quality of life in screen-detected and typical coeliac disease and the effect of excluding dietary gluten. Eur J Gastroenterol Hepatol. 2004;16(12):1281-6. Excluded: Wrong comparator.15618833
Juby LD, Rothwell J, Axon AT. Lactulose/mannitol test: an ideal screen for celiac disease. Gastroenterology. 1989;96(1):79-85. Excluded: Wrong study design for Key Question.2491824
Kalayci AG, Kansu A, Girgin N, . Bone mineral density and importance of a gluten-free diet in patients with celiac disease in childhood. Pediatrics. 2001;108(5):E89. Excluded: Wrong comparator.11694673
Kane EV, Newton R, Roman E. Non-Hodgkin lymphoma and gluten-sensitive enteropathy: estimate of risk using meta-analyses. Cancer Causes Control. 2011;22(10):1435-44. Excluded: Wrong study design for Key Question.21755296
Kappler M, Krauss-Etschmann S, Diehl V, . Detection of secretory IgA antibodies against gliadin and human tissue transglutaminase in stool to screen for coeliac disease in children: validation study. BMJ. 2006;332(7535):213-4. Excluded: Wrong study design for Key Question.16377644
Karagiozoglou-Lampoudi T, Zellos A, Vlahavas G, . Screening for coeliac disease in preschool Greek children: the feasibility study of a community-based project. Acta Paediatr. 2013;102(7):749-54. Excluded: Wrong study design for Key Question.23600795
Katz KD, Rashtak S, Lahr BD, . Screening for celiac disease in a North American population: sequential serology and gastrointestinal symptoms. Am J Gastroenterol. 2011;106(7):1333-9. Excluded: Wrong comparator.21364545
Kaukinen K, Collin P, Mykkanen AH, . Celiac disease and autoimmune endocrinologic disorders. Dig Dis Sci. 1999;44(7):1428-33. Excluded: Individual study in included systematic review.10489930
Kaukinen K, Salmi J, Lahtela J, . No effect of gluten-free diet on the metabolic control of type 1 diabetes in patients with diabetes and celiac disease. Retrospective and controlled prospective survey. Diabetes Care. 1999;22(10):1747-8. Excluded: Wrong outcome.
Kaukinen K, Salmi T, Collin P, . Clinical trial: gluten microchallenge with wheat-based starch hydrolysates in coeliac disease patients - a randomized, double-blind, placebo-controlled study to evaluate safety. Aliment Pharmacol Ther. 2008;28(10):1240-8. Excluded: Wrong intervention.18710436
Kemppainen T, Kroger H, Janatuinen E, . Osteoporosis in adult patients with celiac disease. Bone. 1999;24(3):249-55. Excluded: Wrong comparator.10071918
Kingstone K, Gillett HR. Lactulose-mannitol intestinal permeability test: a useful screening test for adult coeliac disease. Ann Clin Biochem. 2001;38(Pt 4):415-6. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).11471891
Kocna P, Vanickova Z, Perusicova J, . Tissue transglutaminase-serology markers for coeliac disease. Clin Chem Lab Med. 2002;40(5):485-92. Excluded: Wrong study design for Key Question.12113293
Kolek A, Fischerova E, Kos V, . Application of ELISA method to determine antigliadin antibodies in children with coeliac disease. Acta Univ Palacki Olomuc Fac Med. 1989;122:183-92. Excluded: Wrong study design for Key Question.2530815
Koletzko S, Burgin-Wolff A, Koletzko B, . Prevalence of coeliac disease in diabetic children and adolescents. A multicentre study. Eur J Pediatr. 1988;148(2):113-7. Excluded: Wrong study design for Key Question.3069470
Koop I, Ilchmann R, Izzi L, . Detection of autoantibodies against tissue transglutaminase in patients with celiac disease and dermatitis herpetiformis. Am J Gastroenterol. 2000;95(8):2009-14. Excluded: Wrong population.10950050
Korponay-Szabo IR, Szabados K, Pusztai J, . Population screening for coeliac disease in primary care by district nurses using a rapid antibody test: diagnostic accuracy and feasibility study. BMJ. 2007;335(7632):1244-7. Excluded: Wrong study design for Key Question.18063612
Kratzer W, Kibele M, Akinli A, . Prevalence of celiac disease in Germany: a prospective follow-up study. World J Gastroenterol. 2013;19(17):2612-20. Excluded: Wrong study design for Key Question.23674868
Kurppa K, Ashorn M, Iltanen S, . Celiac disease without villous atrophy in children: a prospective study. J Pediatr. 2010;157(3):373-80. Excluded: Wrong comparator.20400102
Kurppa K, Lindfors K, Collin P, . Antibodies against deamidated gliadin peptides in early-stage celiac disease. J Clin Gastroenterol. 2011;45(8):673-8. Excluded: Wrong population.21063208
Lagerqvist C, Ivarsson A, Juto P, . Screening for adult coeliac disease - which serological marker(s) to use? J Intern Med. 2001;250(3):241-8. Excluded: Wrong study design for Key Question.11555129
Lahdeaho ML, Kaukinen K, Laurila K, . Glutenase ALV003 attenuates gluten-induced mucosal injury in patients with celiac disease. Gastroenterology. 2014;146(7):1649-58. Excluded: Wrong intervention.24583059
Lahteenoja H, Toivanen A, Raiha I, . Salivary antigliadin and antiendomysium antibodies in coeliac disease. Scand J Immunol. 1999;50(5):528-35. Excluded: Wrong study design for Key Question.10564556
Leach ST, Aurangzeb B, Day AS. Coeliac disease screening in children: assessment of a novel anti-gliadin antibody assay. J Clin Lab Anal. 2008;22(5):327-33. Excluded: Wrong population.18803267
Lebwohl B, Genta RM, Kapel RC, . Procedure volume influences adherence to celiac disease guidelines. Eur J Gastroenterol Hepatol. 2013;25(11):1273-8. Excluded: Individual study in included systematic review.23995767
Lebwohl B, Granath F, Ekbom A, . Mucosal healing and mortality in coeliac disease. Aliment Pharmacol Ther. 2013;37(3):332-9. Excluded: Wrong comparator.23190299
Lebwohl B, Hassid B, Ludwin S, . Increased sedation requirements during endoscopy in patients with celiac disease. Dig Dis Sci. 2012;57(4):994-9. Excluded: Individual study in included systematic review.22052448
Lebwohl B, Kapel RC, Neugut AI, . Adherence to biopsy guidelines increases celiac disease diagnosis. Gastrointest Endosc. 2011;74(1):103-9. Excluded: Individual study in included systematic review.21601201
Leon F, Camarero C, R-Pena R, . Anti-transglutaminase IgA ELISA: clinical potential and drawbacks in celiac disease diagnosis. Scand J Gastroenterol. 2001;36(8):849-53. Excluded: Wrong study design for Key Question.11495081
Leon F, Eiras P, Roy G, . Intestinal intraepithelial lymphocytes and anti-transglutaminase in a screening algorithm for coeliac disease. Gut. 2002;50(5):740-1. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).11950827
Levinson-Castiel R, Hartman C, Morgenstern S, . The role of duodenal bulb biopsy in the diagnosis of celiac disease in children. J Clin Gastroenterol. 2011;45(1):26-9. Excluded: Individual study in included systematic review.20628309
Lewis NR, Scott BB. Systematic review: the use of serology to exclude or diagnose coeliac disease (a comparison of the endomysial and tissue transglutaminase antibody tests). Aliment Pharmacol Ther. 2006;24(1):47-54. Excluded: Systematic review or meta-analysis used as source document only to identify individual studies.16803602
Lewis NR, Scott BB. Meta-analysis: deamidated gliadin peptide antibody and tissue transglutaminase antibody compared as screening tests for coeliac disease. Aliment Pharmacol Ther. 2010;31(1):73-81. Excluded: Individual study in included systematic review.19664074
Liao Z, Gao R, Xu C, . Indications and detection, completion, and retention rates of small-bowel capsule endoscopy: a systematic review. Gastrointest Endosc. 2010;71(2):280-6. Excluded: Individual study in included systematic review.20152309
Liu E, Li M, Bao F, . Need for quantitative assessment of transglutaminase autoantibodies for celiac disease in screening-identified children. J Pediatr. 2005;146(4):494-9. Excluded: Wrong study design for Key Question.15812452
Lock RJ, Stevens S, Pitcher MCL, . Is immunoglobulin A anti-tissue transglutaminase antibody a reliable serological marker of coeliac disease? Eur J Gastroenterol Hepatol. 2004;16(5):467-70. Excluded: Wrong population.15097038
Lorini R, Scotta MS, Cortona L, . Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. J Diabetes Complications. 1996;10(3):154-9. Excluded: Wrong study design for Key Question.8807465
Ludvigsson JF, Pathak J, Murphy S, . Use of computerized algorithm to identify individuals in need of testing for celiac disease. J Am Med Inform Assoc. 2013;20(e2):e306-10. Excluded: Wrong study design for Key Question.23956016
Lurz E, Scheidegger U, Spalinger J, . Clinical presentation of celiac disease and the diagnostic accuracy of serologic markers in children. Eur J Pediatr. 2009;168(7):839-45. Excluded: Wrong study design for Key Question.18923841
Lytton SD, Antiga E, Pfeiffer S, . Neo-epitope tissue transglutaminase autoantibodies as a biomarker of the gluten sensitive skin disease--dermatitis herpetiformis. Clin Chim Acta. 2013;415:346-9. Excluded: Wrong intervention.23142793
Maki M, Hallstrom O, Vesikari T, . Evaluation of a serum IgA-class reticulin antibody test for the detection of childhood celiac disease. J Pediatr. 1984;105(6):901-5. Excluded: Wrong study design for Key Question.6502340
Mankai A, Sakly W, Landolsi H, . Tissue transglutaminase antibodies in celiac disease, comparison of an enzyme linked immunosorbent assay and a dot blot assay. Pathol Biol (Paris). 2005;53(4):204-9. Excluded: Wrong population.15850953
Mascart-Lemone F, Lambrechts A. Serology of coeliac disease: early diagnosis and therapeutic impact. Acta Gastroenterol Belg. 1995;58(5-6):388-96. Excluded: Wrong study design for Key Question.8775995
Mascart-Lemone F, Van den Broeck J, Cadranel S, . Serological aspects of coeliac disease. Acta Gastroenterol Belg. 1992;55(2):200-8. Excluded: Wrong study design for Key Question.1632137
Matuchansky C. Apparently asymptomatic patients with serologic markers of celiac disease and gluten-free diet. Gastroenterology. 2015;148(1):260. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).
Mazure R, Vazquez H, Gonzalez D, . Bone mineral affection in asymptomatic adult patients with celiac disease. Am J Gastroenterol. 1994;89(12):2130-4. Excluded: Wrong study design for Key Question.7977227
Mazzarella G, Salvati VM, Iaquinto G, . Reintroduction of gluten following flour transamidation in adult celiac patients: a randomized, controlled clinical study. Clin Dev Immunol. 2012;2012:329150. Excluded: Wrong population.22899947
Mazzone L, Reale L, Spina M, . Compliant gluten-free children with celiac disease: an evaluation of psychological distress. BMC Pediatr. 2011;11:46. Excluded: Wrong comparator.21619651
McGowan KE, Castiglione DA, Butzner JD. The changing face of childhood celiac disease in north america: impact of serological testing. Pediatrics. 2009;124(6):1572-8. Excluded: Wrong study design for Key Question.19948628
Medical Advisory S. Clinical utility of serologic testing for celiac disease in asymptomatic patients: an evidence-based analysis (Structured abstract). Health Technology Assessment Database 2014(2). Excluded: Not a study (letter, editorial, non-systematic review article, no original data).
Medical Advisory S. Clinical utility of serologic testing for celiac disease in Ontario (symptomatic patients) (Structured abstract). Health Technology Assessment Database 2014(2). Excluded: Not a study (letter, editorial, non-systematic review article, no original data).
Miller A, Paspaliaris W, Elliott PR, . Anti-transglutaminase antibodies and coeliac disease. Aust N Z J Med. 1999;29(2):239-42. Excluded: Wrong study design for Key Question.10342024
Mooney PD, Hadjivassiliou M, Sanders DS. Coeliac disease. [Review]. BMJ. 2014;348. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).
Moreno M. Celiac disease in children and adolescents. JAMA Pediatr. 2014;168(3):300. Excluded: Wrong study design for Key Question.24590142
Mozo L, Gomez J, Escanlar E, . Diagnostic value of anti-deamidated gliadin peptide IgG antibodies for celiac disease in children and IgA-deficient patients. J Pediatr Gastroenterol Ntr. 2012;55(1):50-5. Excluded: Individual study in included systematic review.
Mubarak A, Nikkels P, Houwen R, . Reproducibility of the histological diagnosis of celiac disease. Scand J Gastroenterol. 2011;46(9):1065-73. Excluded: Individual study in included systematic review.21668407
Mustalahti K, Collin P, Sievanen H, . Osteopenia in patients with clinically silent coeliac disease warrants screening. Lancet. 1999;354(9180):744-5. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).10475193
Mustalahti K, Lohiniemi S, Collin P, . Gluten-free diet and quality of life in patients with screen-detected celiac disease. Eff Clin Pract. 2002;5(3):105-13. Excluded: Wrong study design for Key Question.12088289
Nachman F, del Campo MP, Gonzalez A, . Long-term deterioration of quality of life in adult patients with celiac disease is associated with treatment noncompliance. Dig Liver Dis. 2010;42(10):685-91. Excluded: Wrong study design for Key Question.20399159
Nachman F, Maurino E, Vazquez H, . Quality of life in celiac disease patients: prospective analysis on the importance of clinical severity at diagnosis and the impact of treatment. Dig Liver Dis. 2009;41(1):15-25. Excluded: Wrong comparator.18602354
National Institute for Health and Clinical Excellence Centre for Clinical Practice. Coeliac disease: recognition and assessment of coeliac disease. 2009. Excluded: individual study in included systematic review.
Nemec G, Ventura A, Stefano M, . Looking for celiac disease: diagnostic accuracy of two rapid commercial assays. Am J Gastroenterol. 2006;101(7):1597-600. Excluded: Wrong study design for Key Question.16863566
Nenna R, Mennini M, Petrarca L, . Immediate effect on fertility of a gluten-free diet in women with untreated coeliac disease. Gut. 2011;60(7):1023-4. Excluded: Wrong study design for Key Question.
Nenna R, Pontone S, Pontone P, . Duodenal bulb in celiac adults: the “whether biopsying” dilemma. J Clin Gastroenterol. 2012;46(4):302-7. Excluded: Individual study in included systematic review.21934529
Neves MMPS, Gonzalez-Garcia MB, Nouws HPA, . An electrochemical deamidated gliadin antibody immunosensor for celiac disease clinical diagnosis. Analyst. 2013;138(7):1956-8. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).23400113
Nordyke K, Norstrom F, Lindholm L, . Health-related quality of life in adolescents with screening-detected celiac disease, before and one year after diagnosis and initiation of gluten-free diet, a prospective nested case-referent study. BMC Public Health. 2013;13:142. Excluded: Wrong study design for Key Question.23414483
Nordyke K, Rosen A, Emmelin M, . Internalizing the threat of risk--a qualitative study about adolescents' experience living with screening-detected celiac disease 5 years after diagnosis. Health Qual Life Outcomes. 2014;12(91). Excluded: Wrong study design for Key Question.
Norstrom F, Lindholm L, Sandstrom O, . Delay to celiac disease diagnosis and its implications for health-related quality of life. BMC Gastroenterology. 2011;11:118. Excluded: Wrong comparator.22060243
Olen O, Gudjonsdottir AH, Browaldh L, . Antibodies against deamidated gliadin peptides and tissue transglutaminase for diagnosis of pediatric celiac disease. J Pediatr Gastroenterol Ntr. 2012;55(6):695-700. Excluded: Individual study in included systematic review.
Olivares M, Castillejo G, Varea V, . Double-blind, randomised, placebo-controlled intervention trial to evaluate the effects of Bifidobacterium longum CECT 7347 in children with newly diagnosed coeliac disease. Br J Nutr. 2014;112(1):30-40. Excluded: Wrong intervention.24774670
Paavola A, Kurppa K, Ukkola A, . Gastrointestinal symptoms and quality of life in screen-detected celiac disease. Dig Liver Dis. 2012;44(10):814-8. Excluded: Wrong study design for Key Question.22673312
Pais WP, Duerksen DR, Pettigrew NM, . How many duodenal biopsy specimens are required to make a diagnosis of celiac disease? Gastrointest Endosc. 2008;67(7):1082-7. Excluded: Individual study in included systematic review.18308317
Parizade M, Bujanover Y, Weiss B, . Performance of serology assays for diagnosing celiac disease in a clinical setting. Clin Vaccine Immunol. 2009;16(11):1576-82. Excluded: Wrong population.19776198
Parnanen A, Kaukinen K, Helakorpi S, . Symptom-detected and screen-detected celiac disease and adult height: a large cohort study. Eur J Gastroenterol Hepatol. 2012;24(9):1066-70. Excluded: Wrong study design for Key Question.22664941
Pascolo P, Faleschini E, Tonini G, . Type 1 diabetes mellitus and celiac disease: usefulness of gluten-free diet. Acta Diabetol. 2013;50(5):821-2. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).21833778
Persliden J, Pettersson HB, Falth-Magnusson K. Small intestinal biopsy in children with coeliac disease: measurement of radiation dose and analysis of risk. Acta Paediatr. 1993;82(3):296-9. Excluded: Individual study in included systematic review.8495087
Perticarari S, Presani G, Trevisan M, . Serum IgA and IgG antibodies to alpha-gliadin: comparison between two ELISA methods. Ric Clin Lab. 1987;17(4):323-9. Excluded: Wrong outcome.3438667
Pettersson HB, Falth-Magnusson K, Persliden J, . Radiation risk and cost-benefit analysis of a paediatric radiology procedure: results from a national study. Br J Radiol. 2005;78(925):34-8. Excluded: Individual study in included systematic review.15673527
Pinto Sanchez MI, Smecuol E, Vazquez H, . Very high rate of misdiagnosis of celiac disease in clinical practice. Acta Gastroenterol Latinoam. 2009;39(4):250-3. Excluded: Individual study in included systematic review.20178253
Pittschieler K, Ladinser B. Coeliac disease: screened by a new strategy. Acta Paediatr Suppl. 1996;412:42-5. Excluded: Wrong study design for Key Question.8783755
Poland DCW, Ceelie H, Dinkelaar RB, . Determination of anti-endomysium IgA antibodies in the diagnosis of celiac disease: comparison of a novel ELISA-based assay with conventional immunofluorescence. World J Gastroenterol. 2006;12(17):2779-80. Excluded: Wrong comparator.16718769
Prasad KK, Thapa BR, Nain CK, . The frequency of histologic lesion variability of the duodenal mucosa in children with celiac disease. World J Pediatr. 2010;6(1):60-4. Excluded: Individual study in included systematic review.20143213
Ransford RAJ, Hayes M, Palmer M, . A controlled, prospective screening study of celiac disease presenting as iron deficiency anemia. J Clin Gastroenterol. 2002;35(3):228-33. Excluded: Wrong study design for Key Question.12192198
Ravelli A, Bolognini S, Gambarotti M, . Variability of histologic lesions in relation to biopsy site in gluten-sensitive enteropathy. Am J Gastroenterol. 2005;100(1):177-85. Excluded: Individual study in included systematic review.15654798
Ress K, Harro J, Uibo O, . Use of a fully automated immunoassay for celiac disease screening in a pediatric population. Clin Chem Lab Med. 2011;49(6):983-7. Excluded: Wrong study design for Key Question.21428860
Ring Jacobsson L, Friedrichsen M, Goransson A, . Does a Coeliac School increase psychological well-being in women suffering from coeliac disease, living on a gluten-free diet? J Clin Nurs. 2012;21(5-6):766-75. Excluded: Wrong population.22039932
Rokkas T, Niv Y. The role of video capsule endoscopy in the diagnosis of celiac disease: a meta-analysis. Eur J Gastroenterol Hepatol. 2012;24(3):303-8. Excluded: Individual study in included systematic review.22266837
Roldan MB, Barrio R, Roy G, . Diagnostic value of serological markers for celiac disease in diabetic children and adolescents. J Pediatr Endocrinol. 1998;11(6):751-6. Excluded: Wrong study design for Key Question.
Roos S, Karner A, Hallert C. Psychological well-being of adult coeliac patients treated for 10 years. Dig Liver Dis. 2006;38(3):177-80. Excluded: Wrong comparator.16461026
Rose C, Howard R. Living with coeliac disease: a grounded theory study. J Hum Nutr Diet. 2014;27(1):30-40. Excluded: Wrong study design for Key Question.23516989
Rostom A, Dube C, Cranney A, . The diagnostic accuracy of serologic tests for celiac disease: a systematic review. Gastroenterology. 2005;128(4 Suppl 1):S38-46. Excluded: Systematic review or meta-analysis used as source document only to identify individual studies.15825125
Saadah OI, Zacharin M, O'Callaghan A, . Effect of gluten-free diet and adherence on growth and diabetic control in diabetics with coeliac disease. Arch Dis Child. 2004;89(9):871-6. Excluded: Wrong comparator.15321869
Saari A, Harju S, Makitie O, . Systematic growth monitoring for the early detection of celiac disease in children. JAMA Pediatr. 2015;169(3):e1525. Excluded: Wrong study design for Key Question.25730696
Sacchetti L, Calcagno G, Ferrajolo A, . Discrimination between celiac and other gastrointestinal disorders in childhood by rapid human lymphocyte antigen typing. Clin Chem. 1998;44(8 Pt 1):1755-7. Excluded: Wrong population.9702970
Sacchetti L, Ferrajolo A, Salerno G, . Diagnostic value of various serum antibodies detected by diverse methods in childhood celiac disease. Clin Chem. 1996;42(11):1838-42. Excluded: Wrong population.8906085
Sainsbury K, Mullan B, Sharpe L. A randomized controlled trial of an online intervention to improve gluten-free diet adherence in celiac disease. Am J Gastroenterol. 2013;108(5):811-7. Excluded: Wrong intervention.23458849
Sakly W, Bienvenu F, Peretti N, . IgA anti-transglutaminase antibodies as a tool for screening atypical forms of coeliac disease in a French at-risk paediatric population. Eur J Gastroenterol Hepatol. 2005;17(2):235-9. Excluded: Wrong study design for Key Question.15674103
Sakly W, Mankai A, Ghdess A, . Performance of anti-deamidated gliadin peptides antibodies in celiac disease diagnosis. Clin Res Hepatol Gastroenterol. 2012;36(6):598-603. Excluded: Individual study in included systematic review.22436429
Salmaso C, Ocmant A, Pesce G, . Comparison of ELISA for tissue transglutaminase autoantibodies with antiendomysium antibodies in pediatric and adult patients with celiac disease. Allergy. 2001;56(6):544-7. Excluded: Wrong population.11421901
Sardy M, Odenthal U, Karpati S, . Recombinant human tissue transglutaminase ELISA for the diagnosis of gluten-sensitive enteropathy. Clin Chem. 1999;45(12):2142-9. Excluded: Wrong study design for Key Question.10585346
Sategna-Guidetti C, Grosso SB, Grosso S, . The effects of 1-year gluten withdrawal on bone mass, bone metabolism and nutritional status in newly-diagnosed adult coeliac disease patients. Aliment Pharmacol Ther. 2000;14(1):35-43. Excluded: Wrong study design for Key Question.
Sethi GR, Singhal KK, Puri AS, . Benefit of gluten-free diet in idiopathic pulmonary hemosiderosis in association with celiac disease. Pediatr Pulmonol. 2011;46(3):302-5. Excluded: Wrong population.20967850
Shah S, Akbari M, Vanga R, . Patient perception of treatment burden is high in celiac disease compared with other common conditions. Ame J Gastroenterol. 2014;109(9):1304-11. Excluded: Wrong study design for Key Question.
Shamir R, Yehezkely-Schildkraut V, Hartman C, . Population screening for celiac disease: follow up of patients identified by positive serology. J Gastroenterol Hepatol. 2007;22(4):532-5. Excluded: Individual study in included systematic review.17376047
Sharma A, Mews C, Jevon G, . Duodenal bulb biopsy in children for the diagnosis of coeliac disease: experience from Perth, Australia. J Paediatr Child Health. 2013;49(3):210-4. Excluded: Individual study in included systematic review.23432775
Siegel M, Garber ME, Spencer AG, . Safety, tolerability, and activity of ALV003: results from two phase 1 single, escalating-dose clinical trials. Dig Dis Sci. 2012;57(2):440-50. Excluded: Wrong population.21948339
Smecuol E, Hwang HJ, Sugai E, . Exploratory, randomized, double-blind, placebo-controlled study on the effects of Bifidobacterium infantis natren life start strain super strain in active celiac disease. J Clin Gastroenterol. 2013;47(2):139-47. Excluded: Wrong intervention.23314670
Srinivas M, Basumani P, Podmore G, . Utility of testing patients, on presentation, for serologic features of celiac disease. Clin Gastroenterol Hepatol. 2014;12(6):946-52. Excluded: Individual study in included systematic review.24262940
Stern M, Teuscher M, Wechmann T. Serological screening for coeliac disease: methodological standards and quality control. Acta Paediatr Suppl. 1996;412:49-51. Excluded: Wrong study design for Key Question.8783758
Sugai E, Hwang HJ, Vazquez H, . New serology assays can detect gluten sensitivity among enteropathy patients seronegative for anti-tissue transglutaminase. Clin Chem. 2010;56(4):661-5. Excluded: Individual study in included systematic review.20022983
Swallow K, Wild G, Sargur R, . Quality not quantity for transglutaminase antibody 2: the performance of an endomysial and tissue transglutaminase test in screening coeliac disease remains stable over time. Clin Exp Immunol. 2013;171(1):100-6. Excluded: Individual study in included systematic review.23199329
Swift GL, Smith PM, King L. Screening test for coeliac disease.[Erratum appears in Lancet 1997 Aug 9;350(9075):450]. Lancet. 1997;349(9060):1254. Excluded: Not a study (letter, editorial, non-systematic review article, no original data).9130972
Tack GJ, van de Water JMW, Bruins MJ, . Consumption of gluten with gluten-degrading enzyme by celiac patients: a pilot-study. World J Gastroenterol. 2013;19(35):5837-47. Excluded: Wrong population.24124328
Toftedal P, Nielsen C, Madsen JT, . Positive predictive value of serological diagnostic measures in celiac disease. Clin Chem Lab Med. 2010;48(5):685-91. Excluded: Wrong study design for Key Question.20201743
Tontini GE, Rondonotti E, Saladino V, . Impact of gluten withdrawal on health-related quality of life in celiac subjects: an observational case-control study. Digestion. 2010;82(4):221-8. Excluded: Wrong study design for Key Question.20588037
Tosco A, Auricchio R, Aitoro R, . Intestinal titres of anti-tissue transglutaminase 2 antibodies correlate positively with mucosal damage degree and inversely with gluten-free diet duration in coeliac disease. Clin Exp Immunol. 2014;177(3):611-7. Excluded: Wrong population.24773630
Trevisiol C, Ventura A, Baldas V, . A reliable screening procedure for coeliac disease in clinical practice. Scand J Gastroenterol. 2002;37(6):679-84. Excluded: Wrong population.12126246
Tursi A, Giorgetti GM, Iani C, . Peripheral neurological disturbances, autonomic dysfunction, and antineuronal antibodies in adult celiac disease before and after a gluten-free diet. Dig Dis Sci. 2006;51(10):1869-74. Excluded: Wrong study design for Key Question.16967315
Uenishi RH, Gandolfi L, Almeida LM, . Screening for celiac disease in 1st degree relatives: a 10-year follow-up study. BMC Gastroenterology. 2014;14:36. Excluded: Wrong study design for Key Question.24552206
Ukkola A, Maki M, Kurppa K, . Diet improves perception of health and well-being in symptomatic, but not asymptomatic, patients with celiac disease. Clin Gastroenterol Hepatol. 2011;9(2):118-23. Excluded: Wrong study design for Key Question.21029791
Usai P, Manca R, Cuomo R, . Effect of gluten-free diet and co-morbidity of irritable bowel syndrome-type symptoms on health-related quality of life in adult coeliac patients. Dig Liver Dis. 2007;39(9):824-8. Excluded: Wrong comparator.17644056
Usai P, Minerba L, Marini B, . Case control study on health-related quality of life in adult coeliac disease. Dig Liver Dis. 2002;34(8):547-52. Excluded: Wrong study design for Key Question.12502210
Valdimarsson T, Toss G, Ross I, . Bone mineral density in coeliac disease. Scand J Gastroenterol. 1994;29(5):457-61. Excluded: Wrong study design for Key Question.8036462
van der Windt D, Jellema P, Mulder CJ, . Diagnostic testing for celiac disease among patients with abdominal symptoms: a systematic review. JAMA. 2010;303(17):1738-46. Excluded: Individual study in included systematic review.20442390
Van Meensel B, Hiele M, Hoffman I, . Diagnostic accuracy of ten second-generation (human) tissue transglutaminase antibody assays in celiac disease. Clin Chem. 2004;50(11):2125-35. Excluded: Individual study in included systematic review.15388634
Vasquez H, Mazure R, Gonzalez D, . Risk of fractures in celiac disease patients: a cross-sectional, case-control study. Am J Gastroenterol. 2000;95(1):183-9. Excluded: Wrong study design for Key Question.10638580
Vere CC, Rogoveanu I, Streba CT, . The role of capsule endoscopy in the detection of small bowel disease. Chirurgia (Bucur). 2012;107(3):352-60. Excluded: Individual study in included systematic review.22844834
Vermeersch P, Coenen D, Geboes K, . Use of likelihood ratios improves clinical interpretation of IgA anti-tTG antibody testing for celiac disease. Clin Chim Acta. 2010;411(1-2):13-7. Excluded: Individual study in included systematic review.19799890
Vermeersch P, Geboes K, Marien G, . Diagnostic performance of IgG anti-deamidated gliadin peptide antibody assays is comparable to IgA anti-tTG in celiac disease. Clin Chim Acta. 2010;411(13-14):931-5. Excluded: Individual study in included systematic review.20171961
Vermeersch P, Geboes K, Marien G, . Serological diagnosis of celiac disease: comparative analysis of different strategies. Clin Chim Acta. 2012;413(21-22):1761-7. Excluded: Individual study in included systematic review.22771970
Viljamaa M, Collin P, Huhtala H, . Is coeliac disease screening in risk groups justified? A fourteen-year follow-up with special focus on compliance and quality of life. Aliment Pharmacol Ther. 2005;22(4):317-24. PMID: 16097998. Excluded: Wrong study design for Key Question.16097998
Vilppula A, Kaukinen K, Luostarinen L, . Clinical benefit of gluten-free diet in screen-detected older celiac disease patients. BMC Gastroenterology. 2011;11:136. Excluded: Wrong study design for Key Question.22176557
Vogelsang H, Genser D, Wyatt J, . Screening for celiac disease: a prospective study on the value of noninvasive tests. Am J Gastroenterol. 1995;90(3):394-8. Excluded: Wrong population.7872276
Volta U, Caio G, Stanghellini V, . The changing clinical profile of celiac disease: a 15-year experience (1998-2012) in an Italian referral center. BMC Gastroenterol. 2014;14(1):194. Excluded: Wrong study design for Key Question.25404189
Vriezinga SL, Auricchio R, Bravi E, . Randomized feeding intervention in infants at high risk for celiac disease. New Engl J Med. 2014;371(14):1304-15. Excluded: Wrong population.25271603
Walters JR, Banks LM, Butcher GP, . Detection of low bone mineral density by dual energy x ray absorptiometry in unsuspected suboptimally treated coeliac disease. Gut. 1995;37(2):220-4. Excluded: Wrong study design for Key Question.7557572
Wang C, Rasmussen H, Perrow W, . Larazotide acetate, a first in-class, novel tight junction regulator, meets primary endpoint and significantly reduces signs and symptoms of celiac disease in patients on a gluten-free diet: Results of a multicenter, randomized, placebo controlled trial. Gastroenterology.146(5 SUPPL. 1):S-159. Excluded: Wrong comparator.
Weir DC, Glickman JN, Roiff T, . Variability of histopathological changes in childhood celiac disease. Am J Gastroenterol. 2010;105(1):207-12. Excluded: Individual study in included systematic review.19809405
Zanini B, Magni A, Caselani F, . High tissue-transglutaminase antibody level predicts small intestinal villous atrophy in adult patients at high risk of celiac disease. Dig Liver Dis. 2012;44(4):280-5. Excluded: Individual study in included systematic review.22119616

## Appendix A5 U.S. Preventive Services Quality Criteria for Rating Individual Studies

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used.
- Standard appraisal of included studies.
- Validity of conclusions.
- Recency and relevance are especially important for systematic reviews.

#### Definition of ratings from above criteria

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variables.

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to followup.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, adequately described.
- Study uses a credible reference standard, performed regardless of test results.
- Reference standard interpreted independently of screening test.
- Handles indeterminate results in a reasonable manner.
- Spectrum of patients included in study.
- Sample size.
- Administration of reliable screening test.

#### Definition of ratings based on above criteria

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has fatal flaw such as: Uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum of patients.

Source: U.S Preventive Services Task Force. Procedure Manual. Accessed at http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.

## Appendix A6 Reviewers of the Draft Report

- Carlo Catassi, MD
  Professor of Pediatrics, Università Politecnica dele Marche, Italy
- Ivor Hill, MB, ChB, MD
  Professor of Clinical Pediatrics, Section Chief Pediatric Gastroenterology, Ohio State University College of Medicine and Nationwide Children's Hospital
- Ciaran P. Kelly, MD
  Professor of Medicine, Harvard Medical School; Director, Celiac Center, Beth Israel Deaconess Medical Center
- Kalle Kurppa, MD, MPH
  Tampere Centre for Child Health Research, University of Tampere and Tampere University Hospital, Finland
- John Marshall, MD, MSc, FRCPC, AGAF
  Professor of Medicine, Division of Gastroenterology, McMaster University, Canada