# References

1 U.S. Preventive Services Task Force. (2008). Primary care interventions to promote breastfeeding: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med.
2 Labbok M, Krasovec K. (1990). Toward consistency in breastfeeding definitions. Studies in family planning.
3 World Health Organization. (2003). Global Strategy on Infant and Young Child Feeding.
4 American Academy of Pediatrics. (2012). Breastfeeding and the use of human milk. Pediatrics.
5 American Academy of Family Physicians. (2012). Breastfeeding (policy statement).
6 American Congress of Obstetricians and Gynecologists. (2007). Breastfeeding: maternal and infant aspects.
7 World Health Organization, UNICEF. (1989). Protecting, promoting and supporting breast-feeding: the special role of maternity services.
8 World Health Organization. (1981). International Code of Marketing Breast-milk Substitutes.
9 Baby-Friendly USA. (2010). Guidelines and evaluation criteria for facilities seeking baby-friendly designation.
10 U.S. Department of Health and Human Services. (2014). Healthy People 2020: Maternal, Infant, and Child Health. HealthyPeoplegov.
11 U.S. Department of Health and Human Services. (2011). The Surgeon General's Call to Action to Support Breastfeeding.
12 Ip S, Chung M, Raman G, et al. (2007). Breastfeeding and maternal and infant health outcomes in developed countries. Evid Rep Technol Assess (Full Rep).
13 Ip S, Chung M, Raman G, et al. (2009). A summary of the Agency for Healthcare Research and Quality's evidence report on breastfeeding in developed countries. Breastfeed Med.
14 Alm B, Wennergren G, Mollborg P, et al. (2015). Breastfeeding and dummy use have a protective effect on sudden infant death syndrome. Acta Paediatr.
15 Amitay EL, Keinan-Boker L. (2015). Breastfeeding and Childhood Leukemia Incidence: A Meta-analysis and Systematic Review. JAMA Pediatr.
16 Aune D, Norat T, Romundstad P, et al. (2014). Breastfeeding and the maternal risk of type 2 diabetes: a systematic review and dose-response meta-analysis of cohort studies. Nutr Metab Cardiovasc Dis.
17 Bowatte G, Tham R, Allen KJ, et al. (2015). Breastfeeding and childhood acute otitis media: a systematic review and meta-analysis. Acta Paediatr Suppl.
18 Cardwell CR, Stene LC, Ludvigsson J, et al. (2012). Breast-feeding and childhood-onset type 1 diabetes: a pooled analysis of individual participant data from 43 observational studies. Diabetes Care.
19 Chowdhury R, Sinha B, Sankar MJ, et al. (2015). Breastfeeding and Maternal Health Outcomes: A Systematic Review and Meta-Analysis. Acta Paediatr Suppl.
20 Dias CC, Figueiredo B. (2015). Breastfeeding and depression: A systematic review of the literature. J Affect Disord.
21 Horta BL, de Mola CL, Victora CG. (2015). Long-term consequences of breastfeeding on cholesterol, obesity, systolic blood pressure and type 2 diabetes: a systematic review and meta-analysis. Acta Paediatr Suppl.
22 Horta BL, de Mola CL, Victora CG. (2015). Breastfeeding and intelligence: systematic review and meta-analysis. Acta Paediatr Suppl.
23 Lamberti LM, Fischer Walker CL, Noiman A, et al. (2011). Breastfeeding and the risk for diarrhea morbidity and mortality. BMC Public Health.
24 Lodge CJ, Tan DJ, Lau M, et al. (2015). Breastfeeding and asthma and allergies: a systematic review and meta-analysis. Acta Paediatr Suppl.
25 Sankar MJ, Sinha B, Chowdhury R, et al. (2015). Optimal breastfeeding practices and infant and child mortality: a systematic review and meta-analysis. Acta Paediatr Suppl.
26 Gdalevich M, Mimouni D, David M, et al. (2001). Breast-feeding and the onset of atopic dermatitis in childhood: a systematic review and meta-analysis of prospective studies. Journal of the American Academy of Dermatology.
27 Chien PF, Howie PW. (2001). Breast milk and the risk of opportunistic infection in infancy in industrialized and non-industrialized settings. Adv Nutr Res.
28 Kramer MS, Kakuma R. (2012). Optimal duration of exclusive breastfeeding. Cochrane Database Syst Rev.
29 Bachrach VR, Schwarz E, Bachrach LR. (2003). Breastfeeding and the risk of hospitalization for respiratory disease in infancy: a meta-analysis. Arch Pediatr Adolesc Med.
30 Norris JM, Scott FW. (1996). A meta-analysis of infant diet and insulin-dependent diabetes mellitus: do biases play a role?. Epidemiology.
31 Owen CG, Martin RM, Whincup PH, et al. (2006). Does breastfeeding influence risk of type 2 diabetes in later life? A quantitative analysis of published evidence. Am J Clin Nutr.
32 Arenz S, Ruckerl R, Koletzko B, et al. (2004). Breast-feeding and childhood obesity--a systematic review. Int J Obes Relat Metab Disord.
33 Lamberti LM, Zakarija-Grkovic I, Fischer Walker CL, et al. (2013). Breastfeeding for reducing the risk of pneumonia morbidity and mortality in children under two: a systematic literature review and meta-analysis. BMC Public Health.
34 Henriksson C, Bostrom AM, Wiklund IE. (2013). What effect does breastfeeding have on coeliac disease? A systematic review update. Evid Based Med.
35 Carreira H, Bastos A, Peleteiro B, et al. (2014). Breast-feeding and Helicobacter pylori infection: systematic review and meta-analysis. Public Health Nutr.
36 Tham R, Bowatte G, Dharmage SC, et al. (2015). Breastfeeding and the risk of dental caries: a systematic review and meta-analysis. Acta Paediatr Suppl.
37 Peres KG, Cascaes AM, Nascimento GG, et al. (2015). Effect of breastfeeding on malocclusions: a systematic review and meta-analysis. Acta Paediatr Suppl.
38 Bernier MO, Plu-Bureau G, Bossard N, et al. (2000). Breastfeeding and risk of breast cancer: a metaanalysis of published studies. Hum Reprod Update.
39 Collaborative Group on Hormonal Factors in Breast C. (2002). Breast cancer and breastfeeding: collaborative reanalysis of individual data from 47 epidemiological studies in 30 countries, including 50302 women with breast cancer and 96973 women without the disease. Lancet.
40 Colen CG, Ramey DM. (2014). Is breast truly best? Estimating the effects of breastfeeding on long-term child health and wellbeing in the United States using sibling comparisons. Social science & medicine (1982).
41 Der G, Batty GD, Deary IJ. (2006). Effect of breast feeding on intelligence in children: prospective study, sibling pairs analysis, and meta-analysis. Bmj.
42 Evenhouse E, Reilly S. (2005). Improved estimates of the benefits of breastfeeding using sibling comparisons to reduce selection bias. Health Serv Res.
43 Gillman MW, Rifas-Shiman SL, Berkey CS, et al. (2006). Breast-feeding and overweight in adolescence: within-family analysis. Epidemiology.
44 O'Tierney PF, Barker DJ, Osmond C, et al. (2009). Duration of breast-feeding and adiposity in adult life. J Nutr.
45 Disantis KI, Collins BN, Fisher JO, et al. (2011). Do infants fed directly from the breast have improved appetite regulation and slower growth during early childhood compared with infants fed from a bottle?. The international journal of behavioral nutrition and physical activity.
46 Centers for Disease Control and Prevention. Breastfeeding among U.S. Children Born 2002–2012, CDC National Immunization Surveys.
47 Skafida V. (2009). The relative importance of social class and maternal education for breast-feeding initiation. Public Health Nutr.
48 Ahluwalia IB, Morrow B, D'Angelo D, et al. (2012). Maternity care practices and breastfeeding experiences of women in different racial and ethnic groups: Pregnancy Risk Assessment and Monitoring System (PRAMS). Matern Child Health J.
49 National Center for Chronic Disease Prevention and Health Promotion. (2014). Breastfeeding report card.
50 World Health Organization. Global Health Observatory Data Repository, Exclusive breastfeeding under 6 months: Data by country.
51 Ibanez G, Martin N, Denantes M, et al. (2012). Prevalence of breastfeeding in industrialized countries. Rev Epidemiol Sante Publique.
52 Chapman DJ, Perez-Escamilla R. (2012). Breastfeeding among minority women: moving from risk factors to interventions. Adv Nutr.
53 Kehler HL, Chaput KH, Tough SC. (2009). Risk factors for cessation of breastfeeding prior to six months postpartum among a community sample of women in Calgary, Alberta. Can J Public Health.
54 Gagliardi L, Petrozzi A, Rusconi F. (2012). Symptoms of maternal depression immediately after delivery predict unsuccessful breast feeding. Arch Dis Child.
55 Kitsantas P, Pawloski LR. (2010). Maternal obesity, health status during pregnancy, and breastfeeding initiation and duration. J Matern Fetal Neonatal Med.
56 Guelinckx I, Devlieger R, Bogaerts A, et al. (2012). The effect of pre-pregnancy BMI on intention, initiation and duration of breast-feeding. Public Health Nutr.
57 Sutherland T, Pierce CB, Blomquist JL, et al. (2012). Breastfeeding practices among first-time mothers and across multiple pregnancies. Matern Child Health J.
58 Chertok IR, Luo J, Culp S, et al. (2011). Intent to breastfeed: a population-based perspective. Breastfeed Med.
59 Lind J, Perrine C, Li R, et al. (2014). Racial disparities in access to maternity care practices that support breastfeeding - United States, 2011. MMWR Morb Mortal Wkly Rep.
60 Long S, Bugg K. (2015). Can't we all just get along?. J Hum Lact.
61 Payne S. (2014). A call to action: lactation equity through professional diversification. J Hum Lact.
62 Perez-Escamilla R, Sellen D. (2015). Equity in breastfeeding: where do we go from here?. J Hum Lact.
63 Zamora G, Lutter CK, Pena-Rosas JP. (2015). Using an Equity Lens in the Implementation of Interventions to Protect, Promote, and Support Optimal Breastfeeding Practices. J Hum Lact.
64 Chung M, Ip S, Yu W, et al. (2008). Interventions in primary care to promote breastfeeding: a systematic review.
65 Chung M, Raman G, Trikalinos T, et al. (2008). Interventions in primary care to promote breastfeeding: an evidence review for the U.S. Preventive Services Task Force. Ann Intern Med.
66 Renfrew MJ, McCormick FM, Wade A, et al. (2012). Support for healthy breastfeeding mothers with healthy term babies. Cochrane Database Syst Rev.
67 Center for Disease Control and Prevention. (2013). Strategies to Prevent Obesity and Other Chronic Diseases: The CDC Guide to Strategies to Support Breastfeeding Mothers and Babies.
68 Eisenberg SR, Bair-Merritt MH, Colson ER, et al. (2015). Maternal Report of Advice Received for Infant Care. Pediatrics.
69 Taveras EM, Li R, Grummer-Strawn L, et al. (2004). Mothers' and clinicians' perspectives on breastfeeding counseling during routine preventive visits. Pediatrics.
70 Taveras EM, Li R, Grummer-Strawn L, et al. (2004). Opinions and practices of clinicians associated with continuation of exclusive breastfeeding. Pediatrics.
71 Krogstrand KS, Parr K. (2005). Physicians ask for more problem-solving information to promote and support breastfeeding. J Am Diet Assoc.
72 American Academy of Pediatrics. (2014). Federal Support of Breastfeeding.
73 Health Resources and Services Administration. Women's Preventive Services Guidelines: Affordable Care Act Expands Prevention Coverage for Women's Health and Well-Being.
74 United States Department of Labor. (2013). Fact Sheet #73: Break Time for Nursing Mothers under the FLSA. Wage and Hour Division.
75 United Nations Development Programme. (2014). Human Development Report 2014. Sustaining Human Progress: Reducing Vulnerabilties and Building Resilience.
76 U.S. Preventive Services Task Force. Procedure Manual.
77 World Health Organization. (2008). Indicators for Assessing Infant and Young Child Feeding Practices. Part 1, Definitions.
78 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Controlled clinical trials.
79 Lavender T, Baker L, Smyth R, et al. (2005). Breastfeeding expectations versus reality: a cluster randomised controlled trial. BJOG.
80 Elliott-Rudder M, Pilotto L, McIntyre E, et al. (2014). Motivational interviewing improves exclusive breastfeeding in an Australian randomised controlled trial. Acta Paediatrica.
81 Kools EJ, Thijs C, Kester AD, et al. (2005). A breast-feeding promotion and support program a randomized trial in The Netherlands. Prev Med.
82 Fu I, Fong D, Heys M, et al. (2014). Professional breastfeeding support for first-time mothers: a multicentre cluster randomised controlled trial. BJOG.
83 Jolly K, Ingram L, Freemantle N, et al. (2012). Effect of a peer support service on breast-feeding continuation in the UK: A randomised controlled trial. Midwifery.
84 Gijsbers B, Mesters I, Knottnerus JA, et al. (2006). The Success of an Educational Program to Promote Exclusive Breastfeeding for 6 Months in Families with a History of Asthma: A Randomized Controlled Trial. Pediatr Asthma Allergy Immunol.
85 Reading R, Harvey I, McLean M. (2000). Cluster randomised trials in maternal and child health: implications for power and sample size. Arch Dis Child.
86 Higgins JP, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
87 (2011). Higgins J, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0.
88 Hartung J, Knapp G. (2001). A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med.
89 Peters JL, Sutton AJ, Jones DR, et al. (2006). Comparison of two methods to detect publication bias in meta-analysis. JAMA.
90 Abbass-Dick J, Stern SB, Nelson LE, et al. (2015). Coparenting breastfeeding support and exclusive breastfeeding: a randomized controlled trial. Pediatrics.
91 Anderson AK, Damio G, Young S, et al. (2005). A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community. Arch Pediatr Adolesc Med.
92 Bonuck K, Stuebe A, Barnett J, et al. (2014). Effect of primary care intervention on breastfeeding duration and intensity. Am J Public Health.
93 Bonuck KA, Freeman K, Trombley M. (2006). Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Arch Pediatr Adolesc Med.
94 Bonuck KA, Trombley M, Freeman K, et al. (2005). Randomized, controlled trial of a prenatal and postnatal lactation consultant intervention on duration and intensity of breastfeeding up to 12 months. Pediatrics.
95 Bunik M, Shobe P, O'Connor ME, et al. (2010). Are 2 weeks of daily breastfeeding support insufficient to overcome the influences of formula?. Acad Pediatr.
96 Carfoot S, Williamson P, Dickson R. (2005). A randomised controlled trial in the north of England examining the effects of skin-to-skin care on breast feeding. Midwifery.
97 Carlsen EM, Kyhnaeb A, Renault KM, et al. (2013). Telephone-based support prolongs breastfeeding duration in obese women: a randomized trial. Am J Clin Nutr.
98 Chapman DJ, Morel K, Bermudez-Millan A, et al. (2013). Breastfeeding education and support trial for overweight and obese women: a randomized trial. Pediatrics.
99 Dennis CL, Hodnett E, Gallop R, et al. (2002). The effect of peer support on breast-feeding duration among primiparous women: a randomized controlled trial. CMAJ.
100 Di Meglio G, McDermott MP, Klein JD. (2010). A randomized controlled trial of telephone peer support's influence on breastfeeding duration in adolescent mothers. Breastfeed Med.
101 Di Napoli A, Di Lallo D, Fortes C, et al. (2004). Home breastfeeding support by health professionals: findings of a randomized controlled trial in a population of Italian women. Acta Paediatr.
102 Edwards RC, Thullen MJ, Korfmacher J, et al. (2013). Breastfeeding and complementary food: randomized trial of community doula home visiting. Pediatrics.
103 Forster D, McLachlan H, Lumley J, et al. (2004). Two mid-pregnancy interventions to increase the initiation and duration of breastfeeding: a randomized controlled trial. Birth.
104 Gagnon AJ, Dougherty G, Jimenez V, et al. (2002). Randomized trial of postpartum care after hospital discharge. Pediatrics.
105 Gouchon S, Gregori D, Picotto A, et al. (2010). Skin-to-skin contact after cesarean delivery: an experimental study. Nurs Res.
106 Graffy J, Taylor J, Williams A, et al. (2004). Randomised controlled trial of support from volunteer counsellors for mothers considering breast feeding. BMJ.
107 Hawkins SS, Stern AD, Baum CF, et al. (2014a). Evaluating the impact of the Baby-Friendly Hospital Initiative on breast-feeding rates: a multi-state analysis. Public Health Nutr.
108 Hawkins SS, Stern AD, Baum CF, et al. (2014b). Compliance with the Baby-Friendly Hospital Initiative and impact on breastfeeding rates. Arch Dis Child Fetal Neonatal Ed.
109 Henderson A, Stamp G, Pincombe J. (2001). Postpartum positioning and attachment education for increasing breastfeeding: a randomized trial. Birth.
110 Hoddinott P, Britten J, Prescott GJ, et al. (2009). Effectiveness of policy to provide breastfeeding groups (BIG) for pregnant and breastfeeding mothers in primary care: cluster randomised controlled trial. BMJ.
111 Hopkinson J, Konefal Gallagher M. (2009). Assignment to a hospital-based breastfeeding clinic and exclusive breastfeeding among immigrant Hispanic mothers: a randomized, controlled trial. J Hum Lact.
112 Howard CR, Howard FM, Lanphear B, et al. (2003). Randomized clinical trial of pacifier use and bottle-feeding or cupfeeding and their effect on breastfeeding. Pediatrics.
113 Howell EA, Balbierz A, Wang J, et al. (2012). Reducing postpartum depressive symptoms among black and Latina mothers: a randomized controlled trial. Obstet Gynecol.
114 Howell EA, Bodnar-Deren S, Balbierz A, et al. (2014). An intervention to extend breastfeeding among black and Latina mothers after delivery. Am J Obstet Gynecol.
115 Jenik AG, Vain NE, Gorestein AN, et al. (2009). Does the recommendation to use a pacifier influence the prevalence of breastfeeding?. J Pediatr.
116 Kellams AL, Gurka KK, Hornsby PP, et al. (2015). The Impact of a Prenatal Education Video on Rates of Breastfeeding Initiation and Exclusivity during the Newborn Hospital Stay in a Low-income Population. J Hum Lact.
117 Kramer MS, Barr RG, Dagenais S, et al. (2001). Pacifier use, early weaning, and cry/fuss behavior: a randomized controlled trial. JAMA.
118 Kronborg H, Maimburg RD, Vaeth M. (2012). Antenatal training to improve breast feeding: a randomised trial. Midwifery.
119 Labarere J, Bellin V, Fourny M, et al. (2003). Assessment of a structured in-hospital educational intervention addressing breastfeeding: a prospective randomised open trial. BJOG.
120 Labarere J, Gelbert-Baudino N, Ayral AS, et al. (2005). Efficacy of breastfeeding support provided by trained clinicians during an early, routine, preventive visit: a prospective, randomized, open trial of 226 mother-infant pairs. Pediatrics.
121 MacArthur C, Jolly K, Ingram L, et al. (2009). Antenatal peer support workers and initiation of breast feeding: Cluster randomised controlled trial. BMJ.
122 Mattar CN, Chong YS, Chan YS, et al. (2007). Simple antenatal preparation to improve breastfeeding practice: a randomized controlled trial. Obstet Gynecol.
123 McDonald SJ, Henderson JJ, Faulkner S, et al. (2010). Effect of an extended midwifery postnatal support programme on the duration of breast feeding: a randomised controlled trial. Midwifery.
124 McQueen KA, Dennis CL, Stremler R, et al. (2011). A pilot randomized controlled trial of a breastfeeding self-efficacy intervention with primiparous mothers. J Obstet Gynecol Neonatal Nurs.
125 Mesters I, Gijsbers B, Bartholomew K, et al. (2013). Social cognitive changes resulting from an effective breastfeeding education program. Breastfeed Med.
126 Muirhead PE, Butcher G, Rankin J, et al. (2006). The effect of a programme of organised and supervised peer support on the initiation and duration of breastfeeding: a randomised trial. Br J Gen Pract.
127 Noel-Weiss J, Bassett V, Cragg B. (2006). Developing a prenatal breastfeeding workshop to support maternal breastfeeding self-efficacy. J Obstet Gynecol Neonatal Nurs.
128 Noel-Weiss J, Rupp A, Cragg B, et al. (2006). Randomized controlled trial to determine effects of prenatal breastfeeding workshop on maternal breastfeeding self-efficacy and breastfeeding duration. J Obstet Gynecol Neonatal Nurs.
129 Nolan A, Lawrence C. (2009). A pilot study of a nursing intervention protocol to minimize maternal-infant separation after Cesarean birth. J Obstet Gynecol Neonatal Nurs.
130 Paul IM, Beiler JS, Schaefer EW, et al. (2012). A randomized trial of single home nursing visits vs office-based care after nursery/maternity discharge: the Nurses for Infants Through Teaching and Assessment After the Nursery (NITTANY) Study. Arch Pediatr Adolesc Med.
131 Pollard DL. (2011). Impact of a feeding log on breastfeeding duration and exclusivity. Matern Child Health J.
132 Quinlivan JA, Box H, Evans SF. (2003). Postnatal home visits in teenage mothers: a randomised controlled trial. Lancet.
133 Reeder JA, Joyce T, Sibley K, et al. (2014). Telephone peer counseling of breastfeeding among WIC participants: a randomized controlled trial. Pediatrics.
134 Stockdale J, Sinclair M, Kernohan WG, et al. (2008). Feasibility study to test DESIGNER BREASTFEEDING: a randomised controlled trial. Evidence Based Midwifery.
135 Su LL, Chong YS, Chan YH, et al. (2007). Antenatal education and postnatal support strategies for improving rates of exclusive breast feeding: randomised controlled trial. BMJ.
136 Wallace LM, Dunn OM, Alder EM, et al. (2006). A randomised-controlled trial in England of a postnatal midwifery intervention on breast-feeding duration. Midwifery.
137 Wambach KA, Aaronson L, Breedlove G, et al. (2011). A randomized controlled trial of breastfeeding support and education for adolescent mothers. West J Nurs Res.
138 Wen LM, Baur LA, Rissel C, et al. (2007). Early intervention of multiple home visits to prevent childhood obesity in a disadvantaged population: a home-based randomised controlled trial (Healthy Beginnings Trial). BMC Public Health.
139 Wen LM, Baur LA, Simpson JM, et al. (2011). Effectiveness of an early intervention on infant feeding practices and “tummy time”: a randomized controlled trial. Arch Pediatr Adolesc Med.
140 Wong KL, Tak Fong DY, Yin Lee IL, et al. (2014). Antenatal education to increase exclusive breastfeeding: a randomized controlled trial. Obstet Gynecol.
141 Kramer MS, Chalmers B, Hodnett ED, et al. (2001). Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus. JAMA.
142 Kramer MS, Matush L, Vanilovich I, et al. (2007). Effects of prolonged and exclusive breastfeeding on child height, weight, adiposity, and blood pressure at age 6.5 y: evidence from a large randomized trial. Am J Clin Nutr.
143 Kramer MS, Matush L, Vanilovich I, et al. (2007). Effect of prolonged and exclusive breast feeding on risk of allergy and asthma: cluster randomised trial. BMJ.
144 Kramer MS, Vanilovich I, Matush L, et al. (2007). The Effect of Prolonged and Exclusive Breast-Feeding on Dental Caries in Early School-Age Children. Caries Research.
145 Kramer MS, Fombonne E, Igumnov S, et al. (2008). Effects of prolonged and exclusive breastfeeding on child behavior and maternal adjustment: evidence from a large, randomized trial. Pediatrics.
146 Kramer MS, Aboud F, Mironova E, et al. (2008). Breastfeeding and child cognitive development: new evidence from a large randomized trial. Archives of general psychiatry.
147 Philipp BL, Malone KL, Cimo S, et al. (2003). Sustained breastfeeding rates at a US baby-friendly hospital. Pediatrics.
148 Philipp BL, Merewood A, Miller LW, et al. (2001). Baby-friendly hospital initiative improves breastfeeding initiation rates in a US hospital setting. Pediatrics.
149 Brodribb W, Kruske S, Miller YD. (2013). Baby-friendly hospital accreditation, in-hospital care practices, and breastfeeding. Pediatrics.
150 Corriveau SK, Drake EE, Kellams AL, et al. (2013). Evaluation of an office protocol to increase exclusivity of breastfeeding. Pediatrics.
151 Feldman-Winter L, Grossman X, Palaniappan A, et al. (2012). Removal of industry-sponsored formula sample packs from the hospital: does it make a difference?. J Hum Lact.
152 Center for Disease Control and Prevention. mPINC results.
153 Perrine CG, Galuska DA, Dohack JL, et al. (2015). Vital Signs: Improvements in Maternity Care Policies and Practices That Support Breastfeeding - United States, 2007-2013. MMWR Morb Mortal Wkly Rep.
154 McInnes RJ, Chambers JA. (2008). Supporting breastfeeding mothers: qualitative synthesis. J Adv Nurs.
155 Burns E, Schmied V, Sheehan A, et al. (2010). A meta-ethnographic synthesis of women's experience of breastfeeding. Matern Child Nutr.
156 Hoddinott P, Craig LC, Britten J, et al. (2012). A serial qualitative interview study of infant feeding experiences: idealism meets realism. BMJ Open.
157 Haroon S, Das JK, Salam RA, et al. (2013). Breastfeeding promotion interventions and breastfeeding practices: a systematic review. BMC Public Health.
158 Jolly K, Ingram L, Khan KS, et al. (2012). Systematic review of peer support for breastfeeding continuation: metaregression analysis of the effect of setting, intensity, and timing. BMJ.
159 Lumbiganon P, Martis R, Laopaiboon M, et al. (2012). Antenatal breastfeeding education for increasing breastfeeding duration. Cochrane Database Syst Rev.
160 Sinha B, Chowdhury R, Sankar MJ, et al. (2015). Interventions to Improve Breastfeeding Outcomes: Systematic Review and Meta Analysis. Acta Paediatr Supl.
161 Skouteris H, Nagle C, Fowler M, et al. (2014). Interventions designed to promote exclusive breastfeeding in high-income countries: a systematic review. Breastfeed Med.
162 Wong KL, Tarrant M, Lok KY. (2015). Group versus Individual Professional Antenatal Breastfeeding Education for Extending Breastfeeding Duration and Exclusivity: A Systematic Review. J Hum Lact.
163 Beake S, Pellowe C, Dykes F, et al. (2012). A systematic review of structured compared with non-structured breastfeeding programmes to support the initiation and duration of exclusive and any breastfeeding in acute and primary health care settings. Matern Child Nutr.
164 Lavender T, Richens Y, Milan SJ, et al. (2013). Telephone support for women during pregnancy and the first six weeks postpartum. Cochrane Database of Systematic Reviews.
165 Jaafar SH, Jahanfar S, Angolkar M, et al. (2012). Effect of restricted pacifier use in breastfeeding term infants for increasing duration of breastfeeding. Cochrane Database Syst Rev.
166 Jaafar SH, Lee KS, Ho JJ. (2012). Separate care for new mother and infant versus rooming-in for increasing the duration of breastfeeding. Cochrane Database Syst Rev.
167 Aarts C, Kylberg E, Hornell A, et al. (2000). How exclusive is exclusive breastfeeding? A comparison of data since birth with current status data. Int J Epidemiol.
168 Chapman DJ, Perez-Escamilla R. (2009). US national breastfeeding monitoring and surveillance: current status and recommendations. Journal of Human Lactation.
169 Hector DJ. (2011). Complexities and subtleties in the measurement and reporting of breastfeeding practices. Int Breastfeed J.
170 Labbok MH, Starling A. (2012). Definitions of breastfeeding: call for the development and use of consistent definitions in research and peer-reviewed literature. Breastfeed Med.
171 Noel-Weiss J, Boersma S, Kujawa-Myles S. (2012). Questioning current definitions for breastfeeding research. Int Breastfeed J.
172 Noel-Weiss J, Taljaard M, Kujawa-Myles S. (2014). Breastfeeding and lactation research: exploring a tool to measure infant feeding patterns. Int Breastfeed J.
173 Thulier D. (2010). A call for clarity in infant breast and bottle-feeding definitions for research. J Obstet Gynecol Neonatal Nurs.
174 Chapman D, Damio G, Young S, et al. (2004). Association of degree and timing of exposure to breastfeeding peer counseling services with breastfeeding duration. Adv Exp Med Biol.
175 Ekstrom A, Nissen E. (2006). A mother's feelings for her infant are strengthened by excellent breastfeeding counseling and continuity of care. Pediatrics.
176 Ekstrom A, Widstrom AM, Nissen E. (2006). Does continuity of care by well-trained breastfeeding counselors improve a mother's perception of support?. Birth.
177 Finch C, Daniel EL. (2002). Breastfeeding education program with incentives increases exclusive breastfeeding among urban WIC participants. J Am Diet Assoc.
178 Kronborg H, Vaeth M, Olsen J, et al. (2007). Effect of early postnatal breastfeeding support: a cluster-randomized community based trial. Acta Paediatr.
179 McKeever P, Stevens B, Miller KL, et al. (2002). Home versus hospital breastfeeding support for newborns: a randomized controlled trial. Birth.
180 McLeod D, Pullon S, Benn C, et al. (2004). Can support and education for smoking cessation and reduction be provided effectively by midwives within primary maternity care?. Midwifery.
181 Moore ER, Anderson GC. (2007). Randomized controlled trial of very early mother-infant skin-to-skin contact and breastfeeding status. J Midwifery Womens Health.
182 Pugh LC, Milligan RA, Brown LP. (2001). The breastfeeding support team for low-income, predominantly-minority women: a pilot intervention study. Health Care Women Int.
183 Pugh LC, Milligan RA, Frick KD, et al. (2002). Breastfeeding duration, costs, and benefits of a support program for low-income breastfeeding women. Birth.
184 Ryser FG. (2004). Breastfeeding attitudes, intention, and initiation in low-income women: the effect of the best start program. J Hum Lact.
185 Schlickau J, Wilson M. (2005). Development and testing of a prenatal breastfeeding education intervention for Hispanic women. J Perinat Educ.
186 Wilhelm SL, Stepans MB, Hertzog M, et al. (2006). Motivational interviewing to promote sustained breastfeeding. J Obstet Gynecol Neonatal Nurs.
187 Winterburn S, Moyer J, Thompson J. (2003). Maternal grandmothers and support for breastfeeding. J Community Nurs.
188 Wolfberg AJ, Michels KB, Shields W, et al. (2004). Dads as breastfeeding advocates: results from a randomized controlled trial of an educational intervention. Am J Obstet Gynecol.
189 Giglia R, Binns C. (2014). The effectiveness of the internet in improving breastfeeding outcomes: a systematic review. J Hum Lact.
190 Owen CG, Whincup PH, Gilg JA, et al. (2003). Effect of breast feeding in infancy on blood pressure in later life: systematic review and meta-analysis. BMJ.
191 Owen CG, Whincup PH, Odoki K, et al. (2002). Infant feeding and blood cholesterol: a study in adolescents and a systematic review. Pediatrics.
192 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. American journal of preventive medicine.
193 Wells GA, S B, O'Connell D, Peterson J, Welch V, Losos M, Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis.