# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Smyth Lai, MLS, for conducting literature searches; Elizabeth O'Connor, for statistical assistance; Keshia Bigler, MPH, for report preparation; and Elizabeth Hess, ESL(D), for editorial support; Karen Bonuck, PhD, Roslyn Giglia, PhD, MPH, Lucy Hope, RM, PhD, Ann Kellams, MD, IBCLC, FAAP, FABM, Miriam Labbok, MD, Anne Merewood, PhD, MPH, IBCLC, and Ann Witt, MD, who provided expert review; and the Centers for Disease Control and Prevention and the Indian Health Service, who provided federal partner review. The authors also thank AHRQ Medical Officer Elisabeth Kato, MD, MRP, as well as current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions.