# 4 Discussion

## Summary of Evidence

We included 52 studies that examined the effectiveness of breastfeeding interventions on rates of breastfeeding. A summary of evidence for all KQs is presented in Table 13. All of the studies varied widely in terms of their methodological quality, included populations and sample sizes, and the types and timing of the interventions tested.

Table 13 Overall Summary of Evidence by Key Question

Key Question | No. of studies (k), study design, n | Study Quality | Limitations^*^ | Consistency | US Primary Care Applicability | Summary of Findings^†^
KQ1: Infant and maternal health outcomes | k=6 RCT n=2,219 | Good: 1 Fair: 5 | No studies reported maternal health outcomes. Most outcomes based on maternal recall. Followup ranged from 4 to 52 weeks. | Inconsistent | High Applicable to a predominantly Hispanic and black low-income population. | Mixed results for the effects on infant gastrointestinal outcomes (k=2): one trial (n=182) found greater risk of ≥1 diarrheal episodes over 3 months in usual care vs. intervention groups (RR, 2.15 [95% CI, 1.16 to 3.97]) while the other trial (n=338) found no difference between intervention and control groups at 1 year (22.7% vs. 25.7%). One trial (n=338) found no difference in risk of otitis media (43.6% vs. 54.9%) or the number of health care visits for respiratory tract illnesses (76% vs. 83.4%) at 1 year. 3 out of 4 trials that reported rates of infant health care utilization found higher use among the usual care control groups (2.8% to 36.0%) than intervention groups (1.2% to 25.0%). No studies reported the effects on maternal health outcomes.
KQ2: Breastfeeding outcomes | Individual-level interventions k=43 RCT n=21,973 | Good: 14 Fair: 29 | Statistical heterogeneity moderate or substantial in most analyses and considerable clinical variation. Lack of detail regarding measurement of breastfeeding, including recall period and definition of exclusivity. Sparse reporting of breastfeeding at 12 months. Indication of small study effects for exclusive breastfeeding for <3 months and at 6 months. | Consistent | Moderate US trials (k=15) applicable to a predominantly Hispanic and black low-income population. Non-US trials have low applicability given differences in usual care and underlying social and cultural differences. | Statistically significant associations between individual-level breastfeeding interventions and any breastfeeding for <3 months (RR, 1.07 [95% CI, 1.03 to 1.11]; k=26; n=11,588) and at 3 to <6 months (RR, 1.11 [95% CI, 1.04 to 1.18]; k=23; n=8,942) and for exclusive breastfeeding for <3 months (RR, 1.21 [95% CI, 1.11 to 1.33]; k=22; n=8,246), 3 to <6 months (RR, 1.20 [95% CI, 1.05 to 1.38]; k=18; n=7,027), and at 6 months (RR, 1.16 [95% CI, 1.02 to 1.32]; k=17; n=7,690). No significant association between individual-level interventions and breastfeeding initiation (RR, 1.00 [95% CI, 0.99 to 1.02]; k=14; n=9,428). Absolute differences in the rates of any breastfeeding ranged from 14.1 percentage points in favor of the control group to 18.4 percentage points in favor of the intervention group. Interventions delivered over more than one time point (e.g., prenatal and postpartum) may be more effective than those only delivered at one time point (e.g., postpartum only).
KQ2: Breastfeeding outcomes | System-level interventions k=9 (7 RCTs, 2 before-after with matched control group) n= 44,784 | Good: 6 Fair: 3 | Only 1 cluster RCT evaluating system-level policy change; 2 studies were controlled before-after designs. Limited number of studies evaluating specific maternity care practices related to breastfeeding. | Consistent | High applicability for studies of policy changes (k=3). Moderate applicability for studies of maintaining mother-baby contact following delivery (k=3). Low applicability for studies of restricted pacifier use (k=3). | No consistent evidence of an association between system-level changes (BFHI accreditation and policies for breastfeeding support groups, minimizing mother and baby separation postdelivery, and restricting or delaying pacifier use) and the rate of any or exclusive breastfeeding at up to 16 weeks postpartum. One large observational study (n=25,327) found a statistically significant higher rate of breastfeeding initiation and exclusive breastfeeding at 4 weeks in women with a lower education (initiation increased by 3.8 percentage points) but not in women overall or among those with higher education (initiation increased by 0.02 percentage points) after implementation of the BFHI.
KQ3: Adverse events | k=2 RCTs n=844 | Good: 0 Fair: 2 | Only 2 trials reported adverse events related to the interventions. | NA | High | One trial (n=586) reported no difference in maternal state anxiety at 2 weeks postpartum between those receiving a home visit from a nurse vs. those receiving usual care (MD, 0.3 [95% CI, -0.5 to 1.1]). Another trial (n=258) reported that 2 mothers expressed feelings of anxiety, decreased confidence, or concerns about confidentiality during a peer support intervention.

* Includes reporting bias.

† Includes precision.

Abbreviations: BFHI=Baby-Friendly Hospital Initiative; CI=confidence interval; k=number of studies; KQ=key question; N=number; NA=not applicable; RCT=randomized, controlled trial; RR=risk ratio; US=United States.

### Infant and Maternal Health Outcomes

Only six studies reported results related to infant health outcomes, with mixed effects of the interventions on gastrointestinal outcomes, cases of otitis media, respiratory tract illnesses, and infant health care use (KQ1) (Table 13). None of the included studies reported the intervention effect on short- or long-term maternal health outcomes, such as postpartum weight loss or the incidence of breast cancer. Despite this limited evidence on the direct effect on health outcomes from our included studies, observational evidence (as described in Chapter 1) supports the link between ever breastfeeding and the duration of any or exclusive breastfeeding and positive infant and maternal health outcomes.

We excluded one study that was included in the original review that reported infant health outcomes. To date, the Promotion of Breastfeeding Intervention Trial (PROBIT) in Belarus is the largest randomized trial (n=17,046) to have evaluated the effects of a system-level breastfeeding promotion intervention on the duration and exclusivity of breastfeeding as well as infant and child outcomes.^141^ This study was not included in our review because of its limited applicability to U.S. health care given the country of origin. At the conception of this trial (1996–1997), Belarus was chosen rather than a North American or Western European country because maternity practices there reflected those in North America and Western Europe 30 to 40 years ago and therefore would provide greater potential contrast between intervention and control conditions. Participating sites were randomly assigned to an intervention (16 sites) modeled after the BFHI or a usual care control intervention (15 sites). Results from the primary trial data showed that infants born to mothers at the intervention sites were significantly more likely than control infants to be breastfed at 12 months (aOR for weaning at 12 months for intervention vs. control, 0.47 [95% CI, 0.32 to 0.69]) and to be exclusively breastfed at both 3 months (43.3% vs. 6.4%; p<0.001) and 6 months (7.9% vs. 0.6%; p=0.01).^141^ The intervention also resulted in a significant reduction in the risk of gastrointestinal tract infection (aOR, 0.06 [95% CI, 0.40 to 0.91]) and the incidence of rashes, including atopic eczema (aOR, 0.54 [95% CI, 0.31 to 0.95]), but resulted in no significant differences in the risk of respiratory tract infections or otitis media in the first year of life.^141^ At the 6.5-year followup, there was no significant intervention effect among children on body mass index, waist or hip circumference, body fat, risk of overweight or obesity, or systolic or diastolic blood pressure;^142^ asthma, allergic symptoms, or allergy diagnoses;^143^ dental caries;^144^ or children's behavior.^145^ Children in the intervention arm, however, had statistically significantly higher scores on cognitive ability tests as well as higher teacher-reported reading and writing abilities than children in the control group at 6.5 years.^146^

### Breastfeeding Outcomes

#### Individual-Level Breastfeeding Support

Our updated review found that individual-level breastfeeding support and education interventions increase the relative likelihood of women breastfeeding up to 6 months and exclusively breastfeeding up to and at 6 months relative to those receiving usual care (Table 13). Our review failed to find a statistically significant relationship between individual-level breastfeeding interventions and initiation of breastfeeding or any breastfeeding at 6 months. Three trials reported breastfeeding rates at 12 months and none found a significant benefit from the intervention.

The size of the treatment effects varied in their magnitude and precision in different trials, and average treatment effects may not be applicable in different settings. The pooled estimates from more than 20 trials suggested an increase in any breastfeeding up to 6 months from 4 to 18 percent and an increase in exclusive breastfeeding up to 6 months from 5 to 38 percent in 18 trials. The average treatment effect for exclusive breastfeeding at 6 months suggested that individual-level interventions can increase the likelihood of exclusive breastfeeding by an average of 16 percent compared with usual care (RR, 1.16 [95% CI, 1.02 to 1.32]).

The NNTs for any and exclusive breastfeeding at each time point calculated from a range of “baseline” breastfeeding rates generally indicated that fewer than 30 women would need to be treated to get one more woman breastfeeding in the short term (<6 months) and more than 30 women for 6 months (Appendix C Table 3). Among groups of women with higher rates of breastfeeding, the NNT to get one more women breastfeeding is lower. For example, among populations of women where approximately 55 percent of them breastfed from 3 to less than 6 months, the NNT is only 17. On the other hand, in situations where there are fewer women exclusively breastfeeding at “baseline” (e.g., 5% exclusively breastfeeding at 3 to <6 months or 6 months), more than 100 women would need to receive an intervention to see one more woman exclusively breastfeeding at this time point. In general, the NNTs varied more widely for exclusive breastfeeding than for any breastfeeding.

The relatively modest effect seen within and across trials may be a result of the breastfeeding support provided as part of standard or usual care within many of these countries and specific clinical settings, and the magnitude of effect should be interpreted as an incremental benefit above usual care. Most studies indicated that there was a good level of breastfeeding support within the birthing facility at or around the time of delivery from hospital staff, including the provision of lactation care providers, but failed to fully describe the minimal support for breastfeeding during the prenatal and postpartum time periods.

Despite high clinical, methodological, and, in some cases, statistical heterogeneity, there was little evidence that the effects of individual-level interventions varied across different populations or intervention characteristics. The high variability in the interventions' approaches, however, may have masked important relationships. All three types of individual-level interventions (support provided by professionals, support provided by peers, and formal education) were associated with greater rates of any and exclusive breastfeeding compared with usual care. Interventions delivered over more than one time point (provided during the prenatal, and/or peripartum, and/or postpartum periods) may have a larger effect than interventions provided within one time period (e.g., prenatal or postpartum only), but this differential effect was only seen for any breastfeeding for less than 3 months and 3 to less than 6 months and was not evident for the effects on exclusive breastfeeding. Therefore, this moderation effect should be viewed as exploratory and worth pursuing further, but only if the outcome is clinically meaningful. To help explore whether intervention effects vary by these characteristics, future research should include clear descriptions of the time period or periods that an intervention takes place, the total duration of the intervention, and the number of sessions during each time period.

#### System-Level Policies and Practices

We included three studies that evaluated the influence of a system-level policy on the prevalence or duration of breastfeeding and six trials that focused on other system-level maternity care practices (mother and baby contact and delayed pacifier use). Two recent good-quality studies found no difference in breastfeeding initiation or breastfeeding at 1 month before or after BFHI accreditation among women who gave birth in accredited facilities versus women who gave birth in matched nonaccredited facilities. There was some evidence of an effect on initiation and exclusive breastfeeding at 1 month among women with low education (≤12 years of education) but not among all women or women with more than 12 years of education.^107^ A number of studies, including one of our included studies, have shown that the actual implementation of the individual steps (or mothers' perception of experiencing these steps) within the BFHI, rather than BFHI accreditation itself, influences rates of breastfeeding. The study by Hawkins and colleagues in Maine found that while mothers giving birth within BFHI-accredited facilities were more likely to report experiencing seven of the 10 BFHI practices (34.6%) than women delivering at a non-BFHI–accredited facility (27.1%), compliance with the practices was relatively low within the accredited facilities in general. Only one practice (step 3: hospital staff gave information about breastfeeding) significantly increased after BFHI accreditation. Other practice rates were not optimal, with only 57 to 87 percent of women giving birth in BFHI facilities reporting these variables. Overall, each additional breastfeeding practice was associated with an average increase in breastfeeding initiation of 14.6 percentage points.^108^ Our review found no evidence of a consistent effect of maintaining mother and baby contact following delivery (k=3) or delayed pacifier use (k=3) on the prevalence of breastfeeding initiation or the duration of any or exclusive breastfeeding.

There are a number of other longitudinal evaluations of the BFHI and other system-level policies and practices in the United States and other applicable countries, but they are limited to before-after comparisons within single hospitals or retrospective study designs and were not included in our review.^147-151^ For example, Philipp and colleagues were among the first to evaluate rates of breastfeeding before and after implementation of Baby-Friendly policies at the Boston Medical Center. They found that rates of breastfeeding initiation and exclusive breastfeeding increased significantly following implementation of Baby-Friendly policies. Breastfeeding initiation increased from 58 percent before implementation to 77.5 percent during implementation and 86.5 percent following implementation (p<0.001), and the increase was seen across all racial/ethnic and socioeconomic groups. For instance, breastfeeding initiation rose from 34 percent prior to implementation to 74 percent after implementation among U.S.-born black mothers.^148^ These higher rates of initiation and exclusive breastfeeding were maintained in the 2 years following implementation of the policies.^147^ Likewise, in a retrospective before-after design, Corriveau and colleagues found statistically significantly higher rates of initiating exclusive breastfeeding as well as exclusive breastfeeding at 1 week and 2, 4, and 6 months after implementation of a pediatric primary care protocol that included staff training, written policies, onsite lactation consultant support, and community outreach related to breastfeeding support.^150^ A retrospective cohort study in Australia found that after adjustment for significant maternal, infant, clinical, and hospital variables, women who gave birth in BFHI-accredited hospitals had significantly lower odds of breastfeeding at 1 month compared with women who gave birth in nonaccredited facilities. However, women who reported experiencing four in-hospital practices in alignment with the BFHI (early skin-to-skin contact, attempted breastfeeding within the first hour, rooming-in, and no in-hospital supplementation) had higher odds of breastfeeding at 1 and 4 months than women who reported experiencing fewer than four of these practices.^149^ Feldman-Winter and colleagues compared the mean duration of breastfeeding before and after industry-sponsored formula sample packs were no longer distributed to new mothers in one U.S. hospital.^151^ Despite finding a longer duration of any breastfeeding among mothers who did not received industry-sponsored formula sample packs than those who did (49% vs. 45% of intervention vs. control groups were still breastfeeding at 2.5 months), there was no significant difference in the duration of exclusive breastfeeding up to 10 weeks postpartum. This study highlighted difficulties in implementing systemwide changes, as 36 percent of mothers in the intervention group reported receiving infant formula in their discharge bags despite the instructions for staff to remove formula completely.

### Adverse Events

We systematically reviewed the literature for a variety of potential adverse events associated with breastfeeding interventions, including mothers reporting feeling criticized by the interventionist, guilt related to not breastfeeding, increased anxiety about breastfeeding, and increased postpartum depression. Only two of our included studies reported adverse events that mothers experienced related to the intervention and included reports of increased anxiety, feelings of inadequacy, and concerns regarding their family's confidentiality. Although the goals of these interventions focused on initiating and continuing breastfeeding and empowering women to do so, it is important that interventionists respect family's individual decisions.

We did not examine common problems related to the act of breastfeeding itself that may be important determinants of continued breastfeeding, such as cases of mastitis or sore nipples. Interventions to support breastfeeding could either increase these problems (through the increased prevalence of breastfeeding among the population) or decrease these issues (through active management and suggestions for prevention). Given that these breastfeeding-related problems are often the impetus for stopping breastfeeding,^11^ it is clear that part of the goal of any intervention should be to help breastfeeding mothers actively prevent and manage these common issues.

## Applicability to U.S. Health Care

Only 19 of the 52 included studies took place in the United States. The remaining studies took place in Canada, Australia, Europe, Asia, or South America, where we presume the standard of care for breastfeeding support within the health care system to be quite different from that of the United States. Only five of the studies explicitly said that the intervention was offered in a BFHI-accredited facility; the other studies reported varying levels of breastfeeding support within usual care. However, most U.S. birth facilities have some policies and practices that support breastfeeding.^152^ In 2013, more than 85 percent of hospitals responding to the Centers for Disease Control and Prevention's National Survey of Maternity Practices in Infant Nutrition and Care reported adopting three to eight of the 10 Baby-Friendly recommended policies or practices. Approximately 90 percent of U.S. hospitals reported offering prenatal breastfeeding education, teaching breastfeeding techniques, and/or teaching feeding cues. Postdischarge support, having a model policy, and limiting nonbreast milk feedings were less commonly implemented practices (approximately 25% of hospitals reported these practices). Nationally, the percentage of hospitals reporting implementing more than half of the 10 Steps increased from 28.7 percent in 2007 to 53.9 percent in 2013, and this increase was reported across all states.^153^ Thus, it is likely that non-BFHI facilities are adopting practices similar to those of BFHI facilities and that usual care in some of the included studies could be equivalent to, if not more intense than, the interventions that were offered.

The interventions offered were diverse (such as group prenatal education sessions, one individual session in the hospital, telephone support, home visits, and multiple one-on-one sessions spanning the prenatal and postpartum periods), as were the provisions of usual care.

The rates of any and exclusive breastfeeding with increasing infant age among both intervention and control group participants declined steadily, as was expected. Although the U.S. rate of breastfeeding initiation among these samples was high (70% to 99%), far fewer mothers in these studies continued breastfeeding compared with the national average. In 2012, 51.4 percent of U.S. women reported breastfeeding their 6-month-olds. The rate was identical for Hispanic women only (51.4%) but higher and lower for non-Hispanic white (55.8%) and non-Hispanic black (35.3%) mothers, respectively.^46^ Within the included U.S. trials, only one study among a predominantly white, well-educated sample reported that almost half of the women in both the intervention group (49.7%) and usual care group (48.8%) were breastfeeding at 6 months.^130^ The other U.S. trials, which were almost all among predominantly Hispanic and/or non-Hispanic black women intending to breastfeed, reported lower rates of breastfeeding at 6 months. The proportion of women in the control groups reporting breastfeeding at 6 months ranged from 25 to 38 percent. There was no pattern in the relative effects of interventions over time. Some trials affected the breastfeeding rate across time points as infants aged, and some interventions effectively increased the number of women starting to breastfed and in the early weeks but not as infants aged; others demonstrated increasing effectiveness as infants aged (e.g., the intervention was effective at 6 but not 3 months). Likewise, there was no clear pattern indicating that the trials affected any but not exclusive breastfeeding and vice versa. These differences may reflect the variety of aims and the intensity of the respective interventions.

The variations in breastfeeding rates emphasize that the act of breastfeeding is not simply a physiologic transfer of nutrients from mother to baby but rather a behavior deeply rooted within a woman's specific social and cultural circumstances. Decisions regarding feeding are likely influenced by a host of factors, including family and social circumstances, the health of the baby as well as other children in the family, the mother's own health needs, previous breastfeeding experiences, plans for returning to work or school, and the culture in which she lives. Qualitative data have highlighted the need for clinical encounters around breastfeeding to be “family centered” rather than idealistic or goal-oriented and aim to enhance the mother's self-efficacy and minimize feelings of guilt and failure.^154-156^

## Comparison With Other Systematic Reviews

The results of our current review are consistent with previously published reviews suggesting a small increased relative likelihood of breastfeeding, including exclusive breastfeeding, up to 6 months related to structured individual-level support, including professional or peer support.^52,66^, ^157-162^ For example, the 2013 review by Haroon and colleagues found that both individual and group counseling interventions resulted in higher rates of exclusive breastfeeding relative to control groups at 1 to 6 months (RR, 1.90 [95% CI, 1.54 to 2.34]) within developed and developing countries.^157^ Two reviews^160,163^ suggested improved rates of breastfeeding initiation and continuation following system-level breastfeeding interventions such as the BFHI but noted major limitations to the bodies of evidence and their approach to systematic review. All of these reviews cite similar challenges to this literature base, including the high risk of bias of the included studies, the lack of standardization of breastfeeding outcomes and timing of the assessment, and a dearth of well-conducted trials examining system-level interventions. Four recent Cochrane Collaboration reviews for telephone support,^164^ prenatal education,^159^ restricted pacifier use,^165^ and rooming-in^166^ all concluded that there was insufficient good-quality studies from which to draw definitive conclusions regarding the influence of these interventions on breastfeeding outcomes.

## Limitations of Included Studies

Several limitations of the included body of evidence deserve special attention. First, most of the studies included a number of threats to internal validity, including possible selection bias, reporting bias, and relatively high attrition. There are unique issues in the design of these trials that relate to recruiting and randomizing pregnant women who may or may not be eligible for the study after giving birth. Some studies reported as much as 25 percent of the randomized sample not being eligible for the in-hospital peripartum or postpartum intervention after delivery because of factors such as infant low birth weight, admission to a neonatal intensive care unit, or breastfeeding contraindications. The baseline characteristics were often presented for the full randomized sample, so it is not clear how comparable the groups were according to the eligible samples. In addition, while most trials did not explicitly state exclusions based on breastfeeding status, it was clear from examining trials' participant flow diagrams that women who reported stopping breastfeeding or never started breastfeeding were not included in the intervention from that point forward. More explicit information regarding participant flow, by treatment arm, through such studies is warranted.

Second, despite several calls over the last three decades for standardizing breastfeeding definitions and indicators for both surveillance and program evaluation,^2,77,167-173^ there was no uniform reporting of breastfeeding outcomes across the included studies regarding definitions of breastfeeding and timing of assessments. Most of the studies followed the WHO definition for exclusive breastfeeding,^77^ but others used less robust definitions or did not report what counted as exclusive breastfeeding. Few studies specified whether recall was based on the previous 24 hours versus having been exclusively breastfeed since birth. Using 24-hour recall overestimates the proportion of exclusively breastfed infants, as some infants who are given formula irregularly may not have received them the day before the interview. This was evident in one of our included studies that reported rates of exclusive breastfeeding based on three different recall periods. Chapman et al reported that at 3 months, 25.9, 24.1, and 5.0 percent of women reported exclusive breastfeeding based on the recall periods of the past 24 hours, past week, and since birth, respectively.^98^

In addition, there was a lack of clarity concerning the boundary point for many of the prevalence time points. That is, it was unclear if exclusive breastfeeding reported for 6 months was exclusive breastfeeding at 6 months or exclusive breastfeeding to 6 months, which is technically the recommendation (the introduction of something other than breast milk at or after 6 months among otherwise exclusively breastfed infants). We pooled the results for exclusive breastfeeding at 6 months as was reported in the individual trials but suspect this technically means the infant was exclusively breastfed up to 6 months (i.e., did not receive any milk substitutes but may have received solids). Also, very few of the studies noted whether their definition of breastfeeding included feeding the infant expressed breast milk in addition to baby-to-breast breastfeeding. We encourage investigators of future studies to note the specific instrument that was used to capture breastfeeding behavior; describe verbatim the questions that were posed to mothers; and note the specific definitions (in terms of content and feeding method), recall period, and time point related to the measure. Likewise, while most of the studies (31 of 52) stated that they only included women who intended to breastfeed, it was unclear how this was measured and, in most cases, how strong these intentions were.

Finally, as mentioned earlier, the comparator in most studies was “usual” or “routine” care. The support given for breastfeeding in these usual care groups, however, was rarely well described, making it difficult to fully interpret the reasons for differences between trials and in interpreting the overall effect. In an instance where “usual care” is very supportive, the numbers needed to detect a statistical difference would need to be inflated. We did note whether the trial setting indicated BFHI accreditation as an indicator of the usual level of breastfeeding support provided to mothers and infants, but very few studies reported this indicator. The wide range of breastfeeding rates within the control groups across studies illuminates the differences that likely exist in the content of usual care within these settings as well as underlying population and cultural differences.

## Limitations of Our Approach

There are also limitations to our methods that should be noted. We restricted our review to fair- and good-quality RCTs and before-after designs with concurrent control groups to reduce the potential for confounding and other sources of bias. Even with somewhat liberal standards for judging the risk of bias for this complex literature base, we excluded 33 trials for poor quality, several of which were included in the original USPSTF review.^174-188^ The studies excluded for poor quality were fraught with issues related to confounding, selective recall bias, differential loss to followup, and handling of missing data as well as for poor or incomplete reporting of results. Given the quantity of these studies, we did not contrast their findings with our included studies.

To calculate within-study RRs and in our pooled meta-analyses, we chose to use the raw event rates and total number of women randomized. Therefore, our analyses did not control for potential confounding factors such as socioeconomic status, employment status, education level, parity, or previous breastfeeding experience. We compared our crude relative estimates with any study-reported unadjusted and adjusted estimates and noted any differences within the narrative of our results.

Two of our funnel plots presented asymmetry and the tests for small-study effects were significant. There are a number of possible explanations for these results, including publication bias, poor methodological quality leading to spuriously inflated effects in the smaller studies, true heterogeneity in the size of the effects, and chance.

We did not systematically review the relationship between ever versus never breastfeeding or the duration of any or exclusive breastfeeding and short- and long-term child or maternal health outcomes. Thus, we did not complete the entire chain of evidence. We instead focused only on the direct evidence related to interventions to increase breastfeeding and health outcomes. The evidence on the associations between breastfeeding and health outcomes was previously systematically reviewed^12^ and was found to adequately support the USPSTF recommendation. We informally reviewed more recent evidence from existing systematic reviews as part of our introduction; however, a systematic update might have revealed more data than we found.

Our review was limited to studies taking place in countries listed as “very high” on the 2014 United Nations Human Development Index to ensure that the evidence was applicable to a U.S. setting.^75^ This index is based on three key indicators—life expectancy, education, and standard of living—rather than on economic growth alone. Relying on alternative lists for country level of development (e.g., Organization for Economic Cooperation and Development member countries, World Bank classifications by gross national income) may have resulted in a slightly different list of included countries and, therefore, slightly different included studies. We also limited the review to studies conducted within, in conjunction with, or referable from a health care setting. We did not include interventions taking place within worksites or other community settings. We acknowledge, however, that other nonhealth care settings may play very important roles in a woman's decision to start breastfeeding her child and her ability to continue.

## Future Research Needs

Several areas warrant further research in light of the results of this review. In general, future research on breastfeeding interventions in the clinical setting should be more rigorously conducted, with adequate sample sizes and clear descriptions of the included populations, including women's breastfeeding status at the time of recruitment, intentions to breastfeed, previous experience breastfeeding, and sociodemographic characteristics. Future trials should also describe in detail the characteristics of both the intervention and control arms, including the extent to which usual care is supportive of breastfeeding (e.g., BFHI accreditation or not, staff trained in breastfeeding or not). In order to compare breastfeeding outcomes between various studies, it would be helpful to standardize the reporting of breastfeeding rates at critical time points. Given the recommendations for exclusive breastfeeding up to 6 months and any breastfeeding for at least 1 year, rates of exclusive breastfeeding and any breastfeeding should be measured at these points, at a minimum. In addition, studies should include a detailed description of how breastfeeding was measured (e.g., via self-report or based on clinical records, definition of any and exclusive breastfeeding used, and recall period). Only one of our included trials included a measure of partial breastfeeding or breastfeeding “intensity” based on the proportion of feedings that were breast milk; future research should consider this more nuanced breastfeeding indicator to further distinguish the effects of breastfeeding interventions.^2^ Trials should also include reliable and valid measures of infant and maternal health outcomes and be powered to detect potential effects on these outcomes. Likewise, studies should further explore maternal satisfaction with the intervention and any potential negative feelings or feelings of inadequacy that could result from the intervention if mothers choose not to or are unable to breastfeed.

More research is also needed to better understand the root causes of breastfeeding disparities and how they can be addressed through health care and community interventions. We did not identify any trials evaluating interventions targeting Native Americans and found only a few that specifically targeted non-Hispanic black women. These women show marked differences in their rates of breastfeeding initiation and continuation, particularly for exclusive breastfeeding, for which only a third of black women and a quarter of American Indian/Alaska Native women reported exclusively breastfeeding through 3 months. It is evident that effective interventions tailored to the unique barriers for these women deserve increased attention.

There is also a need for more adequately controlled studies that evaluate the impact of system-level changes on rates of breastfeeding, including comparing birth facilities that are BFHI-accredited or are implementing the full suite (or majority) of policies required of BFHI accreditation versus those that are not adopting any or very few of the 10 steps required for accreditation.

Our review included no fair- or good-quality trials that used Internet- or other computer-based interventions to increase the proportion of new mothers initiating breastfeeding or continuing to breastfeed. There is a wealth of Web-based resources for parents regarding infant health and development, including breastfeeding. However, the effectiveness of these resources as a forum for educating new families and supporting those who have started breastfeeding remains understudied.^189^ These resources have the potential to reach large numbers of women at low cost and at the mother's convenience. Numerous informational Web sites, Web-based videos, and Web-based applications related to tracking breastfeeding sessions, establishing proper breastfeeding techniques, managing common breastfeeding-related issues, preparing for return to work or school, and connecting with other mothers and lactation care providers through discussion forums are available, such as latchME, Breastfeeding Central, and Kellymom. These sites could be widely promoted or disseminated through health care providers if they were found to influence the duration or exclusivity of breastfeeding.

We identified 10 ongoing studies that may be relevant for updates of this review, including three trials taking place in the United States (Appendix D).

## Conclusion

The body of fair- to good-quality evidence on the effectiveness of individual- and system-level interventions to support breastfeeding has nearly doubled since the previous USPSTF recommendation in 2009. Although there was substantial variation between the settings, participants, and interventions among the included studies, there is consistent evidence that individual-level support and education interventions that take place during the prenatal, peripartum, and/or postpartum periods can increase the prevalence of breastfeeding, including exclusive breastfeeding, for up to 6 months. Interventions provided by both professionals and peers were effective. There is limited evidence from well-controlled studies of the effect of system-level policies and maternity care practices on rates of breastfeeding. Finally, there is a large need for more research on these system-level interventions as well as interventions among population subgroups for which breastfeeding rates lag behind national goals.