# 3 Results

## Description of Included Studies

Our literature search yielded 2,769 unique citations. From these, we provisionally accepted 211 articles for review based on titles and abstracts (Appendix A Figure 1). After reviewing the full-text articles, we determined that 52 studies (reported in 57 articles) met the inclusion criteria.^79-84^, ^90-140^ Only 21 studies (in 22 articles^79,81,91,93,94,96,99,101,103,104,106,109,112,117,119,120,122,126,128^, ^132,135,136^) were carried forward from the previous review and were synthesized with the new evidence. Thirty-one studies were identified as part of the update. Two independent studies were reported within one publication: the Best Infant Nutrition for Good Outcomes (BINGO) study is referred to as Bonuck, 2014a and the Provider Approaches to Improved Rates of Infant Nutrition & Growth Study (PAIRINGS) study is referred to as Bonuck, 2014b.^92^ Fifty of the 52 included studies were individual- or cluster-based RCTs (n=39,416). The remaining two studies were controlled before-after studies that examined rates of breastfeeding before and after receipt of BFHI accreditation among hospitals receiving accreditation versus matched control hospitals.^107,108^

For the 211 full-text articles that were reviewed, the most common reasons for exclusion were study design (i.e., not an RCT or a controlled before-after design for system-level interventions; k=51), poor quality (k=33), and not reporting any relevant outcomes (k=22). Appendix B contains a list of all excluded studies and their main reason for exclusion, including those excluded for poor quality.

We found clinical and methodological heterogeneity across the included studies in terms of the country setting, study population, intervention and control conditions, specific outcome measures, and timing of those measures. Nineteen of the 52 included studies took place in the United States; the remaining studies occurred in Canada (k=6), Australia (k=6), the United Kingdom (k=7), other European countries (k=9), Hong Kong or Singapore (k=4), and Argentina (k=1) (Table 6). Sample sizes for the RCTs ranged from 36 to 17,482 mothers and the median sample size was 376. In the controlled before-after studies, the sample size ranged from 2,014 to more than 25,000 mothers within five U.S. states for a study comparing rates of breastfeeding before and after BFHI accreditation. Five studies had a primary aim other than promoting breastfeeding (e.g., the effect of early skin-to-skin contact on infant temperature or the effect of postpartum education on postpartum depression),^105,114,129,130,132^ but because their interventions also targeted breastfeeding and breastfeeding outcomes were reported, we included them in our review.

Table 6 Study and Population Characteristics for All Studies, by Author

Author, Year, Quality | Country | n Rand | Key Inclusion Criteria | Primiparous (%) | Previously Breastfed (%)^*^ | Currently BF | Intending to BF (%) | Population Characteristics
Abbass-Dick, 2015^90^ Good | Canada | 214 | ≥18 years old; primiparous; exclusively breastfeeding in hospital and intending to breastfeed >12 weeks; living with male partner who is available to participate in study | 100 | NA | Y | 100^†^ | Predominantly well educated (72.9% attended university), race/ethnicity NR
Anderson, 2005^91^ Fair | US | 182 | ≥18 years old; considering breastfeeding; living in a household earning <185% of the federal poverty level | 51.9 | 40 | N | 100 | Predominantly inner city, Hispanic (71.9%), low-income, not married or cohabiting
Bonuck, 2006^93^ Fair | US | 382 | Not on chronic therapy with medications incompatible with breastfeeding | 39.8 | 42.4 | N | 76.6 | Predominantly low-income Hispanic (56.6%) or black (36.2%), 39.3% foreign-born
Bonuck, 2014a (BINGO)^92^ Good | US | 666 | ≥18 years old | 39.2 | 45.2 | N | 87.6 | Predominantly urban, low-income Hispanic (56.8%) or black (28.5%)
Bonuck, 2014b (PAIRINGS)^92^ Good | US | 275 | ≥18 years old | 43.5 | 49.2 | N | 94.3 | Predominantly Hispanic (55.7%) or black (28.2%)
Bunik, 2010^95^ Fair | US | 341 | ≥18 years old; willing to consider breastfeeding | 100 | NA | N | 100 | Predominantly low-income, Spanish-speaking (65.1%), Hispanic (87.7%)
Carfoot, 2005^96^ Fair | UK | 204 | Intending to breastfeed; did not request either skin-to-skin contact or no skin-to-skin contact after delivery | 43.6 | 48.0 | N | 100 | NR
Carlsen, 2013^97^ Fair | Denmark | 226 | Infant postnatal age <48 hours; began breastfeeding at start of intervention and intending to continue; history of breast surgery; prepregnancy BMI ≥30 kg/m^2^ | 60.4 | NR | Y | 100 | Obese; demographic data sparse; race/ethnicity NR
Chapman, 2013^98^ Fair | US | 206 | ≥18 years old; considering breastfeeding; prepregnancy BMI ≥27.0 kg/m^2^; income <185% of federal poverty level | NR | NR | N | 100 | Overweight or obese, predominantly low-income and unemployed Hispanic (81.8%), 50% of Puerto Rican origin
Dennis, 2002^99^ Fair | Canada | 258 | ≥16 years old; currently breastfeeding in the hospital; primiparous | 100 | NA | Y | 99.6 | Well educated (74.6% at least college education), race/ethnicity NR
Di Meglio, 2010^100^ Fair | US | 78 | <21 years old; currently breastfeeding (1 day postpartum) | 87.2 | 9.0 | Y | 70.8^‡^ | Young adults (<21 years old), predominantly low-income black (50.0%) or white (47.4%)
Di Napoli, 2004^101^ Fair | Italy | 605 | Began breastfeeding at start of intervention and intending to continue | 44.3 | 37.2 | Y | 100 | Well educated (61.0% high school or college degree), race/ethnicity NR
Edwards, 2013^102^ Fair | US | 248 | <21 years old; not planning on having a cesarean delivery | 88.7 | NR | N | 62.1 | Young adults (<21 years old), low-income African American, predominantly currently in school (54.4%) and residing with parent (78.2%)
Elliott-Rudder, 2014^80^ Good | Australia | 330 | Currently breastfeeding for ≥8 weeks; planning to receive postnatal care at a participating general practice | 36.2 | 44.1 | Y | NR | Currently breastfeeding for ≥8 weeks, well educated (53.1% college degree or higher), race/ethnicity NR
Forster, 2004^103^ Fair | Australia | 984 | Primiparous | 100 | NA | N | 92.5 | Low-income, culturally diverse, sparse demographic data
Fu, 2014^82^ Fair | Hong Kong | 724 | ≥18 years old; primiparous; Hong Kong Chinese; intending to breastfeed | 100 | NA | N | 100 | Hong Kong Chinese
Gagnon, 2002^104^ Fair | Canada | 586 | Participating in hospital's short stay program; infant breastfed at least once in the hospital | 32.6 | NR | Y | 89.1^‡^ | General, race/ethnicity NR
Gijsbers, 2006^84^ Fair | Netherlands | 91 | ≥1 first-degree relative had asthma that had been diagnosed by a doctor | 41.6 | 53.9 | N | 86.5 | Family history of asthma, well educated (53.9% highest level of secondary education or university), race/ethnicity NR
Gouchon, 2010^105^ Fair | Italy | 36 | Scheduled for elective cesarean delivery | 23.5 | 58.8 | N | NR | General, race/ethnicity NR
Graffy, 2004^106^ Fair | UK | 720 | Considering breastfeeding; had not breastfed a previous child for ≥6 weeks | 74.9 | NR | N | 96.9 | General, predominantly white (69.7%)
Hawkins, 2014a^107^ Good | US | 25,327 | Gave birth at BFHI-accredited hospital (or nonaccredited for CG) in Alaska, Maine, Nebraska, Ohio, or Washington during 1999 to 2009 | 41.9 | NR | NR | NR | General, predominantly white (50.7%)
Hawkins, 2014b^108^ Good | US | 2,014 | Gave birth at BFHI-accredited hospital (or nonaccredited for CG) in Maine during 2004 to 2008 | NR | NR | NR | | General, predominantly white (95.6%)
Henderson, 2001^109^ Good | Australia | 160 | Primiparous; planning on breastfeeding | 100 | NA | Y | 100 | General, race/ethnicity NR
Hoddinott, 2009^110^ Good | Scotland | 17,482 | Pregnant or breastfeeding; registered at participating general practices in 2002 | NR | NR | NR | NR | Predominantly living in deprived areas^**^
Hopkinson, 2009^111^ Good | US | 522 | Mixed feeding in the hospital | NR | NR | Y | NR | Majority (98%) born in Mexico or Central America^**^
Howard, 2003^112^ Good | US | 807 | Intending to breastfeed for ≥4 weeks; undecided about or wanted pacifier use | 39.3 | 54.0 | N | 100 | Predominantly white (86.6%), employed (77.1%), expectant father lives in household (91.0%)
Howell, 2014^114^ Fair | US | 540 | ≥18 years old; black or Hispanic | 40.7 | NR | N | NR | Black (37.6%) or Hispanic (62.4%), predominantly low-income and well-educated (54.0% some college or more)
Jenik, 2009^115^ Good | Argentina | 1,021 | Exclusively breastfeeding at 2 weeks; intending to breastfeed for ≥3 months; not using pacifiers | NR | 41.0 | Y | 100 | Predominantly or exclusively Hispanic^††^
Jolly, 2012^83^ Fair | UK | 2,724 | Estimated delivery date in study period | 34.4 | 46.1 | N | 81.4 | Predominantly of Asian or Middle Eastern origin, living in deprived urban areas
Kellams, 2015^116^ Good | US | 522 | Women with income <185% of the federal poverty level | NR | NR | N | 67.4 | Low-income, predominantly black (45.4%) or white (41.6%)
Kools, 2005^81^ Fair | Netherlands | 781 | Applied for maternity care in intervention or control maternity centers | 55.9 | 28.7 | N | 68.3 | General, race/ethnicity NR
Kramer, 2001^117^ Good | Canada | 281 | Intending to breastfeed for ≥3 months | 47.3 | 50.8 | N | 100 | Multicultural (66.2% English predominant language), predominantly well educated (16.0 mean years of education), employed (76.0%), married (81.4%)
Kronborg, 2012^118^ Fair | Denmark | 1,193 | ≥18 year old; primiparous | 100 | NA | N | NR | General, most with >10 years education (90.9%), race/ethnicity NR
Labarere, 2003^119^ Good | France | 210 | ≥18 year old; currently breastfeeding in the hospital | 52.6 | NR | Y | NR | Predominantly well-educated (58.9% partial college or college degree), employed (69.2%), race/ethnicity NR
Labarere, 2005^120^ Good | France | 231 | Breastfeeding on day of discharge | 52.4 | NR | Y | NR | Predominantly well-educated (74.0% >high school), employed (77.5%), race/ethnicity NR
Lavender, 2005^79^ Fair | UK | 1,312 | Expressing a desire to breastfeed | 51.2 | NR | N | 100 | Predominantly deprived or low-income white (92.1%)
Mattar, 2007^122^ Fair | Singapore | 401 | No previous cesarean delivery; no obstetric complications that would contraindicate vaginal delivery | 37.2 | 64.4 | N | 95.3 | Asian, predominantly low-income and unemployed
McDonald, 2010^123^ Good | Australia | 849 | ≥18 years old; intending to breastfeed | 50.4 | NR | N | 100^§^ | General, lower SES (33.6%), race/ethnicity NR
McQueen, 2011^124^ Good | Canada | 150 | Primiparous; intending to breastfeed | 100 | NA | N | 100 | Predominantly white (81.3%), well-educated (71.3% college)
Muirhead, 2006^126^ Fair | Scotland | 225 | Received prenatal care at a participating clinic | 53.3 | 23.6 | N | 51.6 | NR
Noel-Weiss, 2006^128^ Fair | Canada | 101 | Primiparous; intending to breastfeed | 100 | NA | N | 100 | Predominantly high family income, well-educated, in committed relationship
Nolan, 2009^129^ Fair | US | 50 | Scheduled for a planned repeat cesarean delivery | 0 | NR | N | NR | Predominantly white (72.0%), married (68.0%)
Paul, 2012^130^ Fair | US | 1,154 | Attempting to breastfeed during maternity stay; intent to continue breastfeeding after discharge | 47.5 | 48.6 | Y | 100 | Predominantly white (88.4%), well-educated (57.4% college degree), higher income, married (79.0%)
Pollard, 2011^131^ Good | US | 86 | 18 to 40 years old; primiparous; intending to breastfeed; initiated breastfeeding within 24 hours of delivery | 100 | NA | Y | 100 | Predominantly white (96.5%), married (80.2%), employed (59.3%)
Quinlivan, 2003^132^ Fair | Australia | 136 | ≤18 years old; intending to continue with pregnancy and not relinquish the infant | NR | NR | N | NR | Adolescents (≤18 years), predominantly low SES (86.6%), 24.3% indigenous Australian
Reeder, 2014^133^ Fair | US | 1,948 | Attending a new pregnancy appointment for WIC; intending or undecided about breastfeeding | NR | NR | N | NR | Low income, predominantly less educated, Hispanic (58.3%)
Stockdale, 2008^134^ Fair | Ireland | 182 | Primiparous | 100 | NA | N | NR | General, race/ethnicity NR
Su, 2007^135^ Fair | Singapore | 450 | Intending to breastfeed | 39.6 | 56.4 | N | 100 | Asian, predominantly low income
Wallace, 2006^136^ Fair | UK | 370 | Primiparous; intending to breastfeed; able to sit out of bed at time of first feed; no cesarean delivery | 100 | NA | N | 100 | NR
Wambach, 2011^137^ Fair | US | 390 | 15 to 18 years old; primiparous; planning to keep newborn | 100 | NA | N | NR | Adolescents (15–18 years), predominantly black (61.0%), low family income, in school (71.0%), living with family (74.0%)
Wen, 2011^139^ Good | Australia | 667 | ≥16 years old; primiparous | 100 | NA | N | NR | General, race/ethnicity NR
Wong, 2014^140^ Good | Hong Kong | 469 | ≥18 years old; primiparous; intending to breastfeed; Hong Kong resident | 100 | NA | N | 100 | Asian, predominantly well- educated (54.4% postsecondary or university degree), high family income

* Among full sample not just multiparous.

† Intended to breastfeed for >12 weeks.

‡ Intended to exclusively breastfeed.

§ 76.3% intended to breastfeed >6 months.

** As described in study text.

†† Race/ethnicity NR, assume 100% Hispanic.

Abbreviations: BF=breastfeed; BFHI=Baby-Friendly Hospital Initiative; BINGO=Best Infant Nutrition for Good Outcomes; BMI=body mass index; CG=control group; n=number; N=no; NA=not applicable; NR=not reported; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; rand=randomized; SES=socioeconomic status; UK=United Kingdom; US=United States; Y=yes

### Included Populations

The inclusion criteria for women allowed in the studies was highly variable across individual studies, and the demographic characteristics of the included samples were often sparsely reported (Table 6). Four studies were limited to adolescents (age <18 years)^132,137^ or young adults (age <21 years).^100,102^ Among the 38 studies that reported the age of included women, the average age ranged from 16 to 34 years and the median of the average age was 29 years. Fifteen trials were limited to primiparous mothers,^82,90,95,99,103,109,118,124,128,131,134,136,137,139,140^ one trial was limited to multiparous women scheduled for a repeat Cesarean delivery,^129^ and the remaining trials that reported parity represented both primiparous and multiparous mothers (23.5% to 88.7% primiparous). Where reported, the percentage of women who had reported any previous breastfeeding within the full sample (not only among multiparous women) ranged from 9 to 64.4 percent.

Fourteen of the 52 trials restricted inclusion to women who were currently breastfeeding at the time of recruitment or at the beginning of the intervention.^80,90,97,99,100,104,109,111,115,119,120,130,131^ Two of these 14 trials limited inclusion to women who had been breastfeeding for at least 2 weeks^115^ or 8 weeks^80^ at the time of recruitment. Thirty-one of the 52 trials included only women who intended to breastfeed^79,82,90,91,95-98,101,109,112,115,117,123,124,128,130,131,135,136,140^ or resulted in samples where 75 percent or more of the women intended to breastfeed at baseline.^83,84,92,93,99,103^, ^104,106,122^ The remaining 21 studies did not report breastfeeding intentions among the expectant mothers or reported that less than 75 percent intended to breastfeed. Almost all of the studies explicitly stated the exclusion of women or infants with conditions that would preclude or complicate breastfeeding, such as an infant congenital abnormality.

Two trials were limited to overweight or obese women^97,98^ and one trial to women who had a family history of asthma.^84^ One study was limited to women who had a male partner who could participate in the study because the focus of the intervention was effective coparenting.^90^ Two studies that evaluated the effect of skin-to-skin contact interventions on maternal and infant outcomes were limited to women scheduled for a Cesarean delivery.^105,129^ One study specifically excluded women who delivered by Cesarean section.^104^ Of the remaining studies that reported the percentage of women who delivered by Cesarean section, the rate ranged from 2.8 to 46.0 percent within treatment arms.

Among the studies that took place in the United States (k=19), most of them included predominantly Hispanic or black low-income women (e.g., the majority of participants received Medicaid or were enrolled in WIC). Within the Canadian trials (k=6), most women were well educated (i.e., ≥70% with at least a college education) but the race/ethnicity of participating women was rarely reported. Very little demographic detail was provided on women participating in the studies that took place in Europe or Australia: two studies in the United Kingdom described the samples as drawn from “deprived urban areas,” with one predominantly including women of Asian or Middle Eastern origin,^79,83^ and one Australian trial used a sample of high-risk, predominantly low socioeconomic status adolescents, of whom nearly a quarter were indigenous.

### Included Interventions and Usual Care Control Groups

The included interventions were also highly variable, including the timing of the intervention (i.e., prenatal, peripartum, and/or postpartum); combination of intervention components; frequency, length, and duration of intervention sessions; providers; content; and implementation (Table 7; Appendix C Table 1). Given the variability in the interventions, we categorized each intervention arm into five groups based on the level of the intervention (i.e., individual- or system-level), type of intervention, and type of provider (i.e., professional or peer). The 52 studies included 58 different intervention arms, as shown in Table 8. We describe the detailed results for breastfeeding outcomes according to the level of the intervention (individual vs. system) and by the specific type of intervention where appropriate.

Table 7 Intervention Characteristics for All Studies, by Author

Author, Year | Quality | Identified in Update | Country | n Rand | Key Inclusion Criteria | Primiparous, n (%) | Previously Breastfed (%)^*^ | Currently BF | Intending to BF, n (%) | Population Characteristics
Abbass-Dick, 2015^3^ | Good | X | Canada | 214 | ≥18 years old; primiparous; exclusively breastfeeding in hospital and intending to breastfeed >12 weeks; living with male partner who is available to participate in study | 214 (100) | NA | Y | 214 (100)^†^ | Predominantly well-educated (72.9% attended university), race/ethnicity NR
Anderson, 2005^4^ | Fair | | US | 182 | ≥18 years old; considering breastfeeding; living in a household earning <185% of the federal poverty level | 70 (51.9) | 40 | N | 135 (100) | Predominantly inner city, Hispanic (71.9%), low-income, not married or cohabiting
Bonuck, 2006^5^ | Fair | | US | 382 | Not on chronic therapy with medications incompatible with breastfeeding | 121 (39.8) | 42.4 | N | 233 (76.6) | Predominantly low-income Hispanic (56.6%) or black (36.2%), 39.3% foreign-born
Bonuck, 2014a (BINGO)^6^ | Good | X | US | 666 | ≥18 years old | 246 (39.2) | 45.2 | N | 550 (87.6) | Predominantly urban, low-income Hispanic (56.8%) or black (28.5%)
Bonuck, 2014b (PAIRINGS)^6^ | Good | X | US | 275 | ≥18 years old | 114 (43.5) | 49.2 | N | 247 (94.3) | Predominantly Hispanic (55.7%) or black (28.2%)
Bunik, 2010^7^ | Fair | X | US | 341 | ≥18 years old; willing to consider breastfeeding | 341 (100) | NA | N | 339 (100) | Predominantly low-income, Spanish-speaking (65.1%), Hispanic (87.7%)
Carfoot, 2005^8^ | Fair | | UK | 204 | Intending to breastfeed; did not request either skin-to-skin contact or no skin-to-skin contact after delivery | 89 (43.6) | 48.0 | N | 204 (100) | NR
Carlsen, 2013^9^ | Fair | X | Denmark | 226 | Infant postnatal age <48 hours; began breastfeeding at start of intervention and intending to continue; history of breast surgery; prepregnancy BMI ≥30 kg/m^2^ | 125 (60.4) | NR | Y | 207 (100) | Obese; demographic data sparse; race/ethnicity NR
Chapman, 2013^10^ | Fair | X | US | 206 | ≥18 years old; considering breastfeeding; prepregnancy BMI ≥27.0 kg/m^2^; income <185% of federal poverty level | NR (NR) | NR | N | 154 (100) | Overweight or obese, predominantly low-income and unemployed Hispanic (81.8%), 50% of Puerto Rican origin
Dennis, 2002^11^ | Fair | | Canada | 258 | ≥16 years old; currently breastfeeding in the hospital; primiparous | 256 (100) | NA | Y | 255 (99.6) | Well-educated (74.6% at least college education), race/ethnicity NR
Di Meglio, 2010^12^ | Fair | X | US | 78 | <21 years old; currently breastfeeding (1 day postpartum) | 68 (87.2) | 9.0 | Y | 50 (70.8)^§^ | Young adults (<21 years), predominantly low-income black (50.0%) or white (47.4%)
Di Napoli, 2004^13^ | Fair | | Italy | 605 | Began breastfeeding at start of intervention and intending to continue | 268 (44.3) | 37.2 | Y | 605 (100) | Well-educated (61.0% high school or college degree), race/ethnicity NR
Edwards, 2013^14^ | Fair | X | US | 248 | <21 years old; not planning on having a cesarean delivery | 219 (88.7) | NR | N | 154 (62.1) | Young adults (<21 years), low-income African American, predominantly currently in school (54.4%) and residing with parent (78.2%)
Elliott-Rudder, 2014^15^ | Good | X | Australia | 330 | Currently breastfeeding for ≥8 weeks; planning to receive postnatal care at a participating general practice | 118 (36.2) | 44.1 | Y | NR (NR) | Currently breastfeeding for ≥8 weeks, well- educated (53.1% college degree or higher), race/ethnicity NR
Forster, 2004^16^ | Fair | | Australia | 984 | Primiparous | 981 (100) | NA | N | 907 (92.5) | Low-income, culturally diverse, sparse demographic data
Fu, 2014^17^ | Fair | X | Hong Kong | 724 | ≥18 years old; primiparous; Hong Kong Chinese; intending to breastfeed | 724 (100) | NA | N | 415 (100) | Hong Kong Chinese
Gagnon, 2002^18^ | Fair | | Canada | 586 | Participating in hospital's short stay program; infant breastfed at least once in the hospital | 191 (32.6) | NR | Y | 522 (89.1)^‡^ | General, race/ethnicity NR
Gijsbers, 2006^19^ | Fair | X | Netherlands | 91 | ≥1 first-degree relative had asthma that had been diagnosed by a doctor | 37 (41.6) | 53.9 | N | 77 (86.5) | Family history of asthma, well-educated (53.9% highest level of secondary education or university), race/ethnicity NR
Gouchon, 2010^20^ | Fair | X | Italy | 36 | Scheduled for elective cesarean delivery | 8 (23.5) | 58.8 | N | NR (NR) | General, race/ethnicity NR
Graffy, 2004^21^ | Fair | | UK | 720 | Considering breastfeeding; had not breastfed a previous child for ≥6 weeks | 539 (74.9) | NR | N | 689 (96.9) | General, predominantly white (69.7%)
Hawkins, 2014a^22^ | Good | X | US | 25,327 | Gave birth at BFHI-accredited hospital (or nonaccredited for CG) in Alaska, Maine, Nebraska, Ohio, or Washington during 1999–2009 | 41.9 | NR | NR | NR (NR) | General, predominantly white (50.7%)
Hawkins, 2014b^23^ | Good | X | US | 2,014 | Gave birth at BFHI-accredited hospital (or nonaccredited for CG) in Maine during 2004–2008 | NR (NR) | NR | NR | NR (NR) | General, predominantly white (95.6%)
Henderson, 2001^24^ | Good | | Australia | 160 | Primiparous; planning on breastfeeding | 160 (100) | NA | Y | 160 (100) | General, race/ethnicity NR
Hoddinott, 2009^25^ | Good | X | Scotland | 17,482 | Pregnant or breastfeeding; registered at participating general practices in 2002 | NR (NR) | NR | NR | NR (NR) | Predominantly living in deprived areas^§^
Hopkinson, 2009^26^ | Good | X | US | 522 | Mixed feeding in the hospital | NR (NR) | NR | Y | NR (NR) | Majority (98%) born in Mexico or Central America^§^
Howard, 2003^27^ | Good | | US | 807 | Intending to breastfeed for ≥4 weeks; undecided about or wanted pacifier use | 275 (39.3) | 54.0 | N | 700 (100) | Predominantly white (86.6%), employed (77.1%), expectant father lives in household (91.0%)
Howell, 2014^28^ | Fair | X | US | 540 | ≥18 years old; black or Hispanic | 220 (40.7) | NR | N | NR (NR) | Black (37.6%) or Hispanic (62.4%), predominantly low-income and well-educated (54.0% some college or more)
Jenik, 2009^29^ | Good | X | Argentina | 1,021 | Exclusively breastfeeding at 2 weeks; intending to breastfeed for ≥3 months; not using pacifiers | NR (NR) | 41.0 | Y | 1021 (100) | Predominantly or exclusively Hispanic^¶^
Jolly, 2012^30^ | Fair | X | UK | 2,724 | Estimated delivery date in study period | 816 (34.4) | 46.1 | N | 690 (81.4) | Predominantly of Asian or Middle Eastern origin, living in deprived urban areas
Kellams, 2015^31^ | Good | X | US | 522 | Women with income <185% of the federal poverty level | NR (NR) | NR | N | 335 (67.4) | Low-income, predominantly black (45.4%) or white (41.6%)
Kools, 2005^32^ | Fair | | Netherlands | 781 | Applied for maternity care in intervention or control maternity centers | 390 (55.9) | 28.7 | N | 477 (68.3) | General, race/ethnicity NR
Kramer, 2001^33^ | Good | | Canada | 281 | Intending to breastfeed for ≥3 months | 122 (47.3) | 50.8 | N | 258 (100) | Multicultural (66.2% English predominant language), predominantly well educated (16.0 mean years of education), employed (76.0%), married (81.4%)
Kronborg, 2012^34^ | Fair | X | Denmark | 1,193 | ≥18 year old; primiparous | 1162 (100) | NA | N | NR (NR) | General, most with >10 years education (90.9%), race/ethnicity NR
Labarere, 2003^35^ | Good | | France | 210 | ≥18 year old; currently breastfeeding in the hospital | 100 (52.6) | NR | Y | NR (NR) | Predominantly well- educated (58.9% partial college or college degree), employed (69.2%), race/ethnicity NR
Labarere, 2005^36^ | Good | | France | 231 | Breastfeeding on day of discharge | 121 (52.4) | NR | Y | NR (NR) | Predominantly well- educated (74.0% >high school), employed (77.5%), race/ethnicity NR
Lavender, 2005^37^ | Fair | | UK | 1,312 | Expressing a desire to breastfeed | 672 (51.2) | NR | N | 1312 (100) | Predominantly deprived or low-income white (92.1%)
Mattar, 2007^38^ | Fair | | Singapore | 401 | No previous cesarean delivery; no obstetric complications that would contraindicate vaginal delivery | 149 (37.2) | 64.4 | N | 382 (95.3) | Asian, predominantly low-income and unemployed
McDonald, 2010^39^ | Good | X | Australia | 849 | ≥18 years old; intending to breastfeed | 428 (50.4) | NR | N | 849 (100)^**^ | General, lower SES (33.6%), race/ethnicity NR
McQueen, 2011^40^ | Good | X | Canada | 150 | Primiparous; intending to breastfeed | 150 (100) | NA | N | 150 (100) | Predominantly white (81.3%), well-educated (71.3% college)
Muirhead, 2006^41^ | Fair | | Scotland | 225 | Received prenatal care at a participating clinic | 120 (53.3) | 23.6 | N | 116 (51.6) | NR
Noel-Weiss, 2006^42^ | Fair | | Canada | 101 | Primiparous; intending to breastfeed | 92 (100) | NA | N | 92 (100) | Predominantly high family income, well- educated, in committed relationship
Nolan, 2009^43^ | Fair | X | US | 50 | Scheduled for a planned repeat cesarean delivery | 0 (0) | NR | N | NR (NR) | Predominantly white (72.0%), married (68.0%)
Paul, 2012^44^ | Fair | X | US | 1,154 | Attempting to breastfeed during the maternity stay; intent to continue breastfeeding after discharge | 548 (47.5) | 48.6 | Y | 1154 (100) | Predominantly white (88.4%), well-educated (57.4% college degree), higher income, married (79.0%)
Pollard, 2011^45^ | Good | X | US | 86 | 18–40 years old; primiparous; intending to breastfeed; initiated breastfeeding within 24 hours of delivery | 86 (100) | NA | Y | 86 (100) | Predominantly white (96.5%), married (80.2%), employed (59.3%)
Quinlivan, 2003^46^ | Fair | | Australia | 136 | ≤18 years old; intending to continue with pregnancy and not relinquish the infant | NR (NR) | NR | N | NR (NR) | Adolescents (≤18 years), predominantly low SES (86.6%), 24.3% indigenous Australian
Reeder, 2014^47^ | Fair | X | US | 1,948 | Attending a new pregnancy appointment for WIC; intending or undecided about breastfeeding | NR (NR) | NR | N | NR (NR) | Low income, predominantly less educated, Hispanic (58.3%)
Stockdale, 2008^48^ | Fair | X | Ireland | 182 | Primiparous | 144 (100) | NA | N | NR (NR) | General, race/ethnicity NR
Su, 2007^49^ | Fair | | Singapore | 450 | Intending to breastfeed | 178 (39.6) | 56.4 | N | 450 (100) | Asian, predominantly low income
Wallace, 2006^50^ | Fair | | UK | 370 | Primiparous; intending to breastfeed; able to sit out of bed at time of first feed; no cesarean delivery | 370 (100) | NA | N | 370 (100) | NR
Wambach, 2011^51^ | Fair | X | US | 390 | 15–18 years old; primiparous; planning to keep newborn | 315 (100) | NA | N | NR (NR) | Adolescents (15–18 years), predominantly black (61.0%), low family income, in school (71.0%), living with family (74.0%)
Wen, 2011^52^ | Good | X | Australia | 667 | ≥16 years old; primiparous | 667 (100) | NA | N | NR (NR) | General, race/ethnicity NR
Wong, 2014^53^ | Good | X | Hong Kong | 469 | ≥18 years old; primiparous; intending to breastfeed; Hong Kong resident | 469 (100) | NA | N | 469 (100) | Asian, predominantly well-educated (54.4% postsecondary or university degree), high family income

* Among full sample not just multiparous.

† Intended to breastfeed for >12 weeks.

‡ Intended to exclusively breastfeed.

§ As described in study text.

¶ Race/ethnicity NR, assume 100% Hispanic.

** 76.3% intended to breastfeed >6 months.

Abbreviations: BF=breastfeed; BFHI=Baby-Friendly Hospital Initiative; BINGO=Best Infant Nutrition for Good Outcomes; BMI=body mass index; CG=control group; n=number; N=no; NA=not applicable; NR=not reported; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; rand=randomized; SES=socioeconomic status; UK=United Kingdom; US=United States; Y=yes.

Table 8 Included Interventions to Promote Breastfeeding

Interventions | Types | Number of Included Intervention Arms
Individual-level support and education | Professional support | 29
Individual-level support and education | Peer support | 9
Individual-level support and education | Formal or structured education | 11
System-level policies and practices | Policies, programs, and staff training | 3
System-level policies and practices | Other maternity care practices | 6

Appendix C Figure 1 shows an illustration of the dose of each intervention in terms of the timing, duration, and number of sessions within these five groups. For interventions that had components extending into the postpartum period, only women who continued breastfeeding continued to receive the intervention. This is in contrast to other health behavior interventions (e.g., physical activity interventions), in which participants receive the intervention regardless of their subsequent change in behavior.

#### Individual-Level Breastfeeding Support and Education

##### Professional Support

Twenty-nine intervention arms within 26 trials provided individual-level breastfeeding support by a clinician such as a physician, midwife, or lactation care provider (Appendix C Figure 1).^80-82,84,92,93,95,97,101,102,104,109,111,114,120,122-124,130-132,135,136,139,140^ All but three of the interventions had components that took place during the peripartum and/or postpartum periods. Only 11 of the 29 arms included prenatal contact. The intensity of the interventions ranged from one 30-minute in-hospital support session^109^ to an intervention where women received 20 weeks of support from both a physician or midwife and an IBCLC during seven in-person prenatal sessions, up to 12 postpartum phone calls, an optional postpartum home visit, and a nursing bra and breast pump.^92^ Most interventions were delivered by a physician, midwife, nurse, or lactation care provider. Three studies explicitly stated that the lactation care providers were IBCLCs^92,97,137^ and five studies did not report any licensing of the lactation care providers who had provided the intervention.^81,90,93,122,135^

##### Peer Support

Nine treatment arms were individual-level breastfeeding support interventions provided by peer counselors.^83,91,98-100,106,126,133,137^ Six of these interventions took place in the prenatal and postpartum periods, three of which also involved in-hospital sessions with peer counselors (Appendix C Figure 1);^83,91,98,126,133,137^ the other three studies were limited to one prenatal clinic visit,^106^ at least one postpartum home visit,^99^ and seven postpartum telephone calls.^100^ Two of the interventions were strictly limited to telephone support^100,133^ whereas the remaining seven included face-to-face contact with peer counselors. Five of the studies included planned or optional home visits by peer counselors, including one relatively intense study in the United States that included three prenatal home visits, daily in-hospital visits, and nine postpartum home visits.^91^ In all cases, peer counselors were recruited specifically for the study: they were chosen to represent the sample population (e.g., adolescents,^100^ WIC recipients^133^) and had previous breastfeeding experience. All but one study^99^ explicitly mentioned specialized training for peer counselors on breastfeeding and/or counseling techniques. Most of the training appeared to be relatively intense. For example, one study reported 8 weeks of peer counselor training using the WHO/UNICEF Breastfeeding Counseling Training Course. One study of adolescents used both a peer counselor (a trained teen mother) and a certified lactation care provider.^137^

##### Formal or Structured Education

We categorized as formal breastfeeding education 11 intervention arms within 10 trials.^79,90,103^, ^116,118,119,122,128,134,135^ All but one^116^ of the interventions took place outside the United States. Six of the arms included group education and the others provided one-on-one education, with or without a support person. Eight of the 11 interventions took place during the prenatal period only, whereas the others took place only during the peripartum stay or spanned prenatal and postpartum periods (Appendix C Figure 1). All but two interventions were a single educational session ranging from 15 minutes to 3 hours. The remaining two interventions consisted of two 60-minute prenatal group sessions^103^ and three 3-hour prenatal group sessions, of which only one focused on breastfeeding.^118^ Education sessions were provided by midwives, lactation care providers, or community educators. The content of most of the educational interventions centered on the benefits of breastfeeding, practical breastfeeding skills (e.g., attachment), and the management of common breastfeeding complications, and most of the interventions encouraged a support person to attend with the expectant mother. One intervention was a “coparenting” intervention in which elements were designed to help couples work cooperatively toward meeting their mutually-desired child health outcomes, including breastfeeding.^90^ Two interventions did not include face-to-face contact with an interventionist and instead consisted of educational videos that introduced the benefits of breastfeeding, demonstrated correct positioning, and explained breast care.^116,122^

#### System-Level Policies and Practices

##### Policies, Programs, and Staff Training

Three good-quality studies evaluated system-level policies on rates of breastfeeding.^107,108,110^ Two studies by the same research group compared the rates of breastfeeding before and after BFHI accreditation between mothers who gave birth in hospitals that became accredited during the study period and mothers who gave birth in matched non-BFHI facilities in the United States.^107,108^ The studies gathered information on the month and year of BFHI accreditation directly from Baby-Friendly USA, the accrediting body for the BFHI in the United States. The third study, in Scotland, implemented a local policy to standardize and increase the availability of breastfeeding support groups provided to pregnant women and mothers.^110^

##### Other Maternity Care Practices

The six remaining studies focused on system-level maternity care practices that included three trials focused on maintaining mother and baby contact (including skin-to-skin contact following delivery^96,105,129^) and three trials focused on delaying or restricting pacifier use.^112,115,117^ In the studies that evaluated skin-to-skin contact, babies were place naked against the mother's skin as soon as possible after birth or upon returning to their room following Cesarean delivery and continued until the baby showed signs of readiness to feed or the mother chose to end the contact. In the control groups for these studies, mother-infant contact was interrupted for bathing, weighing, and other newborn procedures, and the infant was wrapped in a towel and handed to a parent. Similar individual-level breastfeeding support was offered to both treatment groups. In the restricted pacifier studies, families were encouraged to avoid pacifier use until the infant's fifth week of life^112^ or until breastfeeding was well established^115,117^ and were instructed about alternative methods for soothing infants. In two of these studies, women in the control groups were given pacifiers and were instructed to use the pacifier as soon as possible or according to their preference.^112,115^ In the other study, women were not given pacifiers but no mention was made to avoid pacifier use.

#### Usual Care Control Groups

All of the studies included usual care control groups, although what constituted usual care was not fully described or was highly variable given the various settings, countries, and time frames in which the interventions took place (Appendix C Table 1). Five of the studies^91,98,103,115,134^ explicitly mentioned that the studies took place in BFHI-accredited facilities, two described their facilities as adopting most of the 10 steps but not yet accredited,^118,123^ and one described its facility as holding an “active certificate of intent to become baby-friendly.”^112^ Other studies simply stated that, given the study population's diversity, it was too difficult to describe a usual care “standard” regarding breastfeeding education and support.

A number of studies mentioned routine or mandatory prenatal education but none described the extent to which breastfeeding was covered as part of that education. Others explicitly stated that there was no routine prenatal education within the study facilities. For studies that described usual postpartum care, most included routine peripartum and/or postpartum contact with lactation care providers. This support, which was provided face to face or by telephone, was part of the routine services of the health system or was provided as an option for the mother (who had to initiate contact through a “warm-line” to the lactation care provider). Many of the non-U.S. studies included routine postpartum home visits as part of usual care.^81,83,103,118,123,126,132,139^ A few studies mentioned discharge materials routinely given to families, including videos or print materials on infant care and breastfeeding, manual breast pumps, lanolin cream, and a water bottle. Only one study^95^ explicitly stated that the hospital discharge bag included infant formula.

In all cases, mothers in both the intervention and control groups received usual care. The intervention components were either in addition to those usual care services or replaced specific pieces. For example, in the U.S. study by Chapman and colleagues,^98^ the peer counseling intervention replaced the optional peer counseling program that was available to control subjects.

### Quality of Included Studies

We rated 20 out of the 52 included studies as good quality and the remaining 32 as fair quality (Table 6). In general, the limitations for trials rated as fair quality included a lack of reporting details about randomization methods, including allocation concealment; small differences in baseline characteristics between intervention arms on variables that may relate to breastfeeding outcomes and were not accounted for in the analyses (such as intentions to breastfeed, parity, previous breastfeeding experience, percent delivering by Cesarean section, marital status, income level); a lack of blinding of outcome assessors; attrition greater than 10 percent but less than 35 percent; differential attrition between study arms; a lack of reporting on how missing data were handled or having completers-only analyses accompanied with high attrition; and problematic intervention fidelity and/or adherence to the intervention. In addition, while all studies relied on self-reported measures of breastfeeding and breastfeeding duration with or without verification from clinical records, the studies we rated as fair quality rarely noted the specific instruments, questions, or definitions used to measure breastfeeding, including whether the measure was based on a 24-hour recall or since birth. Studies that measured breastfeeding duration or time to weaning were especially prone to recall bias, and very few fair-quality studies described how observations were censored in the analyses.

## KQ 1 What Are the Effects of Prenatal, Peripartum, and Postpartum Individual- and Health Care System-Level Interventions to Promote and Support Breastfeeding on Short- and Long-Term Child and Maternal Health Outcomes?

### Overall Results

Six of the 52 included studies reported the effects of an individual-level breastfeeding intervention on infant health outcomes (the majority focusing on health care utilization as a proxy).^91,93,95,98,104,111^ In general, there was mixed evidence on the effectiveness of the interventions on gastrointestinal outcomes (two trials) and no evidence of a benefit on otitis media (one trial) or the number of health care visits for respiratory tract illnesses (one trial). Three out of four trials that reported rates of infant health care utilization found higher use among those in the usual care control groups than those who received intervention. None of these three trials, however, reported an effect of the intervention on the rates of breastfeeding. We did not identify any studies that reported the effects of a breastfeeding intervention on maternal health outcomes, such as postpartum weight loss and incidence of breast cancer.

### Detailed Results

Of the six trials that reported infant health outcomes, five were rated as fair quality and one^111^ as good quality. One trial was conducted in Canada^104^ and the remaining in the United States; all of the U.S. studies were among predominantly low-income Hispanic women. Four of the six trials assessed individual-level breastfeeding support interventions provided by clinicians.^93,95,104,111^ The other two trials assessed interventions provided by peer counselors (Table 7).^91,98^

Two studies of fair quality reported on infant gastrointestinal outcomes, with conflicting results.^91,93^ Anderson and colleagues reported that the risk of infants experiencing one or more diarrheal episodes during the 3-month followup period was more than 2-fold higher in the usual care group than in a peer counseling intervention group (RR, 2.15 [95% confidence interval (CI), 1.16 to 3.97]; n=182); this study also found lower rates of exclusive breastfeeding at both 2 and 3 months in the control group compared with the intervention group.^91^ Bonuck and colleagues (n=338), however, reported no significant differences in gastrointestinal illnesses in infants of women who attended a prenatal and postpartum support intervention (22.7%) and in infants in the usual care group (25.7%) at 52 weeks despite the intervention group breastfeeding for a statistically significant longer duration than the women in the control group.^93,94^

Bonuck and colleagues (2006) also reported infant outcomes for otitis media and respiratory tract illnesses for up to 52 weeks.^93,94^ In a priori analyses, infants in the usual care group who did not receive Medicaid had significantly more cases of otitis media (p≤0.03) than infants in the intervention group; there was no effect among infants who did receive Medicaid. Within this study, however, there was no statistically significant difference in the percent of otitis media cases (43.6% vs. 54.9%) or the number of health care visits for respiratory tract illnesses (76.7% vs. 83.4%) for intervention versus control participants.

Four studies reported outcomes on infant health care utilization, including pediatric visits, emergency room visits, and hospitalizations.^95,98,104,111^ Despite finding a statistically significantly higher rate of exclusive breastfeeding at 4 weeks between groups, the good-quality study by Hopkinson and colleagues found no significant difference in the number of infant visits to the pediatrician or emergency room at 4 weeks postpartum between women randomized to a lactation care provider-led postpartum breastfeeding support intervention (76.3% visited pediatrician, 8.9% visited emergency room; n=255) and those receiving usual care (82.1% visited pediatrician, 9.2% visited emergency room; n=267).^111^ Bunik reported that infants born to mothers assigned to a nurse-delivered brief telephone postpartum support intervention were less likely to have a sick visit by 4 weeks postpartum than were infants born to mothers in the usual care group (25% vs. 36%, respectively; p=0.05); however, there were no significant differences between treatment groups with respect to well-baby and sick care visits at 3 and 6 months postpartum or between any or exclusive breastfeeding at 1, 3, and 6 months.^95^ Gagnon observed that infant hospital admission for multiple conditions (including fever/viral episodes, jaundice, ear infection, and lethargy) during the first 8 weeks postpartum was more than 2-fold higher in the usual care group (7/254 [2.8%]) than in the intervention group receiving a postpartum in-home nursing visit and optional phone support (3/259 [1.2%]); however, there was no significant difference in the rate of any breastfeeding between groups at 2 weeks.^104^ Likewise, Chapman and colleagues reported that infants of mothers who received a breastfeeding peer counseling intervention were significantly less likely to be hospitalized during the first 3 and 6 months after birth after adjustment for maternal age, delivery mode, infant birth, previous breastfeeding experience, maternal pregnancy body mass index, and infant sex (6-month adjusted odds ratio [aOR], 0.24 [95% CI, 0.01 to 0.86]). There were no statistically significant differences, however, in the prevalence of otitis media, diarrhea, or emergency department visits between groups at 3 or 6 months. This study also did not find an effect on rates of any or exclusive breastfeeding beyond 2 weeks.^98^

## KQ 2 What Are the Effects of Prenatal, Peripartum, and Postpartum Individual- and Health Care System-Level Interventions to Promote and Support Breastfeeding on Initiation, Duration, and Exclusivity of Breastfeeding?

### Overall Results

All 52 included studies (N=66,757) reported a breastfeeding outcome. Individual-level support and education interventions provided by professionals or peers (43 trials; n=21,973) were associated with a statistically significant higher likelihood of any and exclusive breastfeeding for less than 3 months and at 3 to less than 6 months and for exclusive (but not any) breastfeeding at 6 months in pooled analyses (Table 9). There was no evidence of a relationship between individual-level support and education interventions and breastfeeding initiation. In addition, none of the three trials that reported breastfeeding rates at 1 year found a statistically significant difference between treatment groups. Results appeared consistent across various adult subgroups and specific intervention characteristics. The four trials that were limited to adolescents or young adults found higher rates of any or exclusive breastfeeding or a longer duration of breastfeeding among mothers receiving professional or peer support compared with those receiving usual care.

Table 9 Pooled Results of Individual-Level Breastfeeding Support and Education Interventions for Any and Exclusive Breastfeeding Among Adults

Breastfeeding Outcome | Time Point | k | n | RR (95% CI) | I^2^, %
Any | Initiation | 14 | 9428 | 1.00 (0.99 to 1.02) | 22.8
Any | <3 months | 26 | 11,588 | 1.07 (1.03 to 1.11) | 72.0
Any | 3 to <6 months | 23 | 8942 | 1.11 (1.04 to 1.18) | 46.5
Any | 6 months | 20 | 9715 | 1.07 (0.98 to 1.16) | 57.5
Any | 12 months | 3 | 1957 | Not pooled | Not pooled
Exclusive | <3 months | 22 | 8246 | 1.21 (1.11 to 1.33) | 52.4
Exclusive | 3 to <6 months | 18 | 7027 | 1.20 (1.05 to 1.38) | 44.6
Exclusive | 6 months | 17 | 7690 | 1.16 (1.02 to 1.32) | 14.3
Exclusive | 12 months | 0 | NA | NA | NA

Abbreviations: CI=confidence interval; k=number of studies; NA=not applicable; RR=risk ratio.

There was no consistent effect on the rate of any or exclusive breastfeeding from nine studies of system-level policy or maternity care practices. Among the three studies that evaluated the effect of a system-level policy on rates of breastfeeding, none found a statistically significant benefit of the policy on the rate of any or exclusive breastfeeding up to 4 to 8 weeks among all women. One large observational study (n=25,327) found a statistically significantly higher rate of breastfeeding initiation and exclusive breastfeeding at 1 month among women with a lower education but not among women overall or among those with higher education after implementation of the BFHI. Likewise, there was no clear benefit from establishing and maintaining mother and baby contact following delivery or restricted pacifier use on the rate of breastfeeding initiation or the continuation of any or exclusive breastfeeding based on six trials. These six trials had limited applicability to U.S. health care practices, and breastfeeding was a secondary outcome within many of these trials.

### Detailed Results Among Adults

#### Individual-Level Breastfeeding Education and Support

##### Breastfeeding Initiation

Fourteen trials reported the effects of a breastfeeding education or support intervention on the rate of breastfeeding initiation.^79,81,83,91,92,98,103,106,116,118,126,139,140^ All of the interventions had a prenatal component that was intended to increase the proportion of women starting to breastfeed compared with usual care. The breastfeeding initiation rate among women in the usual care control groups ranged from 53.1 percent in a trial conducted among women in Scotland^126^—among whom only slightly more than half (51.6%) intended to breastfeed—to 98.7 percent among a sample of women in the United States who intended to breastfeed (Table 10).^98^ Despite nearly all of the trials generally showing improved rates of breastfeeding initiation among mothers receiving the intervention compared with mothers receiving usual care, none of the individual trials found a statistically significant benefit. When all 14 trials were pooled, the results showed no association between receiving an individual-level breastfeeding prenatal intervention and breastfeeding initiation (RR, 1.00 [95% CI, 0.99 to 1.02]; I^2^=22.8%; n=9,428) (Figure 4). Although power could be an issue, the relatively high control group initiation rates and the small overall benefit suggested by the pooled results are consistent with ceiling effects for breastfeeding initiation in women similar to those selected for these interventions. In all but four of these trials,^81,116,118,126^ more than 80 percent of enrolled women intended to initiate breastfeeding (range, 51.6% to 100%).

Table 10 Results of Individual-Level Breastfeeding Support and Education Interventions on Breastfeeding Initiation, by Author

Author, Year | Group | Intervention Name | IG Event Rate, n/N (%) | CG Event Rate, n/N (%) | RR (95% CI)
Anderson, 2005^91^ | IG1 | Peer counseling | 55/63 (90.5) | 55/72 (76.4) | 1.14 (0.98 to 1.34)
Bonuck, 2014a (BINGO)^92^ | IG1 | Lactation support and brief education | 218/226 (96.5) | 65/73 (89.0) | 1.08 (1.00 to 1.18)
Bonuck, 2014a (BINGO)^92^ | IG2 | Lactation support | 70/73 (95.9) | 65/73 (89.0) | 1.08 (0.98 to 1.18)
Bonuck, 2014a (BINGO)^92^ | IG3 | Brief education | 207/223 (92.8) | 65/73 (89.0) | 1.04 (0.95 to 1.14)
Bonuck, 2014b (PAIRINGS)^92^ | IG1 | Lactation support and brief education | 122/124 (98.4) | 123/130 (94.6) | 1.04 (0.99 to 1.09)
Chapman, 2013^98^ | IG1 | Peer counseling | 75/76 (98.7) | 77/78 (98.7) | 1.00 (0.96 to 1.04)
Forster, 2004^103^ | IG1 | Group education (attitude modification) | 291/308 (94.5) | 297/310 (95.8) | 0.99 (0.95 to 1.02)
Forster, 2004^103^ | IG2 | Group education (practical skills training) | 296/306 (96.7) | 297/310 (95.8) | 1.01 (0.98 to 1.04)
Fu, 2014^82^ | IG2 | In-hospital support | 190/190 (100) | 256/260 (98.5) | 1.01 (1.00 to 1.03)
Graffy, 2004^106^ | IG1 | Peer counseling | 320/336 (95.2) | 324/336 (96.4) | 0.99 (0.96 to 1.02)
Jolly, 2012^83^ | IG1 | Peer counseling | 747/1083 (69.0) | 896/1315 (68.1) | 1.01 (0.96 to 1.07)
Kellams, 2015 ^116^ | IG1 | Breastfeeding video | 174/249 (69.9) | 172/248 (69.4) | 1.01 (0.90 to 1.13)
Kools, 2005^81^ | IG1 | Home breastfeeding support | 254/371 (68.5) | 238/330 (72.1) | 0.95 (0.86 to 1.04)
Kronborg, 2012^118^ | IG1 | Group education | 533/552 (96.6) | 529/538 (98.3) | 0.98 (0.96 to 1.00)
Lavender, 2005^79^ | IG1 | Group education | 515/644 (80.3) | 463/605 (76.5) | 1.04 (0.98 to 1.11)
Muirhead, 2006^126^ | IG1 | Peer counseling | 61/112 (54.5) | 60/113 (53.1) | 1.03 (0.80 to 1.31)
Su, 2007^135^ | IG2 | Individual education | 132/138 (95.7) | 131/138 (94.9) | 1.01 (0.96 to 1.06)
Wen, 2011^139^ | IG1 | Home breastfeeding support | 312/337 (92.8) | 304/330 (92.2) | 1.00 (0.96 to 1.05)
Wong, 2014^140^ | IG1 | Lactation support | 220/233 (94.4) | 218/236 (92.4) | 1.02 (0.97 to 1.07)

Abbreviations: CG=control group; IG=intervention group; n=number; N=number analyzed; RR=relative risk.

Figure 4 Pooled Analysis of Randomized, Controlled Trials for Any Breastfeeding Initiation

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; BF=breastfeeding; CG=control group; Ed=education; IG=intervention group; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; NR=not reported; Peer=peer support; Prof=professional support; RR=risk ratio; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for any breastfeeding initiation among adults.

##### Breastfeeding for Less Than 3 Months

Our meta-analysis combining the 26 trials that reported the prevalence of any breastfeeding for less than 3 months (i.e., from 2 weeks through 11 weeks) among adults found a statistically significant pooled relative risk for mothers assigned to a breastfeeding support or education intervention compared with women in the usual care control groups (1.07 [95% CI, 1.03 to 1.11]; I^2^=72.0%; n=11,588) (Figure 5). The range in the absolute difference in rates of any breastfeeding was 6.4 percent in favor of the control group to 17.5 percent in favor of the intervention group. Examined individually, only five of the 26 trials showed a statistically significant effect on the prevalence of any breastfeeding for less than 3 months, with an increased likelihood of breastfeeding in favor of the intervention groups (Appendix C Table 2).^92,93,133,135^ Nineteen of these 26 trials plus an additional three studies^91,104,134^ also reported the proportion of mothers exclusively breastfeeding for less than 3 months. All but two of these 22 trials suggested a greater benefit of the intervention over usual care on exclusive breastfeeding up to 3 months, but statistical significance was not reached in all trials. The pooled RR demonstrated a slightly stronger relationship between individual-level support interventions versus usual care in the rate of exclusive breastfeeding for less than 3 months (RR, 1.21 [95% CI, 1.11 to 1.33]; I^2^=52.4%; k=22; n=8,246) (Figure 6) than that seen for any breastfeeding; however, the same set of trials was not represented in both outcomes. Among these trials, the absolute difference in the rate of exclusive breastfeeding between groups ranged from -2.5 percentage points (in favor of the control group)^83^ to 22.4 percentage points in favor of the intervention group.^91^

Figure 5 Pooled Analysis of Randomized, Controlled Trials for Any Breastfeeding at Less Than 3 Months

Significant difference in risk ratios between groups (b=1.11, SE=0.03, p=0.001 [95% CI, 1.05 to 1.17]).

Intervention timing: 1=prenatal, 2=peripartum, 3=postpartum; duration is presented in weeks.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; CG=control group; Ed=education; IG=intervention group; int=intervention; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; Peer=peer support; Prof=professional support; RR=risk ratio; SE=standard error; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for any breastfeeding at less than 3 months among adults, sorted by the timing of the intervention.

Figure 6 Pooled Analysis of Randomized, Controlled Trials for Exclusive Breastfeeding at Less Than 3 Months

No significant difference in risk ratios between groups (b=1.08, SE=0.11, p=0.424 [95% CI, 0.88 to 1.34]).

Intervention timing: 1=prenatal, 2=peripartum, 3=postpartum; duration is presented in weeks.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; CG=control group; Ed=education; IG=intervention group; int=intervention; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; Peer=peer support; Prof=professional support; RR=risk ratio; SE=standard error; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for exclusive breastfeeding at less than 3 months among adults, sorted by the number of time periods during which the intervention took place.

The funnel plot for exclusive breastfeeding for less than 3 months revealed asymmetric patterns and the results of the Peter's test for small study effects was statistically significant (p=0.047), so we cannot exclude potential publication bias. A sensitivity analysis excluding the five studies that had total sample sizes of less than 200^91,98,124,128,134^ resulted in a slightly attenuated effect with greater precision while reducing statistical heterogeneity (RR, 1.17 [95% CI, 1.08 to 1.26]; I^2^=36.6%; k=17; n=7,508). Thus, the effect size for exclusive breastfeeding at 3 months may be slightly overestimated due to small study effects, including potential publication bias.

Due to a lack of reporting of within-group event rates, we did not include one study in our meta-analysis of exclusive breastfeeding for less than 3 months or 3 to less than 6 months (see paragraph below).^97^ However, the results of this trial were generally consistent with the pooled results, although with higher point estimates. The fair-quality study by Carlsen and colleagues in Denmark randomized 226 obese women who were already breastfeeding at the start of the intervention to a 6-month postpartum telephone support intervention provided by an IBCLC or to usual postpartum care. Obese women were the target of the intervention given the difficulties they often experience in initiating and continuing breastfeeding. The intervention resulted in statistically significantly higher odds of exclusive breastfeeding at 1, 2, 4, and 12 weeks after birth after adjustment for prepregnancy body mass index, gestational weight gain, parity, birth weight, gestational age, and infant sex (Appendix C Table 2). For instance, at 4 weeks, the odds of exclusive breastfeeding was 3 times higher among women receiving postpartum telephone support than among women in the control group (aOR, 2.99 [95% CI, 1.61 to 5.50]).

##### Breastfeeding at 3 to Less Than 6 Months

Slightly fewer studies reported the proportion of adult women performing any (k=23) or exclusive (k=18) breastfeeding at 3 to less than 6 months (12 weeks through 23 weeks) (Appendix C Table 2). Overall, individual-level breastfeeding support and education interventions were statistically significantly related to both any and exclusive breastfeeding at 3 to less than 6 months in pooled analyses (Figure 7 and Figure 8, respectively). Among 23 trials with 8,942 women reporting any breastfeeding at 3 to less than 6 months, the pooled RR was 1.11 (95% CI, 1.04 to 1.18), with evidence of moderate heterogeneity (I^2^=46.5%). The control group breastfeeding rate was highly variable (17.7% to 88.6%), as was the intervention group rate (23.2% to 96.2%). The range in absolute difference was -5.8 to 18.4 percent. These findings appear to be partly due to the breastfeeding rates at 12 weeks usually being higher than those reported at 16 weeks, with a few exceptions. The study by Elliott-Rudder in Australia that reported 88.6 percent of women in the usual care control group still breastfeeding at 16 weeks (4 months) was unique in that only women who were successfully breastfeeding at 8 weeks postpartum were included; intervention participants took part in one structured conversation with a primary care nurse when they brought their infant in for scheduled immunizations at ages 2, 4, or 6 months (Appendix C Figure 1).^80^ Likewise, the study by Abbass-Dick in Canada included only women who were exclusively breastfeeding in the hospital and intended to breastfeed for more than 12 weeks. This study reported any and exclusive breastfeeding rates among the control group participants to be 87.6 and 60.0 percent, respectively.^90^

Figure 7 Pooled Analysis of Any Breastfeeding at 3 to Less Than 6 Months

Significant difference in risk ratios between groups (b=1.14, SE=0.06, p=0.026 [95% CI, 1.02 to 1.29]).

Intervention timing: 1=prenatal, 2=peripartum, 3=postpartum; duration is presented in weeks.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; CG=control group; Ed=education; IG=intervention group; int=intervention; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; Peer=peer support; Prof=professional support; RR=risk ratio; SE=standard error; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for any breastfeeding at 3 to 6 months among adults, sorted by the number of time periods during which the intervention took place.

Figure 8 Pooled Analysis of Randomized, Controlled Trials for Exclusive Breastfeeding at 3 to Less Than 6 Months

No significant difference in risk ratios between groups (b=1.05, SE=0.17, p=0.761 [95% CI, 0.74 to 1.50]).

Intervention timing: 1=prenatal, 2=peripartum, 3=postpartum; duration is presented in weeks.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; CG=control group; Ed=education; IG=intervention group; int=intervention; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; Peer=peer support; Prof=professional support; RR=risk ratio; SE=standard error; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for exclusive breastfeeding at 3 to 6 months among adults, sorted by the number of time periods during which the intervention took place.

The pooled point estimate for exclusive breastfeeding between 3 and less than 6 months also suggested a statistically significant benefit of the intervention compared with usual care (RR, 1.20 [95% CI, 1.05 to 1.38]; I^2^=44.6%; k=18; n=7,027; range in absolute difference, -4.6% to 19.2%) (Figure 8). When examined individually, one good-quality study in the United States (Bonuck, 2014b [PAIRINGS])^92^ and four fair-quality studies (including two conducted in Singapore) demonstrated a statistically significant effect of individual-level professional or peer support interventions on exclusive breastfeeding at 12 weeks. Funnel plots for any or exclusive breastfeeding at 3 to less than 6 months did not suggest the presence of small study effects.

##### Breastfeeding at 6 Months

Among adults, 20 trials (n=9,715) reported the proportion of women performing any breastfeeding at 6 months (24 or 26 weeks). When pooled, the association was not statistically significant but the CI did not rule out potential benefit (RR, 1.07 [95% CI, 0.98 to 1.16]; I^2^=57.5%) (Figure 9). The forest plot shows a lack of consistent effects across the individual trials but some suggestion of a benefit of up to a 2-fold increase in any breastfeeding among women exposed to a professional support intervention compared with usual care (e.g., Bonuck, 2014b [PAIRINGS]^92^ and Labarere, 2005^120^) and others suggesting a decreased probability of any breastfeeding, although not ruling out benefit (e.g., Chapman, 2013).^98^

Figure 9 Pooled Analysis of Randomized, Controlled Trials for Any Breastfeeding at 6 Months

No test for subgroup differences performed given lack of statistical significance in overall effect.

Intervention timing: 1=prenatal, 2=peripartum, 3=postpartum; duration is presented in weeks.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; CG=control group; Ed=education; IG=intervention group; int=intervention; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; Peer=peer support; Prof=professional support; RR=risk ratio; SE=standard error; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for any breastfeeding at 6 months among adults, sorted by the timing of the intervention.

In contrast, the pooled RR demonstrated a positive association between individual-level support or education interventions and exclusive breastfeeding at 6 months, although the CI only narrowly excluded 1.0 (RR, 1.16 [95% CI, 1.02 to 1.32]; I^2^=14.3%; k=17; n=7,690) (Figure 10). Absolute differences in the rates of exclusive breastfeeding at 6 months ranged from 2.9 percentage points in favor of the control group (5.2% vs. 8.1%) to 21.0 percentage points (47.7% vs. 26.1%). The range of exclusive breastfeeding rates at 6 months among control group participants was 0 percent^98^ to 42.5 percent,^103^ the latter in a sample of women from Australia. The funnel plot for exclusive breastfeeding at 6 months presented asymmetric patterns and the results of the Peter's test for small study effects was statistically significant (p=0.015). After three studies with fewer than 100 women per arm^84,98,131^ were removed from the meta-analysis, the pooled RR was slightly attenuated and the CI included 1.0 (RR, 1.09 [95% CI, 0.99 to 1.21]; I^2^=0%; k=14; n=7,409). Wide CIs suggested power was an issue and indicated the potential for benefit was not eliminated.

Figure 10 Pooled Analysis of Randomized, Controlled Trials for Exclusive Breastfeeding at 6 Months

No significant difference in risk ratios between groups (b=1.11, SE=0.17, p=0.497 [95% CI, 0.81 to 1.53]).

Intervention timing: 1=prenatal, 2=peripartum, 3=postpartum; duration is presented in weeks.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; CG=control group; Ed=education; IG=intervention group; int=intervention; n=number; N=number analyzed; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; Peer=peer support; Prof=professional support; RR=risk ratio; SE=standard error; UK=United Kingdom; US=United States.

This figure is a forest plot of individual-level breastfeeding support and education interventions compared with usual care for exclusive breastfeeding at 6 months among adults, sorted by the timing of the intervention.

Only four of the trials that reported 6-month outcomes had intervention components that extended up to 6 months postpartum.^80,93,99,139^ There did not seem to be a pattern, however, between the duration of the intervention and the effects seen at 6 months. For instance, the good-quality trial by Labarere and colleagues in France consisted of one lactation-focused outpatient visit with the infant's primary care physician at 2 weeks postpartum, yet reported 39.3 and 26.3 percent of mothers in the intervention versus usual care groups, respectively, still breastfeeding at 6 months (RR, 1.49 [95% CI, 1.02 to 2.19]).^120^

##### Breastfeeding at 12 Months

Only three of the trials reported the prevalence of any breastfeeding among intervention and control group participants at 12 months (Appendix C Table 2).^79,93,139^ None found a statistically significant effect of the intervention at 12 months, and the data were too sparse and heterogeneous to pool. The reported breastfeeding rates at 12 months within these studies were quite low (9.3% to 21.0%) and clearly below the U.S. national average of 29.2 percent.^46^ Thus, these populations may represent particularly challenging groups for achieving long-term breastfeeding continuation. Among the 52 included studies, the two studies with the longest interventions were conducted by Bonuck and colleagues^93^ and Wen and colleagues,^139^ who reported breastfeeding at 12 months (Appendix C Figure 1). The lactation support intervention by Bonuck and colleagues in the United States spanned approximately 68 weeks; it began in the second trimester of pregnancy and provided optional telephone support to breastfeeding mothers for up to 1 year.^93,94^ In that study of predominantly low-income Hispanic and black women, 18.3 percent of intervention mothers and 15.2 percent of control mothers reported still breastfeeding their infants at 1 year (RR, 1.21 [95% CI, 0.63 to 2.32]). Similarly, the good-quality study by Wen and colleagues in Australia found no significant effect on the rates of any breastfeeding at 1 year among mothers receiving a home visit intervention versus usual care (21.0% vs. 14.9%, respectively; RR, 1.39 [95% CI, 0.96 to 2.01]) despite receiving up to five postpartum home visits lasting 1 to 2 hours for up to a year after birth.^139^ Very wide CIs associated within the individual studies may reflect power issues and cannot rule out potential benefits that could be clinically meaningful. On the other hand, one of the least intense studies by Lavender and colleagues in the United Kingdom (n=1,249) also found no effect of one 2.5-hour prenatal group education session compared with usual care on rates of any breastfeeding at 1 year (9.3% vs. 10.1%); in that study, power was less likely to be an issue.^79^

##### Absolute Duration of Breastfeeding

Twelve individual-level intervention trials among adults reported continuous measures of the duration of any and/or exclusive breastfeeding or time-to-event data (Table 11).^84,97,103,106,114,118^, ^119,126,128,131,139,140^ In these studies, breastfeeding duration was equal to the infant age when the mother completely stopped breastfeeding or stopped exclusively breastfeeding. All 12 studies reported that the intervention group participants breastfed longer or exclusively breastfed longer than those in the control groups; however, the results were only statistically significant in four trials.^84,97,119,139^

Table 11 Results of Individual-Level Breastfeeding Support and Education Interventions on Any and Exclusive Breastfeeding Duration Among Adults

Study, Year Country | Weeks of Followup | Intervention | Group | N | Median (IQR) | Unit | P-Value for Between-Group Difference
Any breastfeeding duration
Carlsen, 2013^97^ Denmark | 26 | Telephone support | IG1 | 105 | 184.0 (92.0 to 185.0) | days | 0.002
Carlsen, 2013^97^ Denmark | 26 | Telephone support | CG | 102 | 108.0 (16.0 to 185.0) | days | 0.002
Forster, 2004^103^ Australia | 26 | Group education (attitude modification) | IG1 | 293 | 17 (10.2)^*^ | weeks | 0.28^†^
Forster, 2004^103^ Australia | 26 | Group education (practical skills) | IG2 | 297 | 19 (9.3)^*^ | weeks | 0.28^†^
Forster, 2004^103^ Australia | 26 | Group education (practical skills) | CG | 299 | 18 (9.7)^*^ | weeks | 0.28^†^
Graffy, 2004^106^ UK | 16 | Peer counseling | IG1 | 336 | 110 | days | 0.445
Graffy, 2004^106^ UK | 16 | Peer counseling | CG | 336 | 96 | days | 0.445
Howell, 2014^114^ US | 26 | Brief education and counseling | IG1 | 270 | 12.0 | weeks | 0.019
Howell, 2014^114^ US | 26 | Brief education and counseling | CG | 270 | 6.5 | weeks | 0.019
Kronborg, 2012^118^ Denmark | 52 | Group education | IG1 | NR | NR | NR | NS^‡^
Kronborg, 2012^118^ Denmark | 52 | Group education | CG | NR | NR | NR | NS^‡^
Labarere, 2005^120^ France | 26 | Lactation support | IG1 | 112 | 18 | weeks | 0.03
Labarere, 2005^120^ France | 26 | Lactation support | CG | 114 | 13 | weeks | 0.03
Muirhead, 2006^126^ Scotland | 16 | Peer counseling | IG1 | 61 | 72 (6 to 138)^§^ | days | 0.4
Muirhead, 2006^126^ Scotland | 16 | Peer counseling | CG | 60 | 56 (22 to 90)^§^ | days | 0.4
Noel-Weiss, 2006^128^ Canada | 8 | Group education | IG1 | 47 | 50.4 (14.2)^*^ | days | 0.875
Noel-Weiss, 2006^128^ Canada | 8 | Group education | CG | 45 | 49.9 (14.5)^*^ | days | 0.875
Paul, 2012^130^ US | 26 | Lactation support | IG1 | NR | NR | NR | 0.29
Paul, 2012^130^ US | 26 | Lactation support | CG | NR | NR | NR | 0.29
Pollard, 2011^131^ US | 24 | Self-monitoring | IG1 | 41 | 13.8 | weeks | 0.2387
Pollard, 2011^131^ US | 24 | Self-monitoring | CG | 43 | 12.1 | weeks | 0.2387
Wen, 2011^139^ Australia | 52 | Home breastfeeding support | IG1 | 268 | 17 (13.9 to 20.4)^§^ | weeks | 0.03
Wen, 2011^139^ Australia | 52 | Home breastfeeding support | CG | 259 | 13 (10.1 to 15.6)^§^ | weeks | 0.03
Wong, 2014^140^ Hong Kong | 26 | Lactation support | IG1 | NR | NR | weeks | NS^‡^
Wong, 2014^140^ Hong Kong | 26 | Lactation support | CG | NR | NR | weeks | NS^‡^
Exclusive breastfeeding duration
Carlsen, 2013^97^ Denmark | 26 | Telephone support | IG1 | 105 | 120 (14 to 142) | days | 0.032
Carlsen, 2013^97^ Denmark | 26 | Telephone support | CG | 102 | 41 (3 to 133) | days | 0.032
Gijsbers, 2006^84^ Netherlands | 26 | Lactation support | IG1 | NR | NR | NR | 0.05^¶^
Gijsbers, 2006^84^ Netherlands | 26 | Lactation support | CG | NR | NR | NR | 0.05^¶^
Kronborg, 2012^118^ Denmark | 52 | Group education | IG1 | NR | NR | NR | NS^‡^
Kronborg, 2012^118^ Denmark | 52 | Group education | CG | NR | NR | NR | NS^‡^
Wong, 2014^140^ Hong Kong | 26 | Lactation support | IG1 | NR | NR | NR | NS^‡^
Wong, 2014^140^ Hong Kong | 26 | Lactation support | CG | NR | NR | NR | NS^‡^

* Mean (SD).

† For test of difference in duration between IG1, IG2, and CG. IG2 was also a group education intervention focused on practical skills training.

‡ Not statistically significant according to hazards ratio, p-value not reported.

§ 95% confidence interval.

¶ Adjusted for maternal age, education level, and breastfeeding experience.

Abbreviations: BINGO=Best Infant Nutrition for Good Outcomes; IG=intervention group; CG=control group; IQR=interquartile range; NR=not reported; NS=not significant; PAIRINGS=Provider Approaches to Improved Rates of Infant Nutrition and Growth Study; SD=standard deviation

##### Differences in Population Subgroups

We explored potential differences in the effects of the interventions as they related to specific settings and population characteristics. Specifically, we examined possible effect modification by country (United States vs. other), breastfeeding status at baseline (whether the trial only included women who had already attempted or established breastfeeding), intention to breastfeed, and previous breastfeeding experience. Our subgroup analyses and meta-regression models did not reveal any clear differences in the rates of any or exclusive breastfeeding at any time point by these study characteristics. Demographic variables such as race/ethnicity and socioeconomic status were too sparsely reported to examine possible differential effects. We report the results of four trials among adolescents and young adults below, which generally revealed effects consistent with those among adults.

We included seven trials that provided direct comparisons of the effect of the interventions among different population subgroups.^81,94,95,126,130,133,136^ Within these seven trials, differences in the following subgroups as they related to the mother were examined: age, education, insurance status, country of origin (foreign-born or U.S. born), primary language spoken (Spanish or English), delivery type, parity, prior breastfeeding experience, and breastfeeding intentions. The only significant differences in the intervention effect by subgroup were for maternal country of origin and primary language spoken, both in studies conducted in the United States.^94,133^ In the study by Bonuck and colleagues, U.S.-born control group participants had the lowest breastfeeding intensity compared with U.S.-born intervention participants or all foreign-born women at 13 and 52 weeks.^94^ Reeder and colleagues found a significant effect of the intervention on any breastfeeding among Spanish-speaking women at 4, 12, and 26 weeks but among English-speaking women only at 4 weeks. This study, however, did not report a formal test of interaction by language group.^133^ Two studies examined differential effects of the intervention by breastfeeding intention and found conflicting results.^81,95^ Bunik found that women who intended to exclusively breastfeed in the intervention group were more likely to breastfeed at 1, 3, and 6 months than women who planned to offer formula and breast milk. No significant differences were seen in the control group due to breastfeeding intention.^95^ Kools reported no interaction of the effects of the intervention by maternal age, maternal education, previous breastfeeding experience, or breastfeeding intentions.^81^ Thus, within-study examination of effect modification by subpopulation was inconclusive.

##### Common Elements of Efficacious Interventions

We also examined a number of specific intervention characteristics to see if they appeared to be associated with effect size, including intervention type (education, professional support, or peer support), intervention timing (prenatal, peripartum, postpartum, or a combination), intervention duration, number of intervention sessions, and whether the intervention included any in-person contact with the provider or telephone support. On the basis of our preliminary assessment, we used stratified analyses and meta-regression to formally examine possible effect modification by intervention characteristics.

We found some evidence of a differential effect of individual-level interventions on the rates of any breastfeeding (but not exclusive breastfeeding) based on the time periods in which the interventions were delivered and the total duration of the intervention. Interventions delivered over a combination of time points (e.g., prenatal and postpartum [shown as “1, 3” within the “Intervention Timing” column in the forest plots]) showed higher relative effects on any breastfeeding than those delivered at one time point only (e.g., postpartum [shown as “3” within the “Intervention Timing” column in the forest plots]). For instance, the pooled RR for interventions delivered at more than one time point showed a statistically significantly association with any breastfeeding for less than 3 months (RR, 1.14 [95% CI, 1.08 to 1.19]), whereas those delivered at one time point only (e.g., postpartum) did not show a statistically significant relationship (RR, 1.02 [95% CI, 0.99 to 1.06]; test for subgroup difference, p=0.001) (Figure 5). Likewise, interventions that were longer in duration (≥4 weeks) were statistically significantly related to any breastfeeding for less than 3 months and 3 to less than 6 months in pooled analyses, whereas interventions that were less than 4 weeks in duration were not related (p<0.05). These two intervention characteristics—timing of the intervention and total duration of the intervention—were closely related. In most, but not all cases, interventions that were delivered for 4 or more weeks also spanned more than one time period (e.g., prenatal and postpartum or prenatal, peripartum, and postpartum), so it is difficult to disentangle which concept (longer duration or multiple time periods) is driving the difference.

There was no evidence of effect modification based on the specific type of intervention (professional support, peer support, or education), number of sessions, presence of face-to-face contact, or presence of telephone support.

We included five studies that had more than one active intervention arm that provided direct comparisons between the arms.^82,92,103,122,135^ There were no statistically significant differences in the rates of any or exclusive breastfeeding between the active intervention arms when comparing in-hospital support versus postpartum telephone counseling,^82^ one prenatal education session with a lactation care provider versus a prenatal video and booklet,^122^ or group education focused on attitude modification versus group education focused on practical skills training.^103^ All of these comparisons, while direct, could have been limited by a lack of power. Bonuck and colleagues found some evidence of stronger effects on the prevalence and intensity of breastfeeding at 3 months among women receiving brief prenatal education plus peripartum and postpartum lactation counseling compared with women receiving only brief education or lactation counseling. For instance, there was a statistically significant difference between the four groups, with 56.2, 50.7, 44.5, and 37.8 percent of the lactation support plus brief education, lactation support only, brief education only, and usual care groups, respectively, reporting any breastfeeding at 3 months (p=0.02). There were no other differences by group at other time points within this study.^92^ The study by Su and colleague in Singapore similarly reported an increased relative effect of an intervention consisting of peripartum and postpartum lactation support versus a brief prenatal intervention for any breastfeeding at 6 weeks (RR, 1.16 [95% CI, 1.02 to 1.31]) but found no other differences between the two intervention arms for any or exclusive breastfeeding at any other time points.^135^ The indirect and direct evidence, while not conclusive, suggests that multiple time points may be important for short-term breastfeeding outcomes.

#### System-Level Policies and Practices

##### Policies, Programs, and Staff Training

We included three good-quality studies that evaluated the impact of system-level changes on rates of breastfeeding (Table 6; Table 12).^107,108,110^ Two studies by the same Hawkins group compared the rates of breastfeeding initiation and continuation of any or exclusive breastfeeding for 4 or more weeks before and after BFHI accreditation between mothers who gave birth in hospitals that became accredited during the study period and mothers who gave birth in matched non-BFHI facilities in the United States.^107,108^ First, Hawkins and colleagues (2014a) included 11,723 mothers who gave birth within 13 hospitals that received accreditation prior to 1999 or became BFHI accredited during 1999 through 2009 and 13,604 mothers from 19 matched non-BFHI birth facilities across five states.^107^ Difference-of-differences analysis found that BFHI accreditation did not increase rates of breastfeeding initiation or any or exclusive breastfeeding among all women but benefited mothers with lower education (≤12 years of education) in a priori subgroup analyses (Table 12). Breastfeeding initiation increased by 3.8 percentage points among mothers with lower education who delivered in BFHI facilities (adjusted coefficient, 0.038 [95% CI, 0.00 to 0.08]; p=0.05) but not among all mothers or mothers with higher education. BFHI accreditation was also associated with increased rates of exclusive breastfeeding for 4 or more weeks by 4.5 percentage points among mothers with lower education who delivered in BFHI facilities (adjusted coefficient, 0.045 [95% CI, 0.01 to 0.08]), but there was no effect on exclusive breastfeeding overall or among those with higher education. There was no difference in the rates of any breastfeeding between groups by education subgroup or overall. ^107^

Table 12 Characteristics and Results of System-Level Policy Interventions

Study, Year | Study Design | Setting | Comparison | Breastfeeding Outcome | Population^*^ | N | Effect Estimate^†^
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Initiation | All women | 25,327 | 0.024 (95% CI, 0.00 to 0.05); p=0.09
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Initiation | Low education | 10,978 | 0.038 (95% CI, 0.00 to 0.08); p=0.05
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Initiation | High education | 13,718 | 0.002 (95% CI, -0.04 to 0.05); p=0.90
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Any ≥4 weeks | All women | 24,776 | 0.006 (95% CI, -0.01 to 0.03); p=0.60
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Any ≥4 weeks | Low education | 10,749 | 0.027 (95% CI, -0.02 to 0.07); p=0.30
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Any ≥4 weeks | High education | 13,418 | -0.028 (95% CI, -0.06 to 0.00); p=0.06
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Exclusive ≥4 weeks | All women | 24,570 | 0.012 (95% CI, -0.01 to 0.03); p=0.30
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Exclusive ≥4 weeks | Low education | 10,606 | 0.045 (95% CI, 0.01 to 0.08); p=0.02
Hawkins, 2014a^107^ | 11-year longitudinal study | 32 hospitals within 5 US states | BFHI accreditation before or during study period vs. non-BFHI accreditation | Exclusive ≥4 weeks | High education | 13,964 | -0.023 (95% CI, -0.05 to 0.01); p=0.10
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Initiation | All women | 1,975 | 0.070 (95% CI, -0.04 to 0.18); p=0.20
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Initiation | Low education | 821 | 0.093 (95% CI, -0.06 to 0.24); p=0.2
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Initiation | High education | 1,153 | 0.048 (95% CI, -0.07 to 0.17); p=0.4
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Any ≥4 weeks | All women | 1,938 | 0.068 (95% CI, -0.02 to 0.16); p=0.10
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Any ≥4 weeks | Low education | 807 | 0.099 (95% CI, -0.11 to 0.30); p=0.30
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Any ≥4 weeks | High education | 1,130 | 0.013 (95% CI, -0.10 to 0.12); p=0.80
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Exclusive ≥4 weeks | All women | 1,951 | 0.025 (95% CI, -0.07 to 0.12); p=0.60
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Exclusive ≥4 weeks | Low education | 812 | 0.054 (95% CI, -0.09 to 0.20); p=0.40
Hawkins, 2014b^108^ | 4-year longitudinal study | 10 hospitals within 1 US state | BFHI accreditation before or during study period vs. non-BFHI accreditation | Exclusive ≥4 weeks | High education | 1,138 | -0.019 (95% CI, -0.20 to 0.16); p=0.80
Hoddinott, 2009^110^ Breastfeeding in Groups (BIG) trial | Cluster RCT | 14 localities of general practices in Scotland | Implementation of a breastfeeding support group policy vs. usual care | Any at 6–8 weeks | All women | 17,482 | Mean (SD) breastfeeding rate: IG: 0.26 (SD, 0.03) CG: 0.30 (SD, 0.07) Mean difference: -0.017^‡^ (95% CI, -0.036 to 0.002); p=0.08

* Low education: ≤12 years of education; high education: ≥13 years of education.

† Regression coefficient with model including birth facility as a fixed effect and an interaction between year and whether a birth facility ever received BFHI accreditation.

‡ Mean difference between groups postintervention adjusted for preintervention rate.

Abbreviations: BFHI=Baby-Friendly Hospital Initiative; IG=intervention group; CG=control group; CI=confidence interval; N=number; RCT=randomized, controlled trial; SD=standard deviation; US=United States.

Similarly, the second good-quality study by Hawkins and colleagues (2014b) compared rates of breastfeeding among 915 mothers who gave birth in four hospitals that were BFHI accredited or became accredited and 1,099 mothers from six matched non-BFHI–accredited facilities in Maine.^108^ Results showed that there was no effect of BFHI status on the rates of breastfeeding initiation, any breastfeeding, or exclusive breastfeeding, either overall or stratified by maternal education (Table 12). In this study, mothers giving birth within BFHI-accredited facilities were more likely to report experiencing seven of the 10 BFHI practices than were women delivering at a non-BFHI–accredited facility (34.6% vs. 27.1%); however, compliance with the individual steps was relatively low in general (ranging from 57.2% to 96.0%) within the accredited facilities, and only one step (step 3: hospital staff gave information about breastfeeding) significantly increased after BFHI accreditation (p=0.01). The authors speculated that the lack of effect by accreditation status suggests that it may be the number of or specific hospital practices supporting breastfeeding rather than BFHI accreditation itself that impacts rates of breastfeeding.^108^

The third good-quality study, conducted in Scotland, used a cluster RCT to compare the rates of breastfeeding at 6 to 8 weeks postpartum before and after implementation of a policy for providing breastfeeding support groups for pregnant women (prenatal) and breastfeeding mothers (postpartum) among seven intervention health localities (n=8,991) and seven control localities (n=8,491) implementing usual care.^110^ As part of the policy, intervention localities were asked to at least double their number of breastfeeding support groups, set up a minimum of two new groups, and ensure that all main population centers had access to a breastfeeding group. The format and content of the support groups were intended to be standardized across groups and include weekly group meetings, women only, a health professional group facilitator, and pregnant or breastfeeding women; allow at least half of the meeting time to be social and interactive; and create a woman-centered approach to the structure and content of the group sessions based on the women's needs. Implementation of the policy was high; intervention localities increased the number of breastfeeding groups from 10 to 27 groups after 2 years, whereas the number of breastfeeding groups in control localities was the same. The effect of the policy on rates of breastfeeding was not notable, however. After adjustment for preintervention breastfeeding rates, there was no statistically significant difference in rates of any or exclusive breastfeeding between groups at birth, at 5 to 7 days, or at 6 to 8 weeks (Table 12).^110^

##### Other Maternity Care Practices

We included six trials focused on other system-level maternity care practices, including three fair-quality trials focused on maintaining mother and baby contact following delivery^96,105,129^ and three good-quality trials focused on delayed or restricted pacifier use (Table 7; Appendix C Table 1).^112,115,117^ The first three trials reported mixed results (Appendix C Table 2). In the fair-quality U.S. study by Nolan and colleagues, 50 women scheduled for a Cesarean delivery were randomly allocated to receive a new protocol for minimizing maternal-infant separation following birth or usual peripartum care whereby infants were removed promptly from the operating room and transferred to the obstetric recovery room with brief or no physical contact with their mothers. This study found higher rates of any breastfeeding at hospital discharge (76.0% vs. 52.0%) and at 4 weeks (72.7% vs. 33.3%) among those receiving the intervention versus those receiving usual care. The relative effect of the intervention versus control on any breastfeeding at 4 weeks was statistically significant for the full sample of randomized women (unadjusted RR, 2.18 [95% CI, 1.17 to 4.06]) but not for only women who initiated breastfeeding at birth (p<0.05).^129^ Neither of the other two trials on maintaining mother and baby contact following delivery found statistically significant differences in the prevalence of any or exclusive breastfeeding or the absolute duration of breastfeeding between treatment arms.^96,105^

There was no evidence from the three good-quality trials that the rate of breastfeeding differed between mothers asked to avoid or delay pacifier use versus those given no such instructions or who were deliberately given pacifiers (Table 11; Appendix C Table 2).^112,115,117^ We judged these trials to have very limited applicability to U.S. primary care, however. For instance, in the U.S. trial by Howard and colleagues, as part of their discharge packet, mothers in the control group were given pacifiers and instructed to use the pacifier as soon as possible as a means of comforting their babies in addition to any other comforting mechanisms they chose.^112^ The trial by Jenik and colleagues, which evaluated the effects of recommendations to offer or not offer pacifiers once lactation was well established, was designed as a noninferiority trial among mothers in Argentina who were highly motivated to breastfeed. In that study, both treatment groups had extremely high rates of any and exclusive breastfeeding, with nearly 100 percent of mothers still breastfeeding at 4 months postpartum.^115^

### Detailed Results Among Adolescents and Young Adults

All four of the trials that were limited to adolescents or young adults found higher rates of any or exclusive breastfeeding or a longer duration of breastfeeding among mothers in the intervention groups than among those assigned to usual care (Appendix C Table 2).^100,102,132,137^ The benefit was statistically significant in all three U.S. trials^100,102,137^ but did not reach statistical significance in the Australian trial.^132^ In the most recent trial by Edwards and colleagues, 248 low-income black mothers (mean age, 18.3 years) were randomized to a 26-week intervention that consisted of 10 weekly prenatal home visits, in-hospital support, 12 postpartum home visits, and optional phone support provided by a community doula with specialized lactation support training; the other mothers were assigned to usual care (control group). Mothers in the intervention group were statistically significantly more likely to initiate breastfeeding than the mothers in the usual care group (63.9% vs. 49.6%; p=0.02) and to breastfeed for at least 6 weeks (28.7% vs. 16.8%; p=0.04). There was no statistically significant difference, however, in the proportion of mothers still breastfeeding at 16 weeks (8.3% vs. 4.4% in the intervention and control groups, respectively).^102^ In another fairly intense intervention, Wambach and colleagues randomized 289 predominantly low-income black girls (mean age, 17 years) to usual care or to a breastfeeding support intervention that spanned from the second trimester of pregnancy through 4 weeks postpartum. The intervention mothers received group prenatal education classes in which support persons were encouraged to attend, in-hospital face-to-face support sessions, and at least five postpartum telephone calls. Intervention participants were also given an electric breast pump at no charge on an as-needed basis. The intervention was provided by an IBCLC and peer counselors. Girls in the intervention group reported a higher rate of breastfeeding initiation (79%) versus those in the usual care group (63%), but this difference was not statistically significant after adjustment for breastfeeding knowledge, breastfeeding intention, timing of feeding decision, positive breastfeeding sentiment, and social and professional support. However, the duration of any breastfeeding was statistically significantly longer in the intervention group (median, 177 days [range, 1 to 213]) than in the usual care group (median, 61 days [range, 1 to 195]) after adjustment for positive breastfeeding sentiment and social and professional support.^137^ In a 5-week postpartum telephone peer support intervention, Di Meglio and colleagues found a statistically significant difference in the duration of exclusive breastfeeding but not for any breastfeeding among predominantly low-income young women in the United States (n=78). Mothers in the peer support group breastfed their infants exclusively for a median of 35 days, whereas mothers in the usual care control group exclusively breastfed for a median of 10 days (p=0.004).^100^ Finally, the trial that took place in Australia among 136 adolescent mothers (mean age, 16 years) found that mothers in the intervention group breastfed for a median of 12 weeks compared with 8 weeks in the control group, a nonstatistically significant difference (p=0.73). Breastfeeding duration was a secondary aim in this trial; the primary aim was reducing adverse infant outcomes and improving the adolescent mothers' knowledge regarding contraception, breastfeeding, and vaccination schedules.^132^

## KQ 3 Are There Adverse Events Associated With Interventions to Promote and Support Breastfeeding?

We identified only two trials^99,104^ that reported adverse events related to a breastfeeding intervention. Both trials were of fair quality and were conducted in Canada. Gagnon and colleagues compared an intervention involving a single postpartum home visit by a nurse with usual care and found no significant difference between the groups in maternal state anxiety scores, as measured by the State-Trait Anxiety Inventory, at 2 weeks postpartum (mean difference, 0.3 [95% CI, -0.5 to 1.1]).^104^ Dennis and colleagues compared a peer support intervention with usual care and reported that a few mothers in the intervention group expressed feelings of anxiety, decreased confidence, or concerns about confidentiality. For example, one mother requested to discontinue her participation in the intervention, stating that the peer volunteer frightened her about the potential hazards of not breastfeeding and diminished her feelings of confidence, despite the fact that breastfeeding was going well for her. The study did not report any such adverse events among mothers in the control group. Another mother felt her right to confidentiality was violated after her peer volunteer contacted the public health department to request professional assistance without her knowledge.^99^