# 2 Methods

## Review Scope

The current review is an update of the 2008 review^64,65^ that supported the previous USPSTF recommendation. Our update focuses on the effectiveness of breastfeeding support interventions on breastfeeding initiation, duration, and exclusivity; child health outcomes; and maternal health outcomes. Our update included all studies from the previous USPSTF review that met our current inclusion criteria as well as newly identified studies. The USPSTF will use this review to update its 2008 recommendation. We did not systematically update the evidence on the association between breastfeeding and child and maternal health outcomes as this was reviewed in 2007 by the AHRQ Effective Health Care Program.^12^

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an Analytic Framework (Figure 2) and three key questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 2 Analytic Framework

This figure is the analytic framework that depicts the three Key Questions (KQs) to be addressed by the systematic review. The figure illustrates how individual- and health care system-level breastfeeding interventions may improve child and maternal health outcomes (KQ1) and work to promote and support breastfeeding initiation, duration, and exclusivity (KQ2). The analytic framework also depicts the possible adverse events occurring from these interventions (KQ3).

### KQs

1. What are the effects of prenatal, peripartum, and postpartum individual- and health care system-level interventions to promote and support breastfeeding on short- and long-term child and maternal health outcomes?
  a. Does the effectiveness of breastfeeding interventions differ by the population subgroups based on age, race/ethnicity, and socioeconomic status?
  b. Are there intervention characteristics that influence the effectiveness of breastfeeding interventions?
2. What are the effects of prenatal, peripartum, and postpartum individual- and health care system-level interventions to promote and support breastfeeding on initiation, duration, and exclusivity of breastfeeding?
  a. Does the effectiveness of breastfeeding interventions differ by the population subgroups based on age, race/ethnicity, and socioeconomic status?
  b. Are there intervention characteristics that influence the effectiveness of breastfeeding interventions?
3. Are there adverse events associated with interventions to promote and support breastfeeding?

## Data Sources and Searches

In addition to re-evaluating the 41 studies (in 42 articles) included in the 2008 review, we also searched the following databases for relevant English-language literature published between January 1, 2008, and September 25, 2015: MEDLINE, PubMED (for publisher-supplied records only), PsycINFO, Cumulative Index for Nursing and Allied Health Literature, and the Cochrane Central Register of Controlled Trials. We worked with a medical librarian to develop our search strategy (Appendix A). We also examined the reference lists of all of our included studies and previously published reviews to identify other studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) and the WHO International Clinical Trials Registry Platform (www.who.int/ictrp) for ongoing trials. We imported the literature from these sources directly into EndNote® X7 (Thomson Reuters, New York, NY).

## Study Selection

We developed criteria for including or excluding studies based on the original review^64,65^ and our understanding of the literature (Appendix A Table 1). We included randomized, controlled trials (RCTs) and cluster RCTs for individual-level interventions and before-after studies with concurrent controls and prospective cohort studies for health system or policy interventions. The population of interest included mothers of full- or near-term infants as well as members of the mother-infant support system (e.g., partners, grandparents, or friends). Included studies targeted the effects of prenatal, peripartum, or postpartum breastfeeding interventions that were initiated in, feasible for, or referable from primary care settings. Infant health outcomes included, but were not limited to, gastrointestinal illness, otitis media, respiratory illness, asthma, atopic dermatitis, and infant health care utilization. Maternal health outcomes were those such as postpartum weight loss and the incidence of breast cancer. Breastfeeding outcomes included self-reported or observed initiation of breastfeeding, the prevalence and duration of any breastfeeding, and the prevalence and duration of exclusive breastfeeding. Definitions of these outcomes are provided below. For adverse events, we specifically looked for harms that could be related to a breastfeeding intervention (e.g., feeling criticized by the interventionist, guilt related to not starting breastfeeding or stopping breastfeeding, increased anxiety about breastfeeding) rather than harms related to breastfeeding itself (e.g., cases of mastitis, nipple pain). We required that studies take place in developed countries as defined as “very high” on the 2014 Human Development Index of the United Nations (http://hdr.undp.org/en/statistics) to ensure that the evidence was applicable to a U.S. setting.^75^ We limited included studies to those that were deemed good or fair quality by the USPSTF quality rating standards (described below).^76^ Studies of poor quality were excluded.

Two independent reviewers independently screened all records in the updated searches on the basis of their titles and abstracts, using the inclusion and exclusion criteria as a guide. Subsequently, at least two reviewers assessed the full text of potentially relevant studies, including all of the previously included studies, using a standard form that outlined the eligibility criteria. Disagreements were resolved through discussion and consensus. We kept detailed records of all included and excluded studies, including the reason for their exclusion.

## Quality Assessment and Data Abstraction

Two reviewers independently assessed the methodological quality of all eligible studies, including the original studies, by using USPSTF criteria.^76^ We assigned each study a quality rating of “good,” “fair,” or “poor” according to study design–specific criteria (Appendix A Table 2). Good-quality RCTs had adequate randomization procedures and allocation concealment, similar groups at baseline, well-defined interventions, reliable outcome measures, blinded outcome assessment, and low attrition (≥90% of participants had followup data, with a <10 percentage-point difference in loss to followup between groups), and they used conservative data substitution methods for missing data. Trials were given a quality rating of fair if they were unable to meet the majority of the good-quality criteria but were not of poor quality. Trials were rated as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points, or if there was any other flaw that seriously affected internal validity, as agreed upon by two independent reviewers.

Good-quality observational studies included a representative exposed cohort and comparable groups on the basis of the design or analysis, adequate ascertainment of the exposure, and no other important threats to internal validity. Observational studies were downgraded to fair if they were unable to meet the majority of these criteria. Poor-quality studies had multiple threats to validity. Discordant quality ratings were reviewed and discussed by two independent reviewers and a third reviewer adjudicated as necessary. Studies rated as poor quality and those that presented incomplete data were excluded from the review.

We abstracted descriptive and outcomes data from each included study (both the original and update studies) into detailed abstraction forms using Microsoft Access® 2010 (Microsoft, Redmond, WA). One reviewer completed primary data abstraction and a secondary reviewer checked all data for accuracy and completeness. Data collection included general characteristics of the study (e.g., author, year, and study design), characteristics of the sample (e.g., age and clinical characteristics of a population, setting, or country), description of the intervention (type, provider, frequency, and duration), definitions of outcomes (initiation and exclusivity), analytic methods, and results. We contacted authors when data reporting was incomplete or particular data points required clarification.

## Breastfeeding Definitions Used in the Report

We noted the specific definition of breastfeeding initiation, any breastfeeding, and exclusive breastfeeding as described by each individual study. We considered breastfeeding initiation to include any breastfeeding reported around the time of delivery up to 1 week postpartum. There are three main definitions of exclusive breastfeeding used in the literature: “exclusive breastfeeding” according to Labbok and Krasovec (breast milk only, without any other food, fluids, water, juice, or other liquids, including vitamins or medicines);^2^ “exclusive breastfeeding” according to the WHO (breast milk only, without any food, water, juice, or other liquids but including vitamins, minerals, and medicines);^77^ and “full breastfeeding,” as defined by Labbok and Krasovec, which includes both predominant breastfeeding (infant may consume water, water-based drinks, fruit juice, or ritualistic fluids but no infant formula) and exclusive breastfeeding (Figure 3).^2^ Within each study, we preferred measures of exclusive breastfeeding over predominant or full breastfeeding when more than one measure was reported. In many cases, the studies did not describe what they considered as exclusive breastfeeding and we assumed they generally meant that the infant did not receive any supplementary feeding with infant formula or with complementary solid foods if before 6 months of life. We considered the prevalence of any breastfeeding to include the infant receiving any breast milk, with or without supplemental feeding with infant formula or complementary feeding with solid foods. Where provided, we noted whether the measure of breastfeeding was based on the previous 24 hours or since birth.

Figure 3 Definitions of Breastfeeding^2,77^

* Partial breastfeeding includes high intensity (>80% of feeds are breastfeeds), medium intensity (20-80% of feeds are breastfeeds), low intensity (<20% of feeds are breastfeeds), and token breastfeeding (i.e., minimal, occasional, irregular breastfeeds)

This figure shows the definitions of any and exclusive breastfeeding in terms of what the infant consumes (i.e., breast milk, vitamins/minerals/medicines, water/juice, or complementary feeds/infant formula).

## Data Synthesis and Analysis

We synthesized data separately for each KQ. The data on health outcomes (KQ1) and adverse events (KQ3) did not allow for quantitative analyses, so we summarized those data qualitatively. For breastfeeding outcomes (KQ2), we synthesized the results of studies with adolescents or young adults (i.e., women age ≤21 years) and those with adults separately. We organized the results for adults by the level of intervention (individual vs. system) and, due to the clinical heterogeneity between them, did not pool the results across these intervention types. Because of the small number of studies available for system-level interventions, we report those results narratively and without pooling the data.

For individual-level interventions with breastfeeding outcomes, we entered the raw number of events (prevalence of breastfeeding initiation, any breastfeeding, or exclusive breastfeeding) in each treatment group and the total number of participants randomized for each group into random effects meta-analyses using the DerSimonian and Laird method^78^ to calculate a pooled risk ratio (RR). We grouped the breastfeeding results into five distinct cross-sectional time points to correspond with U.S. Healthy People 2020 objectives:^10^ breastfeeding initiation (at birth up through 1 week postpartum) and breastfeeding at less than 3 months (2 through 11 weeks), 3 to less than 6 months (12 through 23 weeks), 6 months (24 through 26 weeks), and 12 months (52 weeks).^10^ Each study could be included within more than one meta-analysis if it reported corresponding data. Within each study, however, we chose data from the longest time point within a given time category if more than one time point was reported (e.g., if a study reported both 12- and 20-week outcomes, we pooled the 20-week results); with this approach, an individual trial never contributed to more than one data point for a given pooled estimate. In addition, if a trial had more than one active intervention arm, we plotted the most intensive arm (based on the number and duration of the sessions) or the arm that was the most similar with other interventions included in the analysis. We compared our estimated RR for each study with the study-reported crude or adjusted between-group relative risks. We adjusted for the cluster randomization of six trials^79-84^ by applying a design effect to the number of events, which was based on an estimated average cluster size (the total number of participants analyzed at baseline divided by the total number of clusters) and an estimated intraclass correlation. When not reported, we estimated the intraclass correlation to be 0.035, based on published literature.^85^ We were unable to pool data on continuous measures of absolute breastfeeding duration given the variability in the reported measures (means or medians), followup durations, and direction of the time-to-event data (risk of cessation of breastfeeding vs. risk of still breastfeeding); therefore, we synthesized these data in a table and narratively.

We examined statistical heterogeneity among the pooled studies using standard chi-squared tests and estimated the proportion of total variability in point estimates using the I^2^ statistic.^86^ We applied the Cochrane Collaboration's rules of thumb for interpreting heterogeneity: less than 40 percent likely represents unimportant heterogeneity, 30 to 65 percent moderate heterogeneity, 50 to 90 percent substantial heterogeneity, and greater than 75 percent considerable heterogeneity.^87^ We ran sensitivity analyses for all of our meta-analyses that resulted in substantial heterogeneity (I^2^>50%) using a restricted maximum likelihood model with the Knapp-Hartung modification (using the metareg command in Stata), which is more conservative when there is substantial heterogeneity or a small number of studies.^88^ All statistically significant results remained within the restricted maximum likelihood model, so we show results using the DerSimonian and Laird method.^78^ In addition, we generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and ran the Peters' test to assess statistical significance of imbalance in study size and findings that suggest a pattern.^89^

We calculated the number needed to treat (NNT) for selected results by first estimating the absolute risk reduction based on the pooled RR and three levels of “baseline” rates of breastfeeding (i.e., absolute risk reduction = [RR−1]*baseline risk). Because there was a wide range of control group rates for some of the time points, we chose baseline levels empirically using the included studies and roughly corresponding to the 25th, 50th, and 75th percentiles of control group rates at each time point for any and exclusive breastfeeding. NNT was calculated as the inverse of the absolute RR.^87^

We investigated whether the heterogeneity among the results was associated with any prespecified population or intervention characteristics of the studies first qualitatively, using visual displays and tables grouped or sorted by these potentially important characteristics. Specifically, we examined country (United States vs. others), breastfeeding status at baseline, intention to breastfeed, previous breastfeeding experience, intervention type (education, professional support, peer support), intervention timing (prenatal, peripartum, postpartum, or a combination), intervention duration, number of intervention sessions, whether the intervention included any in-person contact with the provider or telephone support, and the breastfeeding rate in the control group at baseline as they related to the effect estimates. Based on this initial assessment, we used meta-regression and subgroup analyses to examine whether the effects were different in specific subgroups, namely current breastfeeding at study inclusion, intervention type (professional support, peer support, and education), intervention timing (multiple time periods [e.g., prenatal and postpartum] vs. one time period [e.g., prenatal only]), and face-to-face contact. Due to the general lack of statistically significant meta-regression results, we present overall results for all individual-level interventions at each time point. We grouped the studies within forest plots based on the timing of the intervention (multiple time points vs. one time point) and sorted studies within these groups by intervention timing and number of sessions. We used Stata version 13.1 (StataCorp, College Station, TX) for all quantitative analyses. All significance testing was two-sided and results were considered statistically significant if the p-value was 0.05 or less.

## Expert Review and Public Comment

A draft of the Analytic Framework, KQs, and inclusion and exclusion criteria was posted on the USPSTF Web site for public comment from October 9, 2014, through November 5, 2014. The majority of comments, while informative, pertained to details and considerations for background information and data abstraction and analysis. There were no changes made to the research plan that changed the scope of the review or our approach to synthesizing the evidence. A final research plan was posted on the USPSTF Web site on December 18, 2014. The full draft report was reviewed by invited experts from September 18, 2015 through October 12, 2015. We compiled and addressed (where appropriate) the comments received from invited experts. Additionally, a draft of the full report was posted on the USPSTF Web site from April 26, 2016 through May 23, 2016. A few comments were received during this public comment period; no changes were made to the report based on these comments.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.