# 1 Introduction

## Purpose

The Agency for Healthcare Research and Quality (AHRQ) requested an updated evidence report on counseling interventions in primary care to promote and support breastfeeding. This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2008 recommendation on breastfeeding counseling and support interventions.^1^

## Condition Definition

Breastfeeding is typically described based on the exclusivity of breastfeeding (breastfeeding without supplementation) and on how long the infant is fed breast milk. Supplementation typically refers to giving the infant formula or other breast milk substitutes. Various sources define exclusive breastfeeding differently, sometimes allowing vitamins, medicines, or ritualistic feedings as part of the definition.^2,3^ Infants may consume breast milk by direct breastfeeding (baby-to-breast), bottle- or cup-feeding breast milk expressed by the mother or obtained through formal or informal breast milk donation, or both. In this review, we use the term “breastfeeding” to refer to both direct breastfeeding and feeding expressed breast milk unless specifically noted. Various definitions of breastfeeding are further described in the Methods section.

## Recommendations for Breastfeeding and Breastfeeding Support

Multiple national and international organizations, including the American Academy of Pediatrics (AAP) (2012),^4^ the American Academy of Family Physicians (2012),^5^ the American Congress of Obstetrics and Gynecology (2007),^6^ and the World Health Organization (WHO) and the United Nations Children's Fund (UNICEF) (2003),^3^ recommend exclusive breastfeeding up to or around 6 months, followed by continued breastfeeding for at least 1 year as mutually desired by mother and infant while complementary foods are introduced. As part of its recommendation, the AAP suggests peripartum policies and practices that support breastfeeding initiation and maintenance. Specifically, the AAP recommends direct skin-to-skin contact between the infant and the mother immediately after delivery until the first feeding is accomplished and contact throughout the postpartum period, delaying routine procedures such as weighing and bathing and the administration of intramuscular vitamin K until after the first feeding is completed (but within 6 hours in the case of vitamin K), ensuring eight to 12 feedings at the breast every 24 hours, ensuring formal evaluation and documentation of breastfeeding by trained providers (including position, latch, milk transfer, and examination) for at least each nursing shift, giving no supplements (i.e., water, glucose water, commercial infant formula, or other fluids) to the breastfeeding infant unless medically indicated, beginning daily oral vitamin D drops at hospital discharge, and avoiding routine pacifier use for the first 3 or 4 weeks of the postpartum period. Furthermore, the AAP recommends that a pediatrician see a breastfeeding infant at 3 to 5 days old (which is within 48 to 72 hours of discharge from the hospital) to evaluate the child for hydration and body weight gain, observe breastfeeding, and discuss maternal and infant issues with the family.^4^

These same organizations also endorse the Baby-Friendly Hospital Initiative (BFHI). The BFHI is a global program sponsored by the WHO and UNICEF to encourage and recognize hospitals and birth centers that offer an optimal level of care for breastfeeding. The initiative was launched in 1991 and is based on the WHO/UNICEF “10 Steps to Successful Breastfeeding for Hospitals” (Table 1).^7^. In the United States, Baby-Friendly accreditation is awarded by Baby-Friendly USA, Inc., to birthing facilities that successfully implement the 10 Steps to Successful Breastfeeding and the International Code of Marketing of Breast-Milk Substitutes and pass an intensive site visit.^8^ Designations expire after 5 years, at which time facilities must go through a redesignation process. As of August 2015, 286 hospitals and birthing centers in 47 states and the District of Columbia held the BFHI designation and 14.1 percent of U.S. births occurred in BFHI-accredited facilities.^9^

Table 1 WHO/UNICEF 10 Steps to Successful Breastfeeding

1. Have a written breastfeeding policy that is routinely communicated to all health care staff.
2. Train all health care staff in skills necessary to implement this policy.
3. Inform all pregnant women about the benefits and management of breastfeeding.
4. Help mothers initiate breastfeeding within one hour of birth.
5. Show mothers how to breastfeed, and how to maintain lactation even if they should be separated from their infants.
6. Give newborn infants no food or drink other than breast milk, unless medically indicated.
7. Practice rooming in (allow mothers and infants to remain together) 24 hours a day.
8. Encourage breastfeeding on demand.
9. Give no artificial teats or pacifiers (also called dummies or soothers) to breastfeeding infants.^*^
10. Foster the establishment of breastfeeding support groups and refer mothers to them on discharge from the hospital or clinic.

* The AAP does not support a categorical ban on pacifiers because of their role in sudden infant death risk reduction and their analgesic benefit during painful procedures when breastfeeding cannot provide the analgesia. Pacifier use in the hospital in the neonatal period should be limited to specific medical indications such as pain reduction and calming in a drug-exposed infant, for example. Mothers of healthy full-term breastfed infants should be instructed to delay pacifier use until breastfeeding is well established, usually about 3 to 4 weeks after birth.^4^

Healthy People 2020 targets for initiating breastfeeding, breastfeeding to 6 months, and breastfeeding to 12 months are 81.9, 60.6, and 34.1 percent, respectively (Table 2).^10^ Targets for exclusive breastfeeding are 46 percent at 3 months and 25 percent at 6 months. Other Healthy People 2020 objectives related to breastfeeding include increasing the proportion of employers who have worksite lactation support programs, reducing the proportion of breastfed newborns who receive formula supplementation within the first 2 days of life, and increasing the proportion of live births that occur in facilities that provide recommended care for lactating mothers and their babies. In addition, the Surgeon General's 2011 “Call to Action to Support Breastfeeding” outlines 20 specific actions and related implementation strategies to improve rates of breastfeeding in the United States.^11^ Actions specific to the health care sector include: ensuring that maternity care practices throughout the United States are fully supportive of breastfeeding; developing systems to guarantee the continuity of skilled support for lactation between hospitals and health care settings in the community; providing education and training in breastfeeding for all health professionals who care for women and children; including basic support for breastfeeding as a standard of care for midwives, obstetricians, family physicians, nurse practitioners, and pediatricians; ensuring access to services provided by International Board-Certified Lactation Consultants (IBCLCs); and identifying and addressing obstacles to greater availability of safe banked donor milk for fragile infants.

Table 2 Healthy People 2020 Objectives^10^ for Breastfeeding and Current Prevalence^46^

Objective | 2020 Target (%) | 2012 Overall Prevalence (%)
Objective | 2020 Target (%) | U.S. National | Maternal age <20 years | White^*^ | Black^*^ | Hispanic | Asian^*^ | Hawaiian/Pacific Islander^*^ | American Indian/Alaska Native^*^
Any breastfeeding^†^
Ever^‡^ | 81.9 | 80.0 | 58.6 | 83.0 | 66.4 | 82.4 | 83.2 | 83.9 | 71.5
At 6 months | 60.6 | 51.4 | 17.4 | 55.8 | 35.3 | 51.4 | 65.6 | 32.6 | 28.8
At 1 year | 34.1 | 29.2 | 4.3 | 32.8 | 16.9 | 27.9 | 42.3 | 14.4 | 17.9
Exclusive breastfeeding^§^
Through 3 months | 46.2 | 43.3 | 28.3 | 48.0 | 33.4 | 40.3 | 46.5 | 43.3 | 27.4
Through 6 months | 25.5 | 21.9 | 8.0 | 24.4 | 13.9 | 20.8 | 26.9 | 11.8 | 12.5
Reduce the proportion of breastfed newborns who receive formula supplementation within the first 2 days of life | 14.2 | 19.1 | -- | -- | -- | -- | -- | -- | --
Increase the proportion of live births that occur in facilities that provide recommended care for lactating mothers and their babies | 8.1 | 14.1^9^ | -- | -- | -- | -- | -- | -- | --

* Non-Hispanic.

† Any breastfeeding or being fed breast milk.

‡ Ever breastfed or fed breast milk.

§ Child receives no solids, water, or other liquids.

## Association Between Breastfeeding and Breast Milk and Child and Maternal Outcomes

To date, the most comprehensive and widely cited systematic review on the relationship between breastfeeding and infant and maternal health outcomes is a 2007 report prepared by Ip and colleagues for the AHRQ Effective Health Care Program.^12,13^ This report, which synthesized both primary studies and existing systematic reviews, was evaluated by the USPSTF as part of its deliberations in making its 2009 recommendation. A number of more recent systematic reviews have been published that present findings consistent with those from the 2007 report and provide additional data for outcomes with previously limited or otherwise insufficient data.^14-25^ The synthesized evidence for child and maternal outcomes are summarized in Table 3 and Table 4, respectively, and narrated below.

Table 3 Association Between Breastfeeding and Infant/Child Outcomes

Infant Outcome | Evidence From 2007 AHRQ EHC Report^*^ | | | Recent Evidence From Existing Systematic Reviews
Infant Outcome | k | Breastfeeding Comparison | Pooled Adjusted OR (95% CI) | k | Breastfeeding Comparison | Pooled OR (95% CI)
Acute otitis media | 2^12^ | Ever vs. never | 0.77 (0.64 to 0.91) | 5^17^ | Ever vs. never | 0.67 (0.56 to 0.80)
Acute otitis media | 3^12^ | Exclusive ≥3 or ≥6 mo vs. never | 0.50 (0.36 to 0.70) | 5^17^ | Exclusive 6 mo vs. nonexclusive | 0.57 (0.44 to 0.75)
Asthma | 18^12^ | ≥3 mo vs. never | 0.73 (0.59 to 0.92)^†^ | 13^24^ | Ever vs. never | 0.88 (0.82 to 0.95)
Asthma | 18^12^ | ≥3 mo vs. never | 0.73 (0.59 to 0.92)^†^ | 13^24^ | Exclusive >3 or 4 mo vs. <3 mo | 0.94 (0.69 to 1.29)
Atopic dermatitis | 18^26^ | Exclusive ≥3 mo vs. <3 mo | 0.58 (0.41 to 0.92)^‡^ | 6^24,§§^ | ≥3 to 4 mo vs. “other” | 0.74 (0.57 to 0.97)^ǁǁ^
Atopic dermatitis | 18^26^ | Exclusive ≥3 mo vs. <3 mo | 0.58 (0.41 to 0.92)^‡^ | 17^24,§§^ | “More” vs. “less” | 0.95 (0.85 to 1.07)^ǁǁ^
Cardiovascular risk factors: systolic blood pressure | 24^190^ | Ever vs. never | NR^††^ | 18^21^ | Ever vs. never | -0.70 mm Hg (-1.18 to -0.21)^¶¶^
Cardiovascular risk factors: diastolic blood pressure | 23^190^ | Ever vs. never | NR^††^ | 19^21^ | Ever vs. never | -0.34 mm Hg (-0.76 to 0.09)^¶¶^
Cardiovascular risk factors: cholesterol | 37^191^ | Ever vs. never | NR^#^ | 26^21^ | Ever vs. never | -0.01 mmol/L (-0.05 to 0.02)^¶¶^
Childhood leukemia | 3^12^ | ≤6 mo vs. never | 0.91^§^ (0.83 to 1.00) | 18^15^ | Ever vs. never | 0.89 (0.84 to 0.94)
Childhood leukemia | 3^12^ | >6 mo vs. never | 0.80^§^ (0.71 to 0.91) | 18^15^ | ≥6 mo vs. <6 mo | 0.81 (0.73 to 0.89)
Cognitive development | 48^12^ | Ever vs. never | NR^¶^ | 17^22,##^ | Varied by study; 7/17 included studies were ever vs. never | 3.44 points (2.30 to 4.58)^¶¶^
Diabetes mellitus: type 1 | 17^30^ | Ever vs. never | NR^**^ | 14^18^ | Ever vs. never | 0.81 (0.72 to 0.92)
Diabetes mellitus: type 1 | 17^30^ | <3 mo vs. ≥3 mo | 1.23^§^ (1.12 to 1.35) | 28^18^ | ≥2 wk vs. <2 wk | 0.93 (0.81 to 1.07)
Diabetes mellitus: type 2 | 7^31^ | Ever vs. never | 0.61 (0.44 to 0.85) | 11^21^ | Varied | 0.65 (0.49 to 0.86)
Gastrointestinal infection | 14^27^ | Ever vs. never | 0.36 (0.32 to 0.41) | 2^23^ | Never vs. ever | 1.32 (1.06 to 1.63)^***^
Lower respiratory tract infection | 7^29^ | Exclusive ≥4 mo vs. never | 0.28^ǁ^ (0.14 to 0.54) | No updated evidence synthesis identified
Obesity | 9^32^ | Varied^‡‡^ | 0.78 (0.71 to 0.85) | 113^21^ | Varied | 0.74 (0.70 to 0.78)
Obesity | 9^32^ | Varied^‡‡^ | 0.78 (0.71 to 0.85) | 26^21^ | Ever vs. never | 0.77 (0.69 to 0.86)
SIDS | 7^12^ | Ever vs. never | 0.64 (0.51 to 0.81) | 20^14^ | Varied | NR^†††^
All-cause mortality | 1^12^ | Ever vs. never | 0.79 (0.67 to 0.93) | 2^25^ | None vs. partial (infants 0 to 5 mo) | 3.89 (2.28 to 6.65)^‡‡‡^
All-cause mortality | 1^12^ | Ever vs. never | 0.79 (0.67 to 0.93) | 4^25^ | None vs. partial (infants 6 to 11 mo) | 1.76 (1.28 to 2.41)^‡‡‡^
All-cause mortality | 1^12^ | Ever vs. never | 0.79 (0.67 to 0.93) | 6^25^ | None vs. partial (children 12 to 23 mo) | 1.97 (1.45 to 2.67)^‡‡‡^

* The 2007 AHRQ EHC Report^12^ was based on original or updated systematic reviews as well as a review of existing systematic reviews or meta-analyses. We note the citation for the source of the data for each outcome alongside the number of studies.

† Among those without a family history.

‡ Among those with a family history.

§ Unadjusted.

ǁ Hospitalization for lower respiratory tract infection.

¶ Authors concluded there was little or no evidence for an association between breastfeeding in infancy and cognitive performance in childhood based on qualitative synthesis.

# Authors concluded the relationships between breastfeeding and adult cholesterol levels, cardiovascular disease mortality, or ischemic heart disease mortality cannot be characterized due to limited data.

** For risk of type 1 diabetes for breastfeeding <3 months vs. ≥3 months.

†† Authors concluded an association between history of breastfeeding and small reduction in adult blood pressure exists but the clinical or public health implication of the finding is unclear.

‡‡ The pooled adjusted OR of obesity was 0.76 (95% CI, 0.64 to 0.86) in studies comparing ever with never breastfeeding (number of studies not reported) vs. 0.74 (95% CI, 0.64 to 0.85) in studies that used other comparisons (number of studies not reported).

§§ Eczema/atopic dermatitis.

ǁǁ In children younger than age 2 years; ORs also reported for children older than age 2 years.

¶¶ Mean effect.

## Studies in this review were limited to those with the specific outcome of performance on intelligence tests.

*** Risk ratio for the effect of not breastfeeding compared with any breastfeeding on diarrhea incidence among infants ages 6 to 11 months.

††† Pooled OR not reported. Breastfeeding was reported to have a protective effect on SIDS in 10 of 17 observational studies as well as 3 of 3 meta-analyses included in the review.

‡‡‡ Reported as risk ratio.

Abbreviations: AHRQ=Agency for Healthcare Research and Quality; CI=confidence interval; EHC=Effective Healthcare Program; k=number of studies; mo=month; NR=not reported; OR=odds ratio; SIDS=Sudden Infant Death Syndrome; wk=week.

Table 4 Association Between Breastfeeding and Maternal Health Outcomes

Maternal Outcome | Evidence from 2007 AHRQ EHC Report^*^ | | | Recent Evidence From Existing Systematic Reviews
Maternal Outcome | k | Breastfeeding Comparison | Pooled OR (95% CI) | k | Breastfeeding Comparison | Pooled OR (95% CI)
Breast cancer | 47^39^ | Ever vs. never | 0.96^†^ (99% SE, 0.2; p=0.04) | 98^19^ | Ever vs. never | 0.78 (0.74 to 0.82)
Breast cancer | 23^38^ | Lifetime breastfeeding >12 mo vs. never | 0.72 (0.65 to 0.80) | 50^19^ | Lifetime breastfeeding ≥12 mo vs. never | 0.74 (0.69 to 0.79)
Ovarian cancer | 9^12^ | Ever vs. never | 0.79^†^ (0.68 to 0.91) | 41^19^ | Ever vs. never | 0.70 (0.64 to 0.77)
Ovarian cancer | 6^12^ | Lifetime breastfeeding ≥12 mo vs. never | 0.72^†^ (0.54 to 0.97) | 29^19^ | Lifetime breastfeeding ≥12 mo vs. never | 0.63 (0.56 to 0.71)
Diabetes mellitus: type 2 | 2^12^ | Ever vs. never | NR^‡^ | 6^16^ | “Longer” vs. “shorter” duration of lifetime breastfeeding | 0.68 (0.57 to 0.82)

* The 2007 AHRQ EHC Report^12^ was based on original or updated systematic reviews as well as a review of existing systematic reviews or meta-analyses. We note the citation for the source of the data for each outcome alongside the number of studies.

† Adjusted risk ratio reported.

‡ Longer duration of lifetime breastfeeding was associated with reduced risk of developing type 2 diabetes among parous women without a history of gestational diabetes in two large U.S. cohort studies.

Abbreviations: AHRQ=Agency for Healthcare Research and Quality; CI=confidence interval; EHC=Effective Healthcare Program; k=number of studies; mo=month; NR=not reported; OR=odds ratio; SE=standard error.

### Infant and Child Outcomes

A history of being breastfed has been found to be associated with a reduced risk of a variety of health outcomes in infancy and childhood, including acute otitis media,^12^, ^17^ asthma and atopic dermatitis,^12,24,26^ gastrointestinal infection^27,28^ and the incidence of diarrhea,^23^ hospitalizations due to lower respiratory tract infection,^29^ sudden infant death syndrome,^12,14^ childhood leukemia,^12,15^ type 1 diabetes,^18,30^ type 2 diabetes,^21,31^ and obesity.^21,32^ In addition, a 2015 review reported a statistically significant benefit of being breastfed (vs. never being breastfed) on systolic blood pressure in childhood but no association between a history of breastfeeding and diastolic blood pressure or total cholesterol.^21^ Another recent review reported a 1.8- to 3.9-fold higher risk (depending on infant age) of all-cause mortality in children who were never breastfed compared with those who were ever breastfed, although the number of studies available for these analyses were limited (two to six studies).^25^ Several recently published systematic reviews have also reported positive child health benefits of being breastfed that were not part of the earlier AHRQ review. These benefits include reduced risk of pneumonia morbidity and mortality,^33^ celiac disease,^34^ Helicobacter pylori infection,^35^ dental caries,^36^ and malocclusions.^37^ The breastfeeding comparisons used to estimate the relative associations with health outcomes were highly variable (e.g., ever breastfed vs. never breastfed, exclusively breastfed for ≥3 months vs. exclusively breastfed for <3 months) but generally suggest that a history of any breastfeeding is more beneficial than no breastfeeding and that a longer duration, particularly for exclusive breastfeeding, confers greater benefits than a shorter duration (Table 3).

### Maternal Outcomes

In terms of maternal health outcomes, a history of breastfeeding has been found to be associated with a reduced risk for maternal breast and ovarian cancer^12,19,38,39^ and type 2 diabetes (Table 4).^16^ In contrast, no clear relationship between a history of breastfeeding and the risk of osteoporosis has been found to date, and the associations between breastfeeding and the mother's return to prepregnancy weight, postpartum weight loss, and prevalence of postpartum depression have been negligible or unclear.^12,19,20^

### Limitations of Body of Evidence Linking Breastfeeding and Health Outcomes

The evidence regarding the relationship between breastfeeding and health outcomes is almost exclusively based on observational research given that it is unethical to randomize women to breastfeed or not breastfeed. This observational research has well-recognized sources of potential bias, including possible selection bias, misclassification, unmeasured or uncontrolled confounding, reverse causality, and publication bias. In addition, exposure to breastfeeding is measured and reported differently across these studies, including the comparisons made (e.g., ever vs. never breastfeeding, or breastfeeding for 6 vs. 3 months), the definition of breastfeeding (including not distinguishing between any vs. exclusive breastfeeding), and the age at which infant and child outcomes were measured. The studies also differ in their measurement and operationalization of the infant and maternal outcomes, the study setting, and the adjustment for potential confounders. While Ip and colleagues^12^ limited their review to studies conducted in developed countries, much of the updated evidence also included studies in developing and middle-income countries, which may represent a larger set of confounding factors and may not be generalizable to the United States. A few studies have used sibling comparisons to more accurately estimate the impact of breastfeeding on long-term childhood health (mostly childhood obesity), but they have shown generally inconsistent findings.^40-44^

Lastly, there is little evidence regarding differences in the health benefits of breastfeeding directly and feeding expressed breast milk. None of the studies in the 2007 AHRQ review explicitly examined the differential association between baby-to-breast breastfeeding versus bottle-feeding breast milk on health outcomes. The majority of the health benefits of breastfeeding are thought to be conferred via specific biological aspects of breast milk (e.g., antibodies and beneficial bacteria in the breast milk, nutritive values of breast milk, or effects of breast milk on energy metabolism or insulin response) that are absent from infant formula. However, breastfeeding directly from the breast may confer additional benefits. For example, it may help reduce the risk of malocclusions because the process of sucking at a breast is different than the process used to suck from a bottle.^37^ Likewise, the strong negative pressure generated by breastfeeding, as opposed to bottle-feeding, may help reduce the risk of acute otitis media.^17^ There is also some evidence that direct breastfeeding during early infancy is associated with greater appetite regulation later in childhood, which has implications for childhood obesity.^45^

## Prevalence of Breastfeeding

The estimates for any breastfeeding for infants born in 2012 in the United States were 80.0 percent for initiation, 51.4 percent for infants breastfed at 6 months, and 29.2 percent for infants breastfed at 12 months. The rates of exclusive breastfeeding through 3 and 6 months were 43.3 and 21.9 percent, respectively (Table 2).^46^ There is generally a steady decline in any and exclusive breastfeeding with increasing child age (Figure 1).

Figure 1 Rates of Any and Exclusive Breastfeeding by Age Among Children Born in the United States in 2012^46^

Source: http://www.cdc.gov/breastfeeding/data/nis_data/index.htm

This figure depicts the rates of any and exclusive breastfeeding by age among children born in the United States in 2012. It shows that rates of any breastfeeding decline from 80% to approximately 30% from birth to 12 months of age. The rates of exclusive breastfeeding decline from 60% at birth to approximately 20% at 6 months of age.

A number of sociodemographic factors are associated with an increased likelihood of breastfeeding initiation and continuation. These factors include older maternal age, being married, Asian or white race, Hispanic ethnicity, higher maternal education, higher socioeconomic status, access to private insurance, and geography.^11,46-49^ For instance, the rate of any breastfeeding at 6 months for non-Hispanic black infants is only 35.3 percent but is 51.4 percent for Hispanic or Latino infants, 55.8 percent for white infants, and 65.6 for Asian infants.^46^ With regard to education, women who have a high school education are almost half as likely (38.2%) to breastfeed at 6 months than women with a college education (70.3%). Further, women who are part of the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC) are less likely to breastfeed at 6 months than women who are ineligible for the program (39.1% and 68.4%, respectively). Married women are more likely to breastfeed at 6 months than those who are unmarried (62.3% vs. 33.1%). Finally, women younger than age 20 years are far less likely to breastfeed at 6 months than those ages 20 to 29 years or 30 years and older (17.4% vs. 40.6% and 60.2%).^46^

There are also large variations in the rates of breastfeeding initiation and continuation around the world, although the specific indicators and dates in which the data were collected differ.^50,51^ In a recent systematic review, the highest prevalence of exclusive breastfeeding initiation was observed in Norway (99%), Denmark (99%), and Japan (98%) and the lowest initiation rates were observed in the United Kingdom (70%), the United States (70%), and France (63%). With regard to any breastfeeding, New Zealand (81%), Canada (71%), and Italy (66%) had the highest rates of breastfeeding maintenance at 3 to 4 months and the United Kingdom (43%) and France (16%) had the lowest rates.^51^

## Facilitators and Barriers to Breastfeeding

According to the Surgeon General's Call to Action to Support Breastfeeding, the primary barriers to breastfeeding include the lack of maternal knowledge about the benefits and management of breastfeeding, social norms supporting bottle-feeding infant formula versus breastfeeding, poor family and social support, embarrassment about breastfeeding in public, lactation problems, issues related to returning to work and child care, and deficits in hospital policies and clinical practices related to supporting breastfeeding.^11^ Among women who initiate breastfeeding, early discontinuation is often accompanied with a higher prevalence of self-reported problems, such as painful nipples, concerns about the adequacy of milk supply, and concern about the baby's behavior or weight. Factors reported to be associated with lower breastfeeding initiation and duration among ethnic minorities and those of low socioeconomic status include ambivalence about breastfeeding, the availability of free formula from WIC, a high level of comfort with the idea of formula feeding, and limited availability and lower intensity of breastfeeding support.^52^ Other factors that have been linked with lower rates of breastfeeding initiation and continuation include multiparity, body mass index (underweight, overweight, or obese), and a history of depression or anxiety during pregnancy.^53-57^ Conversely, nonsmokers, women who initiate prenatal care earlier in their pregnancy, and women who complete a higher number of prenatal visits are more likely to breastfeed.^58^ There is also a growing recognition that inequity in access to breastfeeding support, including maternity care practices^59^ and credentialing of lactation care providers,^60,61^ based on factors such as race, ethnicity, class, sexual or gender identity, and income level is an important contributor to disparities in rates of breastfeeding and should be addressed.^62,63^

## Breastfeeding Interventions

Health care interventions to encourage and support breastfeeding can include individual-level interventions delivered directly to women and their support persons and also system-level policies or maternity care practices aimed at creating an environment supportive of breastfeeding (Table 5). Interventions can occur over the course of pregnancy (prenatal), the time around and shortly after delivery (peripartum), and/or after birth (postpartum).

Table 5 Interventions to Support or Promote Breastfeeding

Intervention | Types | Examples
Individual-level support and education | Professional support | One-to-one support during hospital stay or outpatient visits, home visits, or telephone support from health professionals
Individual-level support and education | Peer support | Peer counseling or social support from peers or lay persons
Individual-level support and education | Formal or structured education | Structured education sessions or classes directed at mothers or other family members (workshops, didactic teaching session, booklets), typically provided in group sessions
System-level policies and practices | Policies, programs, and staff training | Baby-Friendly Hospital Initiative, implementation of a new policy or protocol, or training of health professionals
System-level policies and practices | Other maternity care practices | Encouragement of skin-to-skin contact^*^, rooming-in^†^, restricted pacifier use, and distribution of breast pumps

* After birth, the newborn is weighed and then immediately placed naked in a prone position between the mother's breasts until the mother chooses to stop the contact or the newborn seems to be ready for feeding.

† The hospital practice where postnatal mothers with healthy infants (including those born by caesarean delivery) stay together in the same room 24 hours a day, from the time they arrive in their room after delivery. They remain together until discharge unless there is a specific medical indication which warrants separation. During rooming-in the infant is placed close to the mother by bed-sharing, an attached side-car crib, or a stand-alone cot by her bedside.^7^

Individual-level interventions can include professional or peer support or structured education. Breastfeeding support can include psychological and social support (encouraging the mother, providing reassurance, discussing the mother's questions and problems) and direct support during breastfeeding observations (helping with the positioning of the infant, observing latching) and is typically offered in addition to general education. This type of support usually begins shortly after birth in the hospital setting or other birthing facility and may continue after the hospital stay. Breastfeeding education, on the other hand, typically includes a formalized program aimed at conveying nontailored breastfeeding knowledge and most often occurs in the prenatal period. Education is usually offered in group sessions and may involve telephone support, electronic interventions, and print materials. Individual-level interventions may be conducted by medical, nursing, or allied professionals (such as lactation care providers) or lay people (such as peer supporters).^64-66^

System-level interventions include policies or maternity care practices such as implementation of the BFHI or all or some of the 10 Steps to Successful Breastfeeding (Table 1). These interventions may include a written breastfeeding policy for the facility, provider or staff training in breastfeeding support, policies for implementing breastfeeding support groups, encouragement of rooming-in, restricted or delayed pacifier use, maintenance of skin-to-skin contact between the mother and baby after birth, and encouragement of early breastfeeding initiation (Table 5).

Nonhealth care breastfeeding support interventions may include community breastfeeding promotion or support; worksite policies and programs; child care policies and practices; and legislation, including family leave policies.^67^

## Current Clinical Practice in the United States

Clinicians providing care to pregnant and postpartum women play a potentially critical role in influencing decisions regarding breastfeeding initiation and continuation. Despite current recommendations encouraging primary care providers to promote and support breastfeeding, a recent study with a nationally representative sample of mothers of infants ages 2 to 6 months (n=1,031) found that many women either did not receive any advice on breastfeeding or were receiving advice that was inconsistent with recommendations from the AAP.^68^ When the doctor or nurse was the source of advice, 21.8 and 13.3 percent of mothers, respectively, did not receive any guidance on breastfeeding, while 15.4 and 14.9 percent, respectively, were given advice that was inconsistent with recommendations. Black and Hispanic mothers were more likely than white mothers to report receiving breastfeeding advice consistent with recommendations from doctors or nurses.

This low rate of provider counseling could be due to a variety of barriers encountered by the health care team. A prospective cohort study comprised of mother-newborn pairs and a cross-sectional study of their health care providers in Boston reported on barriers identified by providers in their ability to support breastfeeding.^69,70^ The most common barriers identified as very important by physicians were a limited amount of time during preventive visits to address breastfeeding problems (56%) and a lack of time to give routine advice on feeding (45%). A recent cross-sectional survey of practicing primary care physicians in Nebraska (n=262) found that physicians felt that they lacked adequate education regarding assisting patients in solving breastfeeding-related problems, which hindered their ability to provide counseling.^71^ In this sample of physicians, only 9 percent felt their education regarding breastfeeding support was adequate. These identified barriers provide insights into provider behavior and suggest opportunities for improvement at the level of the individual as well as the health system.

## Health Policy Context

Under the 2010 Patient Protection and Affordable Care Act, women's preventive health care—including breastfeeding support, supplies, and counseling—are covered by Health Insurance Marketplace plans and private nongrandfathered health plans (plans created or sold after March 2010 or older plans that have been updated).^72,73^ Specifically, health insurance plans must cover the costs associated with providing breast milk to infants, including costs for renting breastfeeding equipment (a breast pump) and comprehensive lactation support and counseling by a trained provider during the pregnancy and/or postpartum period.^72,73^ The Affordable Care Act also amended section 7 of the Fair Labor Standards Act to require employers to provide reasonable break time and a private space (not a bathroom) for breastfeeding employees to express breast milk for her nursing child for 1 year after the child's birth.^74^ Currently, the reasonable break time provision only applies to nonexempt employees under the Fair Labor Standards Act, but advocacy groups are working to expand this provision to exempt employees as well.^72,74^

## Previous USPSTF Recommendations

In 2006, the AHRQ Effective Health Care Program commissioned a review to evaluate the impact of breastfeeding on infant and maternal health outcomes.^12^ Shortly after the publication of this evidence report, AHRQ requested a related systematic review on the effectiveness of interventions to promote breastfeeding so that the USPSTF could update its 2003 recommendation. Thus, in 2008, an updated review was conducted by Chung and colleagues^64,65^ that addressed the effects of primary care–initiated interventions to support or promote breastfeeding on child and maternal health outcomes and breastfeeding rates.

Based on the 2008 review, the USPSTF concluded that there was adequate evidence that primary care interventions to promote and support breastfeeding during pregnancy and after birth increased the rates of initiation, duration, and exclusivity of breastfeeding. No harms associated with the interventions were reported in the included studies. Thus, in 2008 the USPSTF recommended interventions during pregnancy and after birth to promote and support breastfeeding (B recommendation).^1^