# Appendix D Ongoing Studies

Study Reference Trial Identifier | Study Name | Location | Estimated N | Description | Relevant Outcomes | 2015 Status
Abbott, Jonathan. The Effect of Early (2-3 Week Postpartum) Versus Traditional (6-8 Week Postpartum) Follow-Up on Breastfeeding Rates at 6 Months. 2014. Madigan Army Medical Center. PMID: None NCT02221895 | NR | United States | 346 | Randomized trial comparing early postpartum followup to traditional postpartum followup | Any breastfeeding | Recruiting
Forster DA, McLachlan HL, Davey MA, et al. Ringing Up about Breastfeeding: a randomised controlled trial exploring early telephone peer support for breastfeeding (RUBY): trial protocol. BMC Pregnancy Childbirth. 2014;14:177. PMID: 24886264 ACTRN12612001024831 | Ringing Up about Breastfeeding (RUBY) | Australia | NR | Randomized trial comparing telephone-delivered peer support with usual care | Any breastfeeding, exclusive breastfeeding | Not yet recruiting
Furman, Lydia. Breast for Success: A Family-Centered Intervention in Support of Breastfeeding Among High-Risk Low-Income Mothers in Cleveland (BFS). 2014. University Hospital Case Medical Center. PMID: None NCT01272661 | Breast for Success (BFS) | United States | 1296 | Nonrandomized trial comparing the effectiveness of 3 interventions: 1) CHW home-delivered enhanced curriculum, 2) CHW home-delivered enhanced curriculum with support person, and 3) CHW home-delivered enhanced curriculum with paternal support | Any breastfeeding | Study completed, results not published
Horodynski MA, Olson B, Baker S, et al. Healthy babies through infant-centered feeding protocol: an intervention targeting early childhood obesity in vulnerable populations. BMC Public Health. 2011;11:868. PMID: 22085421 NCT01816516 | Healthy Babies (HB) | United States | 372 | Randomized trial comparing Healthy Babies curriculum with Expanded Food and Nutrition Education Program (EFNEP) curriculum | Breastfeeding style, breastfeeding practice | Completed, no results published
Iglesia, Susana Martin. Effectiveness of an Educational Group Intervention in Primary Care to Maintain Exclusive Breastfeeding (PROLACT): A Cluster Randomized Clinical Trial. 2015. PMID: None NCT01869920 | PROLACT | Spain | 432 | Cluster randomized trial comparing a group education session with usual care | Exclusive breastfeeding | Recruiting
Kenyon S, Jolly K, Hemming K, et al. Evaluation of Lay Support In Pregnant women with Social risk (ELSIPS): a randomised controlled trial. BMC Pregnancy Childbirth. 2012;12:11. PMID: 22375895 ISRCTN35027323 | Evaluation of Lay Support In Pregnant women with Social risk (ELSIPS) | United Kingdom | 1316 | Randomized trial comparing lay Pregnancy Outreach Worker (POW) support with standard maternity care versus standard maternity care alone | Breastfeeding initiation rate, breastfeeding continuation | Recruitment completed
Martinez, Josep Balaguer. Telephone Support From Primary Care to Breastfeeding Mothers: A Randomized Multicentre Clinical Trial. 2015. Jordi Gol I Gurina Foundation. PMID: None NCT02186613 | NR | Spain | 434 | Randomized, controlled trial comparing a telephone support intervention with standard care | Exclusive breastfeeding | Recruiting
McLachlan HL, Forster DA, Amir LH, et al. Supporting breastfeeding In Local Communities (SILC): protocol for a cluster randomised controlled trial. BMC Pregnancy Childbirth. 2014;14:346. PMID: 25281300 ACTRN12611000898954 | Supporting breastfeeding In Local Communities (SILC) | Australia | NR | 3-arm cluster randomized trial comparing: 1) home-based support, 2) home-based support plus access to community-based breastfeeding drop-in center, and 3) standard maternity care | Any breastfeeding | Recruiting
Scott, Jane. Parent Infant Feeding Initiative: a study to enhance breastfeeding duration. 2015. PMID: None ACTRN12614000605695 | Parent Infant Feeding Initiative (PIFI) | Australia | 1600 | 4-arm randomized, controlled trial comparing: 1) specialized antenatal class for fathers, 2) Internet- and phone-delivered social support for fathers, 3) specialized antenatal class and social support, and 4) usual care | Any breastfeeding, Exclusive breastfeeding | Not yet recruiting
Zakarija-Grkovic, Irena. The Effect of Written Information and Support Phone Calls for First Time Mothers on Breastfeeding Rates: A Randomized Controlled Trial. 2015. University of Split. PMID: None NCT01998087 | NR | Croatia | 500 | 3-arm randomized trial comparing: 1) written and telephone-delivered support, 2) general support, and 3) standard care | Any breastfeeding, exclusive breastfeeding | Recruiting