# Appendix C Detailed Results

Appendix C Figure 1 Intervention Dose, by Intervention Type and Author Name

Abbreviations: UK=United Kingdom; US=United States; wks=weeks

This figure shows the intervention dose by intervention type and sorted by author.

Appendix C Table 1 Intervention Details, by Intervention Type and Author

Appendix C Table 2 Results of Individual-Level Breastfeeding Support and Education Interventions on Prevalence of Any Breastfeeding, by Author

Appendix C Table 3 Number Needed to Treat for Any and Exclusive Breastfeeding for Varying Levels of Usual Breastfeeding Rates