# Appendix B Excluded Studies

Reason for Exclusion
E1. | Study relevance (not related to breastfeeding intervention)
E2a. | Setting: Not in very high human development country
E2b. | Setting: Not linked to health care (e.g., worksites, correctional facilities)
E2c. | Setting: Not applicable to U.S. health care (e.g., usual care in control group is extremely different than U.S. usual care
E3. | Study design: Not RCT for individual-level intervention; not RCT, controlled before-after, or prospective cohort study for system-level policies
E4. | Population: Studies of preterm or very preterm infants (<35 weeks), low or very low birth weight infants (<2500 g), or studies limited to special populations of women or infants
E5. | Outcomes: No relevant outcomes (maternal or infant health outcomes; breastfeeding initiation, duration, exclusivity; adverse events)
E6. | Poor-quality study
E7. | Non-English–language publication
E8. | Publication type (e.g., dissertation, thesis, conference abstract)

1 Aghdas K, Talat K, Sepideh B. (2014). Effect of immediate and continuous mother-infant skin-to-skin contact on breastfeeding self-efficacy of primiparous women: a randomised control trial. Women Birth.
2 Aksu H, Kucuk M, Duzgun G. (2011). The effect of postnatal breastfeeding education/support offered at home 3 days after delivery on breastfeeding duration and knowledge: a randomized trial. J Matern Fetal Neonatal Med.
3 Albert J, Heinrichs-Breen J. (2011). An evaluation of a breastfeeding privacy sign to prevent interruptions and promote successful breastfeeding. J Obstet Gynecol Neonatal Nurs.
4 Artieta-Pinedo I, Paz-Pascual C, Grandes G, et al. (2013). Antenatal education and breastfeeding in a cohort of primiparas. J Adv Nurs.
5 Askelsdottir B, Lam-de Jonge W, Edman G, et al. (2013). Home care after early discharge: impact on healthy mothers and newborns. Midwifery.
6 Awano M, Shimada K. (2010). Development and evaluation of a self care program on breastfeeding in Japan: A quasi-experimental study. Int Breastfeed J.
7 Ball HL, Moya E, Fairley L, et al. (2012). Infant care practices related to sudden infant death syndrome in South Asian and White British families in the UK. Paediatr Perinat Epidemiol.
8 Barnes M, Cox J, Doyle B, et al. (2010). Evaluation of a practice-development initiative to improve breastfeeding rates. J Perinat Educ.
9 Battersby S. (2008). Breastfeeding peer support: implications for midwives. Pract Midwife.
10 Beiranvand S, Valizadeh F, Hosseinabadi R, et al. (2014). The Effects of Skin-to-Skin Contact on Temperature and Breastfeeding Successfulness in Full-Term Newborns after Cesarean Delivery. Int J Pediatr.
11 Bica OC, Giugliani ER. (2014). Influence of counseling sessions on the prevalence of breastfeeding in the first year of life: a randomized clinical trial with adolescent mothers and grandmothers. Birth.
12 Bick D, Murrells T, Weavers A, et al. (2012). Revising acute care systems and processes to improve breastfeeding and maternal postnatal health: a pre and post intervention study in one English maternity unit. BMC Pregnancy Childbirth.
13 Bigelow AE, Power M, Gillis DE, et al. (2014). Breastfeeding, skin-to-skin contact, and mother-infant interactions over infants' first three months. Infant Ment Health J.
14 Blixt I, Martensson LB, Ekstrom AC. (2014). Process-oriented training in breastfeeding for health professionals decreases women's experiences of breastfeeding challenges. Int Breastfeed J.
15 Bonuck KA, Lischewski J, Brittner M. (2009). Clinical translational research hits the road: RCT of breastfeeding promotion interventions in routine prenatal care. Contemp Clin Trials.
16 Brodribb W, Kruske S, Miller YD. (2013). Baby-friendly hospital accreditation, in-hospital care practices, and breastfeeding. Pediatrics.
17 Cameron SL, Heath AL, Gray AR, et al. (2015). Lactation Consultant Support from Late Pregnancy with an Educational Intervention at 4 Months of Age Delays the Introduction of Complementary Foods in a Randomized Controlled Trial. J Nutr.
18 Carfoot S, Williamson PR, Dickson R. (2004). The value of a pilot study in breast-feeding research. Midwifery.
19 Chapman D, Damio G, Young S, et al. (2004). Association of degree and timing of exposure to breastfeeding peer counseling services with breastfeeding duration. Adv Exp Med Biol.
20 Ciftci EK, Arikan D. (2012). The effect of training administered to working mothers on maternal anxiety levels and breastfeeding habits. J Clin Nurs.
21 Conroy CC, Cottrell BH. (2015). The Influence of Skin-to-Skin Contact after Cesarean on Breastfeeding Rates, Infant Feeding Responses, and Maternal Satisfaction. JOGNN.
22 Corriveau SK, Drake EE, Kellams AL, et al. (2013). Evaluation of an office protocol to increase exclusivity of breastfeeding. Pediatrics.
23 Coutinho SB, de Lira PI, de Carvalho LM, et al. (2005). Comparison of the effect of two systems for the promotion of exclusive breastfeeding. Lancet.
24 da Graca LC, Figueiredo Mdo C, Conceicao MT. (2011). Contributions of the nursing intervention in primary healthcare for the promotion of breastfeeding. Rev Lat Am Enfermagem.
25 Dabritz HA, Hinton BG, Babb J. (2010). Maternal hospital experiences associated with breastfeeding at 6 months in a northern California county. J Hum Lact.
26 Daniels LA, Mallan KM, Battistutta D, et al. (2014). Child eating behavior outcomes of an early feeding intervention to reduce risk indicators for child obesity: the NOURISH RCT. Obesity (Silver Spring).
27 Daniels LA, Mallan KM, Battistutta D, et al. (2012). Evaluation of an intervention to promote protective infant feeding practices to prevent childhood obesity: outcomes of the NOURISH RCT at 14 months of age and 6 months post the first of two intervention modules. Int J Obes (Lond).
28 De Carolis MP, Cocca C, Valente E, et al. (2014). Individualized follow up programme and early discharge in term neonates. Ital.
29 de Oliveira LD, Giugliani ER, Santo LC, et al. (2012). Impact of a strategy to prevent the introduction of non-breast milk and complementary foods during the first 6 months of life: a randomized clinical trial with adolescent mothers and grandmothers. Early Hum Dev.
30 Declercq E, Labbok MH, Sakala C, et al. (2009). Hospital practices and women's likelihood of fulfilling their intention to exclusively breastfeed. Am J Public Health.
31 Dias de Oliveira L, Justo Giugliani ER, Cordova do Espirito Santo L, et al. (2014). Counselling sessions increased duration of exclusive breastfeeding: a randomized clinical trial with adolescent mothers and grandmothers. Nutr J.
32 Dumas L, Lepage M, Bystrova K, et al. (2013). Influence of Skin-to-Skin Contact and Rooming-In on Early Mother–Infant Interaction: A Randomized Controlled Trial. Clin Nurs Res.
33 Ekstrom A, Kylberg E, Nissen E. (2012). A process-oriented breastfeeding training program for healthcare professionals to promote breastfeeding: an intervention study. Breastfeed Med.
34 Ekstrom A, Nissen E. (2006). A mother's feelings for her infant are strengthened by excellent breastfeeding counseling and continuity of care. Pediatrics.
35 Ekstrom A, Widstrom AM, Nissen E. (2006). Does continuity of care by well-trained breastfeeding counselors improve a mother's perception of support?. Birth.
36 Feldman-Winter L, Barone L, Milcarek B, et al. (2010). Residency curriculum improves breastfeeding care. Pediatrics.
37 Feldman-Winter L, Grossman X, Palaniappan A, et al. (2012). Removal of industry-sponsored formula sample packs from the hospital: does it make a difference?. J Hum Lact.
38 Figueredo SF, Mattar MJG, de Vilhena Abrão ACF. (2013). Baby-Friendly Hospital: prevalence of exclusive breastfeeding at 6 months and intervening factors. Rev Esc Enferm USP.
39 Finch C, Daniel EL. (2002). Breastfeeding education program with incentives increases exclusive breastfeeding among urban WIC participants. J Am Diet Assoc.
40 Flaherman VJ, Aby J, Burgos AE, et al. (2013). Effect of early limited formula on duration and exclusivity of breastfeeding in at-risk infants: an RCT. Pediatrics.
41 Gallegos D, Russell-Bennett R, Previte J, et al. (2014). Can a text message a week improve breastfeeding?. BMC Pregnancy Childbirth.
42 Garcia-de-Leon-Gonzalez R, Oliver-Roig A, Hernandez-Martinez M, et al. (2011). Becoming baby-friendly in Spain: a quality-improvement process. Acta Paediatr.
43 Giglia R, Cox K, Zhao Y, et al. (2014). Exclusive Breastfeeding Increased by an Internet Intervention. Breastfeed Med.
44 Grassley JS, Sauls DJ. (2012). Evaluation of the Supportive Needs of Adolescents during Childbirth intrapartum nursing intervention on adolescents' childbirth satisfaction and breastfeeding rates. J Obstet Gynecol Neonatal Nurs.
45 Griffin R, Richardson M, Morris-Thompson T. (2012). An evaluation of the impact of maternity support workers. Br J Midwifery.
46 Grossman X, Chaudhuri J, Feldman-Winter L, et al. (2009). Hospital Education in Lactation Practices (Project HELP): does clinician education affect breastfeeding initiation and exclusivity in the hospital?. Birth.
47 Grossman X, Chaudhuri JH, Feldman-Winter L, et al. (2012). Neonatal weight loss at a US Baby-Friendly Hospital. J Acad Nutr Diet.
48 Haider SJ, Chang LV, Bolton TA, et al. (2014). An evaluation of the effects of a breastfeeding support program on health outcomes. Health Serv Res.
49 Hake-Brooks SJ, Anderson GC. (2008). Kangaroo care and breastfeeding of mother-preterm infant dyads 0-18 months: a randomized, controlled trial. Neonatal Netw.
50 Hannula LS, Kaunonen ME, Puukka PJ. (2014). A study to promote breast feeding in the Helsinki Metropolitan area in Finland. Midwifery.
51 Hoddinott P, Craig L, Maclennan G, et al. (2012). The FEeding Support Team (FEST) randomised, controlled feasibility trial of proactive and reactive telephone support for breastfeeding women living in disadvantaged areas. BMJ Open.
52 Hoddinott P, Craig L, Maclennan G, et al. (2012). Process evaluation for the FEeding Support Team (FEST) randomised controlled feasibility trial of proactive and reactive telephone support for breastfeeding women living in disadvantaged areas. BMJ Open.
53 Holmes AV, McLeod AY, Thesing C, et al. (2012). Physician breastfeeding education leads to practice changes and improved clinical outcomes. Breastfeed Med.
54 Hongwei W, Senqi H, Thobaben M, et al. (2011). Continuous primary nursing care increases satisfaction with nursing care and reduces postpartum problems for hospitalized pregnant women. Contemp Nurse.
55 Ingram J, Johnson D. (2009). Using community maternity care assistants to facilitate family-focused breastfeeding support. Matern Child Nutr.
56 Ingram J, Johnson D, Condon L. (2011). The effects of Baby Friendly Initiative training on breastfeeding rates and the breastfeeding attitudes, knowledge and self-efficacy of community health-care staff. Primary health care research & development.
57 Jang GJ, Kim SH. (2010). J Korean Acad Nurs.
58 Joshi A, Amadi C, Meza J, et al. (2015). Comparison of Socio-Demographic Characteristics of a Computer Based Breastfeeding Educational Intervention Among Rural Hispanic Women. J Community Health.
59 Kair LR, Kenron D, Etheredge K, et al. (2013). Pacifier restriction and exclusive breastfeeding. Pediatrics.
60 Kamran A, Shrifirad G, Mirkarimi SK, et al. (2012). Effectiveness of breastfeeding education on the weight of child and self-efficacy of mothers - 2011. J Educ Health Promot.
61 Kang JS, Choi SY, Ryu EJ. (2008). Effects of a breastfeeding empowerment programme on Korean breastfeeding mothers: a quasi-experimental study. Int J Nurs Stud.
62 Kao JC, Johnson JE, Todorova R, et al. (2015). The Positive Effect of a Group Intervention to Reduce Postpartum Depression on Breastfeeding Outcomes in Low-Income Women. Int J Group Psychother.
63 Kemp L, Harris E, McMahon C, et al. (2011). Child and family outcomes of a long-term nurse home visitation programme: a randomised controlled trial. Arch Dis Child.
64 Kervin BE, Kemp L, Pulver LJ. (2010). Types and timing of breastfeeding support and its impact on mothers' behaviours. J Paediatr Child Health.
65 Kim Y. (2009). J Korean Acad Nurs.
66 Kistin CJ, Barrero-Castillero A, Lewis S, et al. (2012). Maternal note-taking and infant care: a pilot randomised controlled trial. Arch Dis Child.
67 Korade RS, Dhande LA, Bendhari ML, et al. (2015). Can Re-training in Baby Friendly Hospital Initiative (BFHI) Improve Breast Feeding Indicators?. Indian J Pediatr.
68 Kramer MS, Chalmers B, Hodnett ED, et al. (2001). Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus. JAMA.
69 Kronborg H, Vaeth M. (2009). How are effective breastfeeding technique and pacifier use related to breastfeeding problems and breastfeeding duration?. Birth.
70 Kronborg H, Vaeth M, Olsen J, et al. (2007). Effect of early postnatal breastfeeding support: a cluster-randomized community based trial. Acta Paediatr.
71 Labarere J, Gelbert-Baudino N, Laborde L, et al. (2011). CD-ROM-based program for breastfeeding mothers. Matern Child Nutr.
72 Labbok MH, Taylor EC, Nickel NC. (2013). Implementing the ten steps to successful breastfeeding in multiple hospitals serving low-wealth patients in the US: innovative research design and baseline findings. Int Breastfeed J.
73 Leger-Leblanc G, Rioux FM. (2008). Effect of a prenatal nutritional intervention program on initiation and duration of breastfeeding. Can J Diet Pract Res.
74 Lovera D, Sanderson M, Bogle ML, et al. (2010). Evaluation of a breastfeeding peer support program for fathers of Hispanic participants in a Texas special supplemental nutrition program for women, infants, and children. J Am Diet Assoc.
75 Lucchini Raies C, Uribe TC, Villarroel Del PL, et al. (2013). Randomized controlled clinical trial evaluating determinants of successful breastfeeding: Follow-up two months after comprehensive intervention versus standard care delivery. Revista chilena de pediatria.
76 Macaluso A, Bettinelli ME, Chapin EM, et al. (2013). A controlled study on baby-friendly communities in Italy: methods and baseline data. Breastfeed Med.
77 Mannan I, Rahman SM, Sania A, et al. (2008). Can early postpartum home visits by trained community health workers improve breastfeeding of newborns?. J Perinatol.
78 Marin Gabriel MA, Llana Martin I, Lopez Escobar A, et al. (2010). Randomized controlled trial of early skin-to-skin contact: effects on the mother and the newborn. Acta Paediatr.
79 Martin J, MacDonald-Wicks L, Hure A, et al. (2015). Reducing postpartum weight retention and improving breastfeeding outcomes in overweight women: a pilot randomised controlled trial. Nutrients.
80 Martin-Iglesias S, del-Cura-Gonzalez I, Sanz-Cuesta T, et al. (2011). Effectiveness of an implementation strategy for a breastfeeding guideline in Primary Care: cluster randomised trial. BMC Fam Pract.
81 Maycock B, Binns CW, Dhaliwal S, et al. (2013). Education and support for fathers improves breastfeeding rates: a randomized controlled trial. J Hum Lact.
82 Maycock BR, Scott JA, Hauck YL, et al. (2015). A study to prolong breastfeeding duration: design and rationale of the Parent Infant Feeding Initiative (PIFI) randomised controlled trial. BMC Pregnancy Childbirth.
83 Mazumder S, Taneja S, Bahl R, et al. (2014). Effect of implementation of Integrated Management of Neonatal and Childhood Illness programme on treatment seeking practices for morbidities in infants: cluster randomised trial. BMJ.
84 McKeever P, Stevens B, Miller KL, et al. (2002). Home versus hospital breastfeeding support for newborns: a randomized controlled trial. Birth.
85 McLeod D, Pullon S, Benn C, et al. (2004). Can support and education for smoking cessation and reduction be provided effectively by midwives within primary maternity care?. Midwifery.
86 McQueen KA. (2009). Improving breastfeeding outcomes: A pilot randomized controlled trial of a self-efficacy intervention with primiparous mothers.
87 Mejdoubi J, van den Heijkant SC, van Leerdam FJ, et al. (2014). Effects of nurse home visitation on cigarette smoking, pregnancy outcomes and breastfeeding: a randomized controlled trial. Midwifery.
88 Mellin PS, Poplawski DT, Gole A, et al. (2011). Impact of a formal breastfeeding education program. MCN Am J Matern Child Nurs.
89 Mitchell-Box KM, Braun KL. (2013). Impact of male-partner-focused interventions on breastfeeding initiation, exclusivity, and continuation. J Hum Lact.
90 Mizuno K, Mizuno N, Shinohara T, et al. (2004). Mother-infant skin-to-skin contact after delivery results in early recognition of own mother's milk odour. Acta Paediatr.
91 Moore ER, Anderson GC. (2007). Randomized controlled trial of very early mother-infant skin-to-skin contact and breastfeeding status. J Midwifery Womens Health.
92 Morris CA. (2014). The effect of a lactation consultant in the pediatric primary care setting. Diss Abstr Int.
93 Mydlilova A, Sipek A, Vignerova J. (2009). Breastfeeding rates in baby-friendly and non-baby-friendly hospitals in the Czech Republic from 2000 to 2006. J Hum Lact.
94 Nichols J, Schutte NS, Brown RF, et al. (2009). The impact of a self-efficacy intervention on short-term breast-feeding outcomes. Health Educ Behav.
95 Nommsen-Rivers LA, Mastergeorge AM, Hansen RL, et al. (2009). Doula care, early breastfeeding outcomes, and breastfeeding status at 6 weeks postpartum among low-income primiparae. J Obstet Gynecol Neonatal Nurs.
96 Nunes LM, Giugliani ER, Santo LC, et al. (2011). Reduction of unnecessary intake of water and herbal teas on breast-fed infants: a randomized clinical trial with adolescent mothers and grandmothers. J Adolesc Health.
97 Olson BH, Haider SJ, Vangjel L, et al. (2010). A quasi-experimental evaluation of a breastfeeding support program for low income women in Michigan. Matern Child Health J.
98 Otsuka K, Taguri M, Dennis CL, et al. (2014). Effectiveness of a breastfeeding self-efficacy intervention: do hospital practices make a difference?. Matern Child Health J.
99 Pannu PK, Giglia RC, Binns CW, et al. (2011). The effectiveness of health promotion materials and activities on breastfeeding outcomes. Acta Paediatr.
100 Petrova A, Ayers C, Stechna S, et al. (2009). Effectiveness of exclusive breastfeeding promotion in low-income mothers: a randomized controlled study. Breastfeed Med.
101 Pincombe J, Baghurst P, Antoniou G, et al. (2008). Baby Friendly Hospital Initiative practices and breast feeding duration in a cohort of first-time mothers in Adelaide, Australia. Midwifery.
102 Pisacane A, Continisio GI, Aldinucci M, et al. (2005). A controlled trial of the father's role in breastfeeding promotion. Pediatrics.
103 Pisacane A, Continisio P, Filosa C, et al. (2012). Use of baby carriers to increase breastfeeding duration among term infants: the effects of an educational intervention in Italy. Acta Paediatr.
104 Pitcock N. (2013). Evaluation of an Initiative to Increase Rates of Exclusive Breastfeeding Among Rural Hispanic Immigrant Women.
105 Pound CM, Moreau K, Rohde K, et al. (2015). Lactation support and breastfeeding duration in jaundiced infants: a randomized controlled trial. PLoS ONE.
106 Preer G, Pisegna JM, Cook JT, et al. (2013). Delaying the bath and in-hospital breastfeeding rates. Breastfeed Med.
107 Price L. (2014). Can early breastfeeding support increase the 6-8 week breastfeeding prevalence rate?. Community Pract.
108 Pugh LC, Milligan RA, Brown LP. (2001). The breastfeeding support team for low-income, predominantly-minority women: a pilot intervention study. Health Care Women Int.
109 Pugh LC, Milligan RA, Frick KD, et al. (2002). Breastfeeding duration, costs, and benefits of a support program for low-income breastfeeding women. Birth.
110 Pugh LC, Serwint JR, Frick KD, et al. (2010). A randomized controlled community-based trial to improve breastfeeding rates among urban low-income mothers. Academic pediatrics.
111 Raisi Dehkordi Z, Raei M, Ghassab Shirazi M, et al. (2012). Effect of Telephone Counseling on Continuity and Duration of Breastfeeding among Primiparus Women. HAYAT.
112 Rasmussen KM, Dieterich CM, Zelek ST, et al. (2011). Interventions to increase the duration of breastfeeding in obese mothers: the Bassett Improving Breastfeeding Study. Breastfeed Med.
113 Rempel LA, McCleary L. (2012). Effects of the implementation of a breastfeeding best practice guideline in a Canadian public health agency. Res Nurs Health.
114 Rempel LA, Moore KC. (2012). Peer-led prenatal breast-feeding education: a viable alternative to nurse-led education. Midwifery.
115 Rojjanasrirat W, Nelson EL, Wambach KA. (2012). A pilot study of home-based videoconferencing for breastfeeding support. J Hum Lact.
116 Rosen IM, Krueger MV, Carney LM, et al. (2008). Prenatal breastfeeding education and breastfeeding outcomes. MCN Am J Matern Child Nurs.
117 Ryser FG. (2004). Breastfeeding attitudes, intention, and initiation in low-income women: the effect of the best start program. J Hum Lact.
118 Salonen AH, Kaunonen M, Astedt-Kurki P, et al. (2011). Effectiveness of an internet-based intervention enhancing Finnish parents' parenting satisfaction and parenting self-efficacy during the postpartum period. Midwifery.
119 Sandy JM, Anisfeld E, Ramirez E. (2009). Effects of a prenatal intervention on breastfeeding initiation rates in a Latina immigrant sample. J Hum Lact.
120 Scheinmann R, Chiasson MA, Hartel D, et al. (2010). Evaluating a bilingual video to improve infant feeding knowledge and behavior among immigrant Latina mothers. J Community Health.
121 Scheiwe A, Hardy R, Watt RG. (2010). Four-year follow-up of a randomized controlled trial of a social support intervention on infant feeding practices. Matern Child Nutr.
122 Schlickau J, Wilson M. (2005). Development and testing of a prenatal breastfeeding education intervention for Hispanic women. J Perinat Educ.
123 Schwartz R, Ellings A, Baisden A, et al. (2015). Washington ‘Steps’ Up: A 10-Step Quality Improvement Initiative to Optimize Breastfeeding Support in Community Health Centers. J Hum Lact.
124 Serrano MS, Doren FM, Wilson L. (2010). Teaching Chilean mothers to massage their full-term infants: effects on maternal breast-feeding and infant weight gain at age 2 and 4 months. J Perinat Neonatal Nurs.
125 Simonetti V, Palma E, Giglio A, et al. (2012). A structured telephonic counselling to promote the exclusive breastfeeding of healthy babies aged zero to six months: a pilot study. Int J Nurs Pract.
126 Skugarevsky O, Wade KH, Richmond RC, et al. (2014). Effects of promoting longer-term and exclusive breastfeeding on childhood eating attitudes: a cluster-randomized trial. Int J Epidemiol.
127 Spinelli MG, Endicott J, Goetz RR. (2013). Increased breastfeeding rates in black women after a treatment intervention. Breastfeed Med.
128 Srinivas GL, Benson M, Worley S, et al. (2014). A Clinic-Based Breastfeeding Peer Counselor Intervention in an Urban, Low-Income Population: Interaction with Breastfeeding Attitude. J Hum Lact.
129 Tarrant M, Lok KY, Fong DY, et al. (2015). Effect of a hospital policy of not accepting free infant formula on in-hospital formula supplementation rates and breast-feeding duration. Public Health Nutr.
130 Tarrant M, Lok KY, Fong DY, et al. (2015). Effect on Baby-Friendly Hospital Steps When Hospitals Implement a Policy to Pay for Infant Formula. J Hum Lact.
131 Tarrant M, Wu KM, Fong DY, et al. (2011). Impact of baby-friendly hospital practices on breastfeeding in Hong Kong. Birth.
132 Taveras EM, Blackburn K, Gillman MW, et al. (2011). First steps for mommy and me: a pilot intervention to improve nutrition and physical activity behaviors of postpartum mothers and their infants. Matern Child Health J.
133 Thomson T, Hall W, Balneaves L, et al. (2009). Waiting to be weighed: a pilot study of the effect of delayed newborn weighing on breastfeeding outcomes. Can Nurse.
134 Thukral A, Sankar MJ, Agarwal R, et al. (2012). Early skin-to-skin contact and breast-feeding behavior in term neonates: a randomized controlled trial. Neonatology.
135 Tohotoa J, Maycock B, Hauck Y, et al. (2011). Supporting mothers to breastfeed: the development and process evaluation of a father inclusive perinatal education support program in Perth, Western Australia. Health Promot Int.
136 Tully KP, Ball HL. (2012). Postnatal unit bassinet types when rooming-in after cesarean birth: implications for breastfeeding and infant safety. J Hum Lact.
137 Vidas M, Folnegovic-Smalc V, Catipovic M, et al. (2011). The application of autogenic training in counseling center for mother and child in order to promote breastfeeding. Coll Antropol.
138 Vitolo MR, Louzada ML, Rauber F. (2014). Positive impact of child feeding training program for primary care health professionals: a cluster randomized field trial. Rev Bras Epidemiol.
139 Walkup JT, Barlow A, Mullany BC, et al. (2009). Randomized controlled trial of a paraprofessional-delivered in-home intervention for young reservation-based American Indian mothers. J Am Acad Child Adolesc Psychiatry.
140 Wallace LM. (2010). An extended midwifery support programme did not increase breast feeding at 6 months, compared with standard postnatal midwifery support. Evid Based Nurs.
141 Watt RG, Tull KI, Hardy R, et al. (2009). Effectiveness of a social support intervention on infant feeding practices: randomised controlled trial. J Epidemiol Community Health.
142 Wen LM, Baur LA, Rissel C, et al. (2012). Healthy Beginnings Trial Phase 2 study: follow-up and cost-effectiveness analysis. Contemp Clin Trials.
143 Wen LM, Baur LA, Simpson JM, et al. (2012). Effectiveness of home based early intervention on children's BMI at age 2: randomised controlled trial. BMJ.
144 Wilhelm SL, Aguirre TM, Koehler AE, et al. (2015). Evaluating Motivational Interviewing to Promote Breastfeeding by Rural Mexican-American Mothers: the Challenge of Attrition. Issues Compr Pediatr Nurs.
145 Wilhelm SL, Stepans MB, Hertzog M, et al. (2006). Motivational interviewing to promote sustained breastfeeding. J Obstet Gynecol Neonatal Nurs.
146 Wilkinson SA, McIntyre HD. (2012). Evaluation of the ‘healthy start to pregnancy’ early antenatal health promotion workshop: a randomized controlled trial. BMC Pregnancy Childbirth.
147 Williams A, Young J, Kearney L, et al. (2013). Improving knowledge of breastfeeding management: a practice development intervention for paediatric nurses. Neonatal, Paediatric & Child Health Nursing.
148 Winterburn S, Moyer J, Thompson J. (2003). Maternal grandmothers and support for breastfeeding. J Community Nurs.
149 Witt AM, Smith S, Mason MJ, et al. (2012). Integrating routine lactation consultant support into a pediatric practice. Breastfeed Med.
150 Wockel A, Abou-Dakn M. (2011). Padiatrische Praxis.
151 Wolfberg AJ, Michels KB, Shields W, et al. (2004). Dads as breastfeeding advocates: results from a randomized controlled trial of an educational intervention. Am J Obstet Gynecol.
152 Youens K, Chisnell D, Marks-Maran D. (2014). Mother-to-mother breastfeeding peer support: The Breast Buddies project. Br J Midwifery.
153 Yun S, Liu Q, Mertzlufft K, et al. (2010). Evaluation of the Missouri WIC (Special Supplemental NutritionProgram for Women, Infants, and Children) breast-feeding peer counselling programme. Public Health Nutr.
154 Zakarija-Grkovic I, Segvic O, Bozinovic T, et al. (2012). Hospital practices and breastfeeding rates before and after the UNICEF/WHO 20-hour course for maternity staff. J Hum Lact.
155 Wockel A, Abou-Dakn M. (2011). Padiatrische Praxis.
156 Wolfberg AJ, Michels KB, Shields W, et al. (2004). Dads as breastfeeding advocates: results from a randomized controlled trial of an educational intervention. Am J Obstet Gynecol.
157 Youens K, Chisnell D, Marks-Maran D. (2014). Mother-to-mother breastfeeding peer support: The Breast Buddies project. Br J Midwifery.
158 Yun S, Liu Q, Mertzlufft K, et al. (2010). Evaluation of the Missouri WIC (Special Supplemental Nutrition Program for Women, Infants, and Children) breast-feeding peer counselling programme. Public Health Nutr.
159 Zakarija-Grkovic I, Segvic O, Bozinovic T, et al. (2012). Hospital practices and breastfeeding rates before and after the UNICEF/WHO 20-hour course for maternity staff. J Hum Lact.