# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

### CINAHL

S53 S44 AND S52
  Limiters - Published Date: 20080101-20151231; English Language
S52 S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51
S51 (TI (systematic* n3 review*)) or (AB (systematic* n3 review*)) or (TI (systematic* n3 bibliographic*)) or (AB (systematic* n3 bibliographic*)) or (TI (systematic* n3 literature)) or (AB (systematic* n3 literature)) or (TI (comprehensive* n3 literature)) or (AB (comprehensive* n3 literature)) or (TI (comprehensive* n3 bibliographic*)) or (AB (comprehensive* n3 bibliographic*)) or (JN “Cochrane Database of Systematic Reviews”) or (TI (information n2 synthesis)) or (TI (data n2 synthesis)) or (AB (information n2 synthesis)) or (AB (data n2 synthesis)) or (TI (data n2 extract*)) or (AB (data n2 extract*)) or (TI (medline or pubmed or psyclit or cinahl or (psycinfo not “psycinfo database”) or “web of science” or scopus or embase)) or (AB (medline or pubmed or psyclit or cinahl or (psycinfo not “psycinfo database”) or “web of science” or scopus or embase)) or (MH “Systematic Review”)
S50 TI ( (“comparison group*” or “control group*”) ) OR AB ( (“comparison group*” or “control group*”) )
S49 TI ( “controlled before and after” ) OR AB ( “controlled before and after” )
S48 TI “controlled before after” OR AB “controlled before after”
S47 (TX cohort OR TI longitudinal OR AB longitudinal OR TI “follow up” OR AB “follow up” OR TI followup OR AB followup)
S46 (MH “Prospective Studies”) OR (MH “Concurrent Prospective Studies”) OR (MH “Nonconcurrent Prospective Studies”) OR (MH “Correlational Studies”)
S45 (MH “Meta Analysis”) OR (MH “Control Group”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Triple-Blind Studies”) OR (MH “Randomized Controlled Trials”) OR (MH “Clinical Trials”) OR (MH “Random Assignment”) OR (AB clinical n1 trial*) OR (AB controlled n1 trial*) OR (TI clinical n1 trial*) OR (TI controlled n1 trial*) OR (PT Clinical trial) OR (PT randomized controlled trial)
S44 S38 OR S39 OR S40 OR S41 OR S42 OR S43
S43 TI ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((intervention* or program* or clinic or clinics or policy or policies or plan*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) )
S42 TI ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) ) OR AB ( ((incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat*) N5 (“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”)) )
S41 (MH “Lactation Consultants”) OR TI “lactation consult*” OR AB “lactation consult*”
S40 (MH “Breast Feeding/ED”)
S39 (MH “Breast Feeding Promotion”)
S38 S6 AND S37
S37 S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36
S36 TI ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) ) OR AB ( ((hospital* or “health system” or “health systems” or “health care system” or “health care systems”) N3 (policy or policies or initiative* or program* or practice*)) )
S35 TI “rooming in” OR AB “rooming in”
S34 TI ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) ) OR AB ( ((“breast feed*” or “breast fed” or breastfeed* or breastfed or lactation) N1 “on demand”) )
S33 TI pacifier* OR AB pacifier*
S32 TI “skin to skin” OR AB “skin to skin”
S31 TI “baby friendly” OR AB “baby friendly”
S30 TI (kangaroo N3 care) OR AB (kangaroo N3 care)
S29 TI ( ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) ) OR AB ( ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth* or “child birth*”) N5 (train* or educat* or teach* or class*)) )
S28 TI ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) ) OR AB ( (((staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*) N5 (train* or educat* or teach* or class*)) )
S27 TI “home visit*” OR AB “home visit*”
S26 TI “social* support*” OR AB “social* support*”
S25 TI “group counsel*” OR AB “group counsel*”
S24 TI “peer counsel*” OR AB “peer counsel*”
S23 TI “motivational interview*” OR AB “motivational interview*”
S22 (MH “Hospital Programs”)
S21 (MH “Program Implementation”)
S20 (MH “Kangaroo Care”) or (MH “Rooming In”)
S19 (MH “Childbirth Education”)
S18 (MH “Parenting Education”)
S17 (MH “Nutritional Counseling”)
S16 (MH “Prenatal Counseling”)
S15 (MH “Patient Discharge Education”)
S14 (MH “Patient Education”)
S13 (MH “Health Education”)
S12 (MH “Nutritional Counseling”)
S11 (MH “Nurse Counselors”)
S10 (MH “Counselors”)
S9 (MH “Motivational Interviewing”)
S8 (MH “Peer Counseling”)
S7 (MH “Counseling”)
S6 S1 OR S2 OR S3 OR S4 OR S5
S5 ( TI “newborn feeding” OR AB “newborn feeding” ) OR ( TI “infant feeding” OR AB “infant feeding” )
S4 TI lactation OR AB lactation
S3 TI (breastfed OR “breast fed”) OR AB (breastfed OR “breast fed”)
S2 TI (breastfeed* OR “breast feed*”) OR AB (breastfeed* OR “breast feed*”)
S1 (MH “Breast Feeding”) OR (MH “Attitude to Breast Feeding”) OR (MH “Breast Feeding Positions”) OR (MH “Latching, Breastfeeding”) OR (MH “Milk Expression”)

### CENTRAL, Issue 9 of 12, September 2015

#1 (breastfeed* or breastfed or “breast fed” or lactation):ti,ab,kw
#2 (breast next feed*):ti,ab,kw
#3 (infant or newborn):ti,ab,kw next feeding:ti,ab,kw
#4 #1 or #2 or #3 3641
#5 (motivational next interview*):ti,ab,kw
#6 (peer next counsel*):ti,ab,kw
#7 (group next counsel*):ti,ab,kw
#8 (social* next support*):ti,ab,kw
#9 (home next visit*):ti,ab,kw
#10 (staff or nurs* or midwife* or midwives or doula* or doctor* or physician* or obstetrician* or pediatrician* or paediatrician*):ti,ab,kw near/5 (train* or educat* or teach* or class*):ti,ab,kw
#11 (prenatal or “pre natal” or postnatal or “post natal” or atenatal or “ante natal” or childbirth* or (child next birth*)) near/5 (train* or educat* or teach* or class*):ti,ab,kw
#12 (kangaroo near/3 care):ti,ab,kw
#13 “baby friendly”:ti,ab,kw
#14 “skin to skin”:ti,ab,kw
#15 pacifier*:ti,ab,kw
#16 (breast next feed*):ti,ab,kw near/3 demand:ti,ab,kw
#17 (breast fed or breastfeed* or breastfed or lactation):ti,ab,kw near/3 demand:ti,ab,kw
#18 “rooming in”:ti,ab,kw
#19 (hospital* or “health system” or “health systems” or “health care system” or “health care systems”):ti,ab,kw near/3 (policy or policies or initiative* or program* or practice*):ti,ab,kw
#20 {or #5-#19}
#21 #4 and #20
#22 (incr* or improv* or support* or promot* or encourag* or counsel* or educat* or train* or teach* or class* or facilitat*):ti,ab,kw near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”):ti,ab,kw
#23 (intervention* or program* or clinic or clinics or policy or policies or plan*):ti,ab,kw near/5 ((breast next feed*) or “breast fed” or breastfeed* or breastfed or lactation or “newborn feeding” or “infant feeding”):ti,ab,kw
#24 (lactation next consult*):ti,ab,kw
#25 #21 or #22 or #23 or #24 Publication Year from 2008 to 2015, in Trials

### Ovid MEDLINE(R), 1946 to September Week 3 2015 Ovid MEDLINE(R) Daily Update, September 24, 2015 Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations, September 24, 2015

1. Breast feeding/
2. Milk, Human/
3. Breast Milk Expression/
4. Lactation/
5. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti.
6. (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab.
7. limit 6 to (“in data review” or in process or “pubmed not medline”)
8. 1 or 2 or 3 or 4 or 5 or 7
9. Health Promotion/
10. Health Education/
11. Patient Education as Topic/
12. Social Support/
13. Counseling/
14. Motivational Interviewing/
15. Prenatal Education/
16. Education, Medical/
17. Kangaroo-Mother Care Method/
18. Attitude of Health Personnel/
19. Organizational Policy/
20. Program development/
21. Pacifiers/
22. motivational interview$.ti,ab.
23. peer counsel$.ti,ab.
24. group counsel$.ti,ab.
25. social$ support$.ti,ab.
26. home visit$.ti,ab.
27. ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab.
28. ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab.
29. (kangaroo adj3 care).ti,ab.
30. baby friendly.ti,ab.
31. skin to skin.ti,ab.
32. pacifier$.ti,ab.
33. ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab.
34. rooming in.ti,ab.
35. ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab.
36. 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35
37. 8 and 36
38. ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab.
39. ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab.
40. lactation consult$.ti,ab.
41. 37 or 38 or 39 or 40
42. limit 41 to systematic reviews
43. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
44. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
45. Random$.ti,ab.
46. control groups/ or double-blind method/ or single-blind method/
47. clinical trial$.ti,ab.
48. controlled trial$.ti,ab.
49. meta analy$.ti,ab.
50. cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/
51. cohort.ti,ab.
52. longitudinal.ti,ab.
53. (follow up or followup).ti,ab.
54. controlled before after.ti,ab.
55. “controlled before and after”.ti,ab.
56. (comparison group$ or control group$).ti,ab.
57. 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
58. 41 and 57
59. 42 or 58
60. Animal/ not (Human/ and Animal/)
61. 59 not 60
62. limit 61 to (english language and yr=“2008 -Current”)
63. remove duplicates from 62

### PsycINFO (via Ovid)

1 Breast Feeding/
2 Lactation/
3 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation).ti,ab,id.
4 1 or 2 or 3
5 Health Promotion/
6 Counseling/
7 Counselors/
8 Motivational Interviewing/
9 Client Education/
10 Health Education/
11 Childbirth Training/
12 Support Groups/
13 Social Support/
14 Prenatal Care/
15 Policy Making/
16 Organizational Behavior/
17 Personnel Training/
18 promotion & maintenance of health & wellness.cc.
19 motivational interview$.ti,ab,id.
20 peer counsel$.ti,ab,id.
21 group counsel$.ti,ab,id.
22 social$ support$.ti,ab,id.
23 home visit$.ti,ab,id.
24 ((staff or nurs$ or midwife$ or midwives or doula$ or doctor$ or physician$ or obstetrician$ or p?ediatrician$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id.
25 ((prenatal or pre natal or postnatal or post natal or atenatal or ante natal or childbirth$ or child birth$) adj5 (train$ or educat$ or teach$ or class$)).ti,ab,id.
26 (kangaroo adj3 care).ti,ab,id.
27 baby friendly.ti,ab,id.
28 skin to skin.ti,ab,id.
29 pacifier$.ti,ab,id.
30 ((breast feed$ or breast fed or breastfeed$ or breastfed or lactation) adj on demand).ti,ab,id.
31 rooming in.ti,ab,id.
32 ((hospital$ or health system$ or health care system$) adj3 (policy or policies or initiative$ or program$ or practice$)).ti,ab,id.
33 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34 4 and 33
35 ((incr$ or improv$ or support$ or promot$ or encourag$ or counsel$ or educat$ or train$ or teach$ or class$ or facilitat$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id.
36 ((intervention$ or program$ or clinic or clinics or policy or policies or plan$) adj5 (breast feed$ or breast fed or breastfeed$ or breastfed or lactation or newborn feeding or infant feeding)).ti,ab,id.
37 lactation consult$.ti,ab,id.
38 34 or 35 or 36 or 37
39 ((comprehensive$ or integrative or systematic$) adj3 (bibliographic$ or review$ or literature)).ti,ab,id.
40 (cinahl or (cochrane adj3 trial*) or embase or medline or psyclit or pubmed or scopus or “sociological abstracts” or “web of science”).ab.
41 (meta-analy$ or metaanaly$ or “research synthesis” or ((information or data) adj3 synthesis) or (data adj2 extract$)).ti,ab,id.
42 (“systematic review” or “meta analysis”).md.
43 random$.ti,ab,id,hw.
44 placebo$.ti,ab,hw,id.
45 controlled trial$.ti,ab,id,hw.
46 clinical trial$.ti,ab,id,hw.
47 treatment outcome clinical trial.md.
48 cohort.ti,ab,id.
49 longitudinal.ti,ab,id.
50 (follow up or followup).ti,ab,id.
51 longitudinal study.md.
52 prospective study.md.
53 retrospective study.md.
54 controlled before after.ti,ab,id.
55 “controlled before and after”.ti,ab,id.
56 (comparison group$ or control group$).ti,ab,id.
57 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
55 38 and 57
59 limit 58 to (english language and yr=“2008 -Current”)

### PubMed (publisher-supplied)

#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #19 AND publisher[sb] AND English[Language] AND (“2008”[Date - Publication] : “3000”[Date - Publication])
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #1 AND #18
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (support*[tiab] OR promot*[tiab] OR counsel*[tiab] OR educat*[tiab] OR intervention*[tiab])
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (hospital[tiab] OR “health system”[tiab] OR “health systems”[tiab] OR “health care system”[tiab] OR “health care systems”[tiab]) AND (policy[tiab] OR policies[tiab] OR initiative*[tiab] OR program*[tiab])
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “rooming in”[tiab]
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “on demand”[tiab]
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search pacifier*[tiab]
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “skin to skin”[tiab]
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “baby friendly”[tiab]
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (kangaroo[tiab] AND care[tiab])
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (prenatal[tiab] OR “pre natal”[tiab] OR postnatal[tiab] OR “post natal”[tiab] OR antenatal[tiab] OR “ante natal”[tiab]) AND (train*[tiab] OR educat*[tiab])
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (staff[tiab] OR nurs*[tiab] OR midwife*[tiab] OR midwives[tiab] OR doula*[tiab] OR doctor*[tiab] OR physician*[tiab] OR obstetrician*[tiab] OR pediatrician*[tiab]) AND (train*[tiab] OR educat*[tiab])
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search home visit*[tiab]
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search social support*[tiab]
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search group counsel*[tiab]
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search peer counsel*[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search motivational interview*[tiab]
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search lactation consult*[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (“breast feed”[tiab] OR “breast feeds”[tiab] OR “breast feeding”[tiab] OR breastfeed*[tiab] OR “breast fed”[tiab] OR lactation[tiab] OR newborn feeding*[tiab] OR infant feeding*[tiab])

Appendix A Figure 1 Literature Flow Diagram

* Two studies were reported in a single publication.

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 2708 citations identified through literature databases. An additional 19 citations were identified from outside sources, such as reference lists and suggestions from peer reviewers, and 42 citations were from the 2008 USPSTF review. After duplicates were removed, 2769 unique citations were screened at the title/abstract stage. The full text of 211 citations were examined for inclusion for one or more of the Key Questions. The following number of articles were included for Key Question 1 (k=7), Key Question 2 (k=57), and Key Question 3 (k=2). Reasons for excluding the other articles are available in Appendix B.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Study design | - Randomized, controlled trials; cluster randomized, controlled trials; - Controlled before-and-after studies and prospective cohort studies of hospital policies and health system interventions (e.g., the Baby-Friendly Hospital Initiative^*^, provider training); - Systematic evidence reviews | - Observational studies (except studies of hospital policies); - Abstracts, editorials, or theses
Study aim | Studies targeting the effects of prenatal, peripartum, and postpartum breastfeeding interventions on child and maternal health outcomes and/or initiation, duration, and exclusivity of breastfeeding | Studies with breastfeeding as a secondary outcome, in which the intervention was not specifically targeted at breastfeeding (e.g., studies on increasing the frequency of prenatal visits)
Condition | Breastfeeding (including baby to breast, bottle feeding mother's expressed breast milk, and bottle feeding donated breast milk) | Studies with a focus on other forms of infant nutrition (e.g., formula)
Population | - Early-term (37 0/7 to 38 6/7 weeks), full-term (39 0/7 to 40 6/7 weeks), late-term (41 0/7 to 41 6/7 weeks), and post-term (42 0/7 weeks and beyond) newborns, as well as late-preterm newborns with gestational age ≥34 0/7 weeks or birth weight >2,500 g; - Members of mother-child support system (e.g., partners, grandparents, or friends) | - Mothers of preterm or very preterm newborns (<34 weeks of gestation or low or very low birth weight [<2,500 g]), because of their special feeding needs; - Studies limited to special populations of women or infants (e.g., institutionalized women, infants with prenatal disease, infants born to drug-using mothers, infants in a neonatal intensive care unit, infants born to HIV-positive mothers)
Interventions | - Intervention must be initiated in, conducted in, or referable from primary care (e.g., primary care referral of mother-infant pair or family to service, support provided in hospital setting at time of delivery or postpartum, primary care collaboration with community services); - Type of interventions may include, but are not limited to: individual or group counseling, peer counseling, home visits, structured education, technology- or computer-based support, distribution of written materials, rooming-in, restricted pacifier use, or skin-to-skin contact; - Interventions may take place during the prenatal and/or postnatal period; - Stand-alone or multicomponent/multidimensional interventions; - Interventions may be conducted by, but are not limited to: lactation care providers, nurses/nurse practitioners, peer counselors, midwives, doulas, or physicians; - Health care system interventions (e.g., staff training) and hospital policies, such as full or partial implementation of the Baby-Friendly Hospital Initiative^*^ | - Mass media campaigns; - Worksite lactation programs; - Community interventions not affiliated with primary care
Setting | - Any setting linked with the health care system and provision of primary care (e.g., hospital, maternity services, home, clinic, or community); - Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Programme) | - Correctional facilities; - Worksites; - Inpatient/residential facilities; - Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Comparators | - Usual prenatal, peripartum, and/or postpartum care, as defined within each study; - Another breastfeeding intervention (i.e., comparative effectiveness); - Wait list control; - No attention control
Outcomes | KQ 1: Maternal health outcomes associated with breastfeeding intervention (e.g., cessation of menses); child health outcomes associated with breastfeeding intervention (e.g., gastrointestinal symptoms, atopic dermatitis, respiratory symptoms, otitis media, asthma, obesity) KQ 2: Breastfeeding initiation, duration, or exclusivity, as defined within each study KQ 3: Adverse events associated with breastfeeding intervention (e.g., feeling criticized by interventionist, guilt related to not breastfeeding, increased anxiety about breastfeeding, postpartum depression, infant failure to thrive)
Publication language | English | Languages other than English
Quality | Fair or good | Poor (according to design-specific USPSTF criteria)

* The “10 Steps to Successful Breastfeeding,” as designated by the Baby-Friendly Hospital Initiative, are: 1) maintain a written breastfeeding policy that is routinely communicated to all health care staff; 2) train all health care staff in skills necessary to implement this policy; 3) inform all pregnant women about the benefits and management of breastfeeding; 4) help mothers initiate breastfeeding within 1 hour of birth; 5) show mothers how to breastfeed and how to maintain lactation, even if they are separated from their infants; 6) give infants no food or drink other than breast milk, unless medically indicated; 7) practice “rooming-in” (allowing mothers and infants to remain together 24 hours a day); 8) encourage breastfeeding on demand; 9) give no pacifiers or artificial nipples to breastfeeding infants; and 10) foster the establishment of breastfeeding support groups and refer mothers to them upon discharge from the hospital or clinic.

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized, controlled trials, adapted from the U.S. Preventive Services Task Force methods^192^ | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was there a difference in attrition between groups?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there risk of contamination?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?; - Was there a clear definition of the intervention?; - Was the funding source defined?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^193^ | - Was there representativeness of the exposed cohort?; - Was the non-exposed systematically selected?; - Was the ascertainment of exposure reported?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid and reliable?; - Were outcome assessors blinded?; - Was followup long enough for the outcome to occur?; - Was there acceptable followup?; - Was the handling of missing data appropriate?; - Were baseline characteristics well described?; - Was the inclusion/exclusion criteria well described?