# References

1 Centers for Disease Control and Prevention (CDC). Latent Tuberculosis Infection: A Guide for Primary Health Care Providers. Developed in partnership with the New Jersey Medical School Global Tuberculosis Institute. Atlanta, GA. CDC, National Centers for H IV/AIDS, Viral Hepatitis, STD, and TB Prevention. 2013. http://www.cdc.gov/tb/publications/LTBI/default.htm.
2 Grzybowski S, Barnett GD, Styblo K. Contacts of cases of active pulmonary tuberculosis. Bull Int Union Tuberc. 1975;50(1):90-106. [pmid: 1218291].
3 Marks SM, Taylor Z, Qualls NL, et al. Outcomes of contact investigations of infectious tuberculosis patients. Am J Respir Crit Care Med. Dec. 2000;162(6):2033-8. [pmid: 11112109].
4 Huybrechts KF, Rothman KJ, Silliman RA, et al. Risk of death and hospital admission for major medical events after initiation of psychotropic medications in older adults admitted to nursing homes. CMAJ. Apr. 19. 2011;183(7):E411-9. [pmid: 21444611].
5 Ferebee SH. Controlled chemoprophylaxis trials in tuberculosis. A general review. Bibl Tuberc. 1970;26:28-106. [pmid: 4903501].
6 Horsburgh CR Jr. Priorities for the treatment of latent tuberculosis infection in the United States. N Engl J Med. May. 13. 2004;350(20):2060-7. [pmid: 15141044].
7 Sloot R, Schim van der Loeff MF, Kouw PM, et al. Risk of tuberculosis after recent exposure. A 10-year follow-up study of contacts in Amsterdam. Am J Respir Crit Care Med. Nov. 1. 2014;190(9):1044-52. [pmid: 25265362].
8 Shea KM, Kammerer JS, Winston CA, et al. Estimated rate of reactivation of latent tuberculosis infection in the United States, overall and by population subgroup. Am J Epidemiol. Jan. 15. 2014;179(2):216-25. [pmid: 24142915].
9 American Thoracic Society, Centers for Disease Control and Prevention. Targeted tuberculin testing and treatment of latent tuberculosis infection. MMWR Recomm Rep. Jun. 9. 2000;49(RR-6):1-51. [pmid: 10881762].
10 Getahun H, Matteelli A, Chaisson RE, et al. Latent Mycobacterium tuberculosis infection. N Engl J Med. May. 28. 2015;372(22):2127-35. [pmid: 26017823].
11 Lindsay RP, Shin SS, Garfein RS, et al. The association between active and passive smoking and latent tuberculosis infection in adults and children in the United States: results from NHANES. PLoS One. Mar. 24. 2014;9(3):e93137. [pmid: 24664240].
12 Horsburgh CR Jr., Rubin EJ. Clinical practice. Latent tuberculosis infection in the United States. N Engl J Med. Apr. 14. 2011;364(15):1441-8. [pmid: 21488766].
13 Centers for Disease Control and Prevention (CDC). Data and Statistics. Atlanta, GA. CDC. 2014. March. 7. http://www.cdc.gov/tb/statistics/default.htm. May 22, 2015.
14 Salinas JL, Mindra G, Haddad MB, et al. Leveling of tuberculosis incidence - United States, 2013-2015. MMWR Morb Mortal Wkly Rep. 2016;65(11):273-8. [pmid: 27010173].
15 Centers for Disease Control and Prevention. Fact Sheet: Trends in Tuberculosis, 2014. Atlanta, GA. Centers for Disease Control and Prevention. 2014. September. 24. 2015. http://www.cdc.gov/tb/publications/factsheets/statistics/tbtrends.htm. April 28, 2016.
16 Centers for Disease Control and Prevention. National Tuberculosis Indicators. 2013. State Comparison. Atlanta, GA. CDC, National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention, Division of Tuberculoris Elimination. http://www.cdc.gov/tb/statistics/pdf/statetbindicators_2013statecomparison_final.pdf. 8 Jun 2015.
17 World Health Organization. Global tuberculosis report 2014. World Health Organization. WHO/HTM/TB/2014.08. Geneva, Switzerland. 2014. http://www.who.int/tb/publications/global_report/en/.
18 Scott C, Kirking HL, Jeffries C, et al. Tuberculosis trends--United States, 2014. MMWR Morb Mortal Wkly Rep. Mar. 20. 2015;64(10):265-9. [pmid: 25789741].
19 Centers for Disease Control and Prevention. Tuberculosis (TB) (Mycobacterium tuberculosis). Atlanta, GA. Centers for Disease Control and Prevention. 2015. May. 6. http://wwwn.cdc.gov/nndss/conditions/tuberculosis/. 8 June 2015.
20 Miramontes R, Hill AN, Yelk Woodruff RS, et al. Tuberculosis Infection in the United States: Prevalence Estimates from the National Health and Nutrition Examination Survey, 2011-2012. PLoS One. 2015;10(11):e0140881. [pmid: 26536035].
21 McAdam JM, Bucher SJ, Brickner PW, et al. Latent tuberculosis and active tuberculosis disease rates among the homeless, New York, New York, USA, 1992-2006. Emerg Infect Dis. Jul. 2009;15(7):1109-11. [pmid: 19624932].
22 Advisory Council for the Elimination of Tuberculosis (ACET). Tuberculosis elimination revisited: obstacles, opportunities, and a renewed commitment. MMWR Recomm Rep. Aug. 13. 1999;48(RR-9):1-13. [pmid: 10485562].
23 Geiter L, editor. Ending neglect: the elimination of tuberculosis in the United States. Washington, DC. National Academy Press. 2000.
24 Comstock GW, Edwards LB, Philip RN, et al. A comparison in the United States of America of two tuberculins, PPD-S and RT 23. Bull World Health Organ. 1964;31:161-70. [pmid: 14253239].
25 Lee E, Holzman RS. Evolution and current use of the tuberculin test. Clin Infect Dis. Feb. 1. 2002;34(3):365-70. [pmid: 11774084].
26 Mazurek GH, Jereb J, Vernon A, et al. Updated guidelines for using Interferon Gamma Release Assays to detect Mycobacterium tuberculosis infection - United States, 2010. MMWR Recomm Rep. Jun. 25. 2010;59(RR-5):1-25. [pmid: 20577159].
27 Taylor Z, Nolan CM, Blumberg HM. Controlling tuberculosis in the United States. Recommendations from the American Thoracic Society, CDC, and the Infectious Diseases Society of America. MMWR Recomm Rep. Nov. 4. 2005;54(Rr-12):1-81. [pmid: 16267499].
28 Centers for Disease Control and Prevention. Recommendations for use of an isoniazid-rifapentine regimen with direct observation to treat latent Mycobacterium tuberculosis infection. MMWR Morb Mortal Wkly Rep. Dec. 9. 2011;60(48):1650-3. [pmid: 22157884].
29 World Health Organization. 2, Recommendations. Guidelines on the Management of Latent Tuberculosis Infection. Geneva. World Health Organization. 2015.
30 World Health Organization. Tuberculosis Country Profiles. Geneva, Switzerland. World Health Organization. 2014. www.who.int/tb/country/data/profiles/en/. 21 May 2015.
31 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
32 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Paper AHRQ Publication No. 10-EHC070-EF. Rockville MD. Agency for Healthcare Research and Quality. September. 2010. http://effectivehealthcare.ahrq.gov/. [pmid: 21433337].
33 Nyaga VN, Arbyn M, Aerts M. Metaprop: a Stata command to perform meta-analysis of binomial data. Arch Public Health. 2014;72(1):39. [pmid: 25810908].
34 TSPOT. TB Package Insert UK. Oxfordshire, UK. Oxford Immunotec Ltd. 2013. http://www.oxfordimmunotec.com/international/wp-content/uploads/sites/3/PI-TB-IVD-UK-V2.pdf\. 4 May 2015.
35 T-SPOT.TB. Package Insert US. Oxfordshire, UK. Oxford Immunotec. 2013. http://www.oxfordimmunotec.com/international/wp-content/uploads/sites/3/PI-TB-IVD-UK-V2.pdf. 4 May 2015.
36 Kontopantelis E, Reeves D. metaan: random-effects meta-analysis. Stata J. 2010;10(3):395-407.
37 Kontopantelis E, Springate DA, Reeves D. A re-analysis of the Cochrane Library data: the dangers of unobserved heterogeneity in meta-analyses. PLoS One. 2013;8(7):e69930. [pmid: 23922860].
38 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. Mar. 30. 1996;15(6):619-29. [pmid: 8731004].
39 Jackson D, White IR, Thompson SG. Extending DerSimonian and Laird's methodology to perform multivariate random effects meta-analyses. Stat Med. May. 30. 2010;29(12):1282-97. [pmid: 19408255].
40 Cornell JE, Mulrow CD, Localio R, et al. Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. Feb. 18. 2014;160(4):267-70. [pmid: 24727843].
41 Falk A, Fuchs GF. Prophylaxis with isoniazid in inactive tuberculosis. A Veterans Administration Cooperative Study XII. Chest. Jan. 1978;73(1):44-8. [pmid: 340155].
42 Veening GJ. Long term isoniazid prophylaxis. Controlled trial on INH prophylaxis after recent tuberculin conversion in young adults. Bull Int Union Tuberc. Dec. 1968;41:169-71. [pmid: 4885378].
43 Bush OB Jr., Sugimoto M, Fujii Y, et al. Isoniazid prophylaxis in contacts of persons with known tuberculosis. Second report. Am Rev Respir Dis. Nov. 1965;92(5):732-40. [pmid: 5321147].
44 Ferebee SH, Mount FW, Murray FJ, et al. A controlled trial of isoniazid prophylaxis in mental institutions. Am Rev Respir Dis. Aug. 1963;88:161-75. [pmid: 14045220].
45 Sutton AJ, Abrams KR, Jones DR, et al. Methods for meta-analysis in medical research. Wiley Series in Probability and Statistics - Applied Probability and Statistics Section. London. Wiley. 2000.
46 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
47 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
48 Higgins JPT, Green S. Cochrane Handbook for Systematic Reviews of Interventions: The Cochrane Collaboration. London. The Cochrane Collaboration. 2014. 17. April. 2015. www.cochrane-handbook.org. 26 May 2015.
49 Rücker G, Schwarzer G, Carpenter JR, et al. Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. [pmid: 19036172].
50 StataCorp. Stata Statistical Software: Release 13.1. College Station, TX. StataCorp LP. 2013.
51 Painter JA, Graviss EA, Hai HH, et al. Tuberculosis screening by tuberculosis skin test or QuantiFERON-TB Gold In-Tube Assay among an immigrant population with a high prevalence of tuberculosis and BCG vaccination. PLoS One. 12. 19. 2013;8(12):e82727. [pmid: 24367546].
52 Seibert AF, Haynes J Jr., Middleton R, et al. Tuberculous pleural effusion. Twenty-year experience. Chest. Apr. 1991;99(4):883-6. [pmid: 1901261].
53 Fietta A, Meloni F, Cascina A, et al. Comparison of a whole-blood interferon-gamma assay and tuberculin skin testing in patients with active tuberculosis and individuals at high or low risk of Mycobacterium tuberculosis infection. Am J Infect Control. Oct. 2003;31(6):347-53. [pmid: 14608301].
54 Berkel GM, Cobelens FG, de Vries G, et al. Tuberculin skin test: estimation of positive and negative predictive values from routine data. Int J Tuberc Lung Dis. Mar. 2005;9(3):310-6. [pmid: 15786896].
55 Kang YA, Lee HW, Yoon HI, et al. Discrepancy between the tuberculin skin test and the whole-blood interferon gamma assay for the diagnosis of latent tuberculosis infection in an intermediate tuberculosis-burden country. JAMA. Jun. 8. 2005;293(22):2756-61. [pmid: 15941805].
56 Goletti D, Carrara S, Vincenti D, et al. Accuracy of an immune diagnostic assay based on RD1 selected epitopes for active tuberculosis in a clinical setting: a pilot study. Clin Microbiol Infect. Jun. 2006;12(6):544-50. [pmid: 16700703].
57 Tsiouris SJ, Coetzee D, Toro PL, et al. Sensitivity analysis and potential uses of a novel gamma interferon release assay for diagnosis of tuberculosis. J Clin Microbiol. Aug. 2006;44(8):2844-50. [pmid: 16891501].
58 Adetifa IM, Lugos MD, Hammond A, et al. Comparison of two interferon gamma release assays in the diagnosis of Mycobacterium tuberculosis infection and disease in The Gambia. BMC Infect Dis. 2007;7:122. [pmid: 17961228].
59 Dewan PK, Grinsdale J, Kawamura LM. Low sensitivity of a whole-blood interferon-gamma release assay for detection of active tuberculosis. Clin Infect Dis. Jan. 1. 2007;44(1):69-73. [pmid: 17143818].
60 Janssens JP, Roux-Lombard P, Perneger T, et al. Quantitative scoring of an interferon-gamma assay for differentiating active from latent tuberculosis. Eur Respir J. Oct. 2007;30(4):722-8. [pmid: 17537773].
61 Losi M, Bossink A, Codecasa L, et al. Use of a T-cell interferon-gamma release assay for the diagnosis of tuberculous pleurisy. Eur Respir J. Dec. 2007;30(6):1173-9. [pmid: 17715165].
62 Mazurek GH, Weis SE, Moonan PK, et al. Prospective comparison of the tuberculin skin test and 2 whole-blood interferon-gamma release assays in persons with suspected tuberculosis. Clin Infect Dis. Oct. 1. 2007;45(7):837-45. [pmid: 17806047].
63 Pai M, Joshi R, Bandyopadhyay M, et al. Sensitivity of a whole-blood interferon-gamma assay among patients with pulmonary tuberculosis and variations in T-cell responses during anti-tuberculosis treatment. Infection. Apr. 2007;35(2):98-103. [pmid: 17401714].
64 Chee CB, Gan SH, Khinmar KW, et al. Comparison of sensitivities of two commercial gamma interferon release assays for pulmonary tuberculosis. J Clin Microbiol. Jun. 2008;46(6):1935-40. [pmid: 18400912].
65 Harada N, Higuchi K, Yoshiyama T, et al. Comparison of the sensitivity and specificity of two whole blood interferon-gamma assays for M. tuberculosis infection. J Infect. May. 2008;56(5):348-53. [pmid: 18395264].
66 Kobashi Y, Mouri K, Yagi S, et al. Usefulness of the QuantiFERON TB-2G test for the differential diagnosis of pulmonary tuberculosis. Intern Med. 2008;47(4):237-43. [pmid: 18277023].
67 Kobashi Y, Mouri K, Yagi S, et al. Clinical evaluation for diagnosing active TB disease and transitional change of two commercial blood tests. Scand J Infect Dis. 2008;40(8):629-34. [pmid: 18642159].
68 Kobashi Y, Mouri K, Yagi S, et al. Clinical utility of the QuantiFERON TB-2G test for elderly patients with active tuberculosis. Chest. May. 2008;133(5):1196-202. [pmid: 18263689].
69 Soysal A, Torun T, Efe S, et al. Evaluation of cut-off values of interferon-gamma-based assays in the diagnosis of M. tuberculosis infection. Int J Tuberc Lung Dis. Jan. 2008;12(1):50-6. [pmid: 18173877].
70 Ak O, Dabak G, Ozer S, et al. The evaluation of the Quantiferon-TB Gold test in pulmonary and extrapulmonary tuberculosis. Jpn J Infect Dis. Mar. 2009;62(2):149-51. [pmid: 19305058].
71 Higuchi K, Kawabe Y, Mitarai S, et al. Comparison of performance in two diagnostic methods for tuberculosis infection. Med Microbiol Immunol. Feb. 2009;198(1):33-7. [pmid: 19034505].
72 Kobashi Y, Sugiu T, Shimizu H, et al. Clinical evaluation of the T-SPOT.TB test for patients with indeterminate results on the QuantiFERON TB-2G test. Intern Med. 2009;48(3):137-42. [pmid: 19182423].
73 Park SY, Jeon K, Um SW, et al. Clinical utility of the QuantiFERON-TB Gold In-Tube test for the diagnosis of active pulmonary tuberculosis. Scand J Infect Dis. 2009;41(11-12):818-22. [pmid: 19922063].
74 Bocchino M, Chairadonna P, Matarese A, et al. Limited usefulness of QuantiFERON-TB Gold In-Tube for monitoring anti-tuberculosis therapy. Respir Med. Oct. 2010;104(10):1551-6. [pmid: 20542675].
75 Dilektasli AG, Erdem E, Durukan E, et al. Is the T-cell-based interferon-gamma releasing assay feasible for diagnosis of latent tuberculosis infection in an intermediate tuberculosis-burden country?. Jpn J Infect Dis. Nov. 2010;63(6):433-6. [pmid: 21099095].
76 Legesse M, Ameni G, Mamo G, et al. Performance of QuantiFERON-TB Gold In-Tube (QFTGIT) for the diagnosis of Mycobacterium tuberculosis (Mtb) infection in Afar Pastoralists, Ethiopia. BMC Infect Dis. 2010;10:354. [pmid: 21162756].
77 Metcalfe JZ, Cattamanchi A, Vittinghoff E, et al. Evaluation of quantitative IFN-gamma response for risk stratification of active tuberculosis suspects. Am J Respir Crit Care Med. Jan. 1. 2010;181(1):87-93. [pmid: 19797760].
78 Tan CK, Lai CC, Chen HW, et al. Enzyme-linked immunospot assay for interferon-gamma to support the diagnosis of tuberculosis in diabetic patients. Scand J Infect Dis. Oct. 2010;42(10):752-6. [pmid: 20513167].
79 Boyd AE, Ashcroft A, Lipman M, et al. Limited added value of T-SPOT.TB blood test in diagnosing active TB: a prospective bayesian analysis. J Infect. Jun. 2011;62(6):456-61. [pmid: 21570124].
80 Cho OH, Park KH, Kim SM, et al. Diagnostic performance of T-SPOT.TB for extrapulmonary tuberculosis according to the site of infection. J Infect. Nov. 2011;63(5):362-9. [pmid: 21781986].
81 Kim EY, Park MS, Kim YS, et al. Risk factors for false-negative results of QuantiFERON-TB Gold In-Tube assay in non-HIV-infected patients with culture-confirmed tuberculosis. Diagn Microbiol Infect Dis. Jul. 2011;70(3):324-9. [pmid: 21546200].
82 Lai CC, Tan CK, Lin SH, et al. Diagnostic value of an enzyme-linked immunospot assay for interferon-gamma in cutaneous tuberculosis. Diagn Microbiol Infect Dis. May. 2011;70(1):60-4. [pmid: 21513844].
83 Lai CC, Tan CK, Lin SH, et al. Diagnostic performance of whole-blood interferon-gamma assay and enzyme-linked immunospot assay for active tuberculosis'. Diagn Microbiol Infect Dis. Oct. 2011;71(2):139-43. [pmid: 21840675].
84 Lui G, Lee N, Cheung SW, et al. Interferon gamma release assay for differentiating tuberculosis among pneumonia cases in acute healthcare setting. J Infect. Jun. 2011;62(6):440-7. [pmid: 21575991].
85 Ra SW, Lyu J, Choi CM, et al. Distinguishing tuberculosis from Mycobacterium avium complex disease using an interferon-gamma release assay. Int J Tuberc Lung Dis. May. 2011;15(5):635-40. [pmid: 21756514].
86 Ruhwald M, Dominguez J, Latorre I, et al. A multicentre evaluation of the accuracy and performance of IP-10 for the diagnosis of infection with M. tuberculosis. Tuberculosis (Edinb). May. 2011;91(3):260-7. [pmid: 21459676].
87 Walsh MC, Camerlin AJ, Miles R, et al. The sensitivity of interferon-gamma release assays is not compromised in tuberculosis patients with diabetes. Int J Tuberc Lung Dis. Feb. 2011;15(2):179-84. i. iii. [pmid: 21219678].
88 Kobashi Y, Abe M, Mouri K, et al. Usefulness of tuberculin skin test and three interferon-gamma release assays for the differential diagnosis of pulmonary tuberculosis. Intern Med. 2012;51(10):1199-205. [pmid: 22687790].
89 Lee J, Lee SY, Won DI, et al. Comparison of whole-blood interferon-gamma assay and flow cytometry for the detection of tuberculosis infection. J Infect. Apr. 2013;66(4):338-45. [pmid: 23010554].
90 Taki-Eddin L, Monem F. Utility of an interferon-gamma release assay as a potential diagnostic aid for active pulmonary tuberculosis. J Infect Dev Ctries. Jan. 2012;6(1):67-72. [pmid: 22240431].
91 Feng JY, Huang SF, Lee MC, et al. Characteristics of IFN-gamma responses in IGRA among pulmonary TB suspects in a TB-endemic area. Diagn Microbiol Infect Dis. Sep. 2013;77(1):46-52. [pmid: 23867329].
92 Jeon YL, Nam YS, You E, et al. Factors influencing discordant results of the QuantiFERON-TB Gold In-tube test in patients with active TB. J Infect. Oct. 2013;67(4):288-93. [pmid: 23796867].
93 Kim S, Kim YK, Lee H, et al. Interferon gamma mRNA quantitative real-time polymerase chain reaction for the diagnosis of latent tuberculosis: a novel interferon gamma release assay. Diagn Microbiol Infect Dis. Jan. 2013;75(1):68-72. [pmid: 23102550].
94 Min JW, Lee HY, Lee JS, et al. Effect of prolonged incubation time on results of the QuantiFERON TB gold in-tube assay for diagnosis of latent tuberculosis infection. Clin Vaccine Immunol. Sep. 2013;20(9):1377-80. [pmid: 23825190].
95 Qian F, Wang W, Qiu Z, et al. Evaluation of a new tuberculosis-related interferon gamma release assay for tuberculosis infection diagnosis in Huzhou, eastern China. Indian J Pathol Microbiol. Apr-Jun. 2013;56(2):125-8. [pmid: 24056648].
96 Wang S, Chen J, Zhang Y, et al. Mycobacterium tuberculosis region of difference (RD) 2 antigen Rv1985c and RD11 antigen Rv3425 have the promising potential to distinguish patients with active tuberculosis from M. bovis BCG-vaccinated individuals. Clin Vaccine Immunol. Jan. 2013;20(1):69-76. [pmid: 23136116].
97 Lee YJ, Lee J, Kim YY, et al. Performance of whole-blood interferon-gamma release assay in patients admitted to the emergency department with pulmonary infiltrates. BMC Infect Dis. 2011;11:107. [pmid: 21513568].
98 Wlodarczyk M, Rudnicka W, Janiszewska-Drobinska B, et al. Interferon-gamma assay in combination with tuberculin skin test are insufficient for the diagnosis of culture-negative pulmonary tuberculosis. PLoS One. 2014;9(9):e107208. [pmid: 25221998].
99 Erdem H, Ozturk-Engin D, Elaldi N, et al. The microbiological diagnosis of tuberculous meningitis: results of Haydarpasa-1 study. Clin Microbiol Infect. Oct. 2014;20(10):O600-8. [pmid: 24849547].
100 Kim CH, Lim JK, Yoo SS, et al. Diagnostic performance of the QuantiFERON-TB Gold In-Tube assay and factors associated with nonpositive results in patients with miliary tuberculosis. Clin Infect Dis. Apr. 2014;58(7):986-9. [pmid: 24457341].
101 Memish ZA, Mah MW, Mahmood SA, et al. Clinico-diagnostic experience with tuberculous lymphadenitis in Saudi Arabia. Clin Microbiol Infect. Mar. 2000;6(3):137-41. [pmid: 11168089].
102 Kang YA, Lee HW, Hwang SS, et al. Usefulness of whole-blood interferon-gamma assay and interferon-gamma enzyme-linked immunospot assay in the diagnosis of active pulmonary tuberculosis. Chest. Sep. 2007;132(3):959-65. [pmid: 17505029].
103 Ozekinci T, Ozbek E, Celik Y. Comparison of tuberculin skin test and a specific T-cell-based test, T-SPOT.TB, for the diagnosis of latent tuberculosis infection. J Int Med Res. Sep-Oct. 2007;35(5):696-703. [pmid: 17944056].
104 Eum SY, Lee YJ, Kwak HK, et al. Evaluation of the diagnostic utility of a whole-blood interferon-gamma assay for determining the risk of exposure to Mycobacterium tuberculosis in Bacille Calmette-Guerin (BCG)-vaccinated individuals. Diagn Microbiol Infect Dis. Jun. 2008;61(2):181-6. [pmid: 18296002].
105 Palazzo R, Spensieri F, Massari M, et al. Use of whole-blood samples in in-house bulk and single-cell antigen-specific gamma interferon assays for surveillance of Mycobacterium tuberculosis infections. Clin Vaccine Immunol. Feb. 2008;15(2):327-37. [pmid: 18032595].
106 Kalantri Y, Hemvani N, Chitnis DS. Evaluation of whole blood IFNgamma test using PPD and recombinant antigen challenge for diagnosis of pulmonary and extra-pulmonary tuberculosis. Indian J Exp Biol. Jun. 2009;47(6):463-8. [pmid: 19634712].
107 Kobashi Y, Shimizu H, Ohue Y, et al. False negative results of QuantiFERON TB-2G test in patients with active tuberculosis. Jpn J Infect Dis. Jul. 2009;62(4):300-2. [pmid: 19628910].
108 Shalabi NM, Houssen ME. Discrepancy between the tuberculin skin test and the levels of serum interferon-gamma in the diagnosis of tubercular infection in contacts. Clin Biochem. Nov. 2009;42(16-17):1596-601. [pmid: 19732759].
109 Shrestha R, Gyawali P, Yadav BK, et al. In-vitro assessment of cell-mediated immunity by demonstrating effector-t cells for diagnosis of tuberculosis in Nepalese subjects. Nepal Med Coll J. Dec. 2011;13(4):275-8. [pmid: 23016479].
110 Li H, Yang L, Zheng CY, et al. Use of bronchoalveolar lavage enzyme-linked immunospot for diagnosis of smear-negative pulmonary tuberculosis. Int J Tuberc Lung Dis. Dec. 2012;16(12):1668-73. [pmid: 23131267].
111 Turtle L, Kemp T, Davies GR, et al. In routine UK hospital practice T-SPOT.TB is useful in some patients with a modest pre-test probability of active tuberculosis. Eur J Intern Med. Jun. 2012;23(4):363-7. [pmid: 22560387].
112 Kamiya H, Ikushima S, Kondo K, et al. Diagnostic performance of interferon-gamma release assays in elderly populations in comparison with younger populations. J Infect Chemother. Apr. 2013;19(2):217-22. [pmid: 23108426].
113 Villarino ME, Burman W, Wang YC, et al. Comparable specificity of 2 commercial tuberculin reagents in persons at low risk for tuberculous infection. JAMA. Jan. 13. 1999;281(2):169-71. [pmid: 9917121].
114 Villarino ME, Brennan MJ, Nolan CM, et al. Comparison testing of current (PPD-S1) and proposed (PPD-S2) reference tuberculin standards. Am J Respir Crit Care Med. Apr. 2000;161(4 Pt 1):1167-71. [pmid: 10764307].
115 Mazurek GH, LoBue PA, Daley CL, et al. Comparison of a whole-blood interferon gamma assay with tuberculin skin testing for detecting latent Mycobacterium tuberculosis infection. JAMA. Oct. 10. 2001;286(14):1740-7. [pmid: 11594899].
116 Bellete B, Coberly J, Barnes GL, et al. Evaluation of a whole-blood interferon-gamma release assay for the detection of Mycobacterium tuberculosis infection in 2 study populations. Clin Infect Dis. Jun. 1. 2002;34(11):1449-56. [pmid: 12015690].
117 Taggart EW, Hill HR, Ruegner RG, et al. Evaluation of an in vitro assay for gamma interferon production in response to Mycobacterium tuberculosis infections. Clin Diagn Lab Immunol. Nov. 2004;11(6):1089-93. [pmid: 15539511].
118 Taggart EW, Hill HR, Ruegner RG, et al. Evaluation of an in vitro assay for interferon gamma production in response to the Mycobacterium tuberculosis-synthesized peptide antigens ESAT-6 and CFP-10 and the PPD skin test. Am J Clin Pathol. Mar. 2006;125(3):467-73. [pmid: 16613353].
119 Bua A, Molicotti P, Delogu G, et al. QuantiFERON TB Gold: a new method for latent tuberculosis infection. New Microbiol. Oct. 2007;30(4):477-80. [pmid: 18080685].
120 Mazurek GH, Zajdowicz MJ, Hankinson AL, et al. Detection of Mycobacterium tuberculosis infection in United States Navy recruits using the tuberculin skin test or whole-blood interferon-gamma release assays. Clin Infect Dis. Oct. 1. 2007;45(7):826-36. [pmid: 17806046].
121 Bienek DR, Chang CK. Evaluation of an interferon-gamma release assay, T-SPOT.TB, in a population with a low prevalence of tuberculosis. Int J Tuberc Lung Dis. Nov. 2009;13(11):1416-21. [pmid: 19861016].
122 Katsenos S, Nikolopoulou M, Konstantinidis AK, et al. Interferon-gamma release assay clarifies the effect of bacille Calmette-Guerin vaccination in Greek army recruits. Int J Tuberc Lung Dis. May. 2010;14(5):545-50. [pmid: 20392346].
123 Mancuso JD, Mazurek GH, Tribble D, et al. Discordance among commercially available diagnostics for latent tuberculosis infection. Am J Respir Crit Care Med. Feb. 15. 2012;185(4):427-34. [pmid: 22161162].
124 Lempp JM, Margan JZ, Hankinson AL, et al. Assessment of the QuantiFERON-TB Gold In-Tube Test for the Detection of Mycobacterium tuberculosis Infection in US Navy Recruits. Atlanta, GA. Centers for Disease Control and Prevention. 2015.
125 Saigal S, Agarwal SR, Nandeesh HP, et al. Safety of an ofloxacin-based antitubercular regimen for the treatment of tuberculosis in patients with underlying chronic liver disease: a preliminary report. J Gastroenterol Hepatol. Sep. 2001;16(9):1028-32. [pmid: 11595068].
126 Franken WP, Timmermans JF, Prins C, et al. Comparison of Mantoux and QuantiFERON TB Gold tests for diagnosis of latent tuberculosis infection in Army personnel. Clin Vaccine Immunol. Apr. 2007;14(4):477-80. [pmid: 17301213].
127 Dorman SE, Belknap R, Graviss EA, et al. Interferon-gamma release assays and tuberculin skin testing for diagnosis of latent tuberculosis infection in healthcare workers in the United States. Am J Respir Crit Care Med. Jan. 1. 2014;189(1):77-87. [pmid: 24299555].
128 Franken WP, Thijsen S, Wolterbeek R, et al. Variation in T-SPOT.TB spot interpretation between independent observers from different laboratories. Clin Vaccine Immunol. Oct. 2009;16(10):1439-42. [pmid: 19710293].
129 Whitworth WC, Hamilton LR, Goodwin DJ, et al. Within-subject interlaboratory variability of QuantiFERON-TB gold in-tube tests. PLoS One. 2012;7(9):e43790. [pmid: 22970142].
130 Whitworth WC, Goodwin DJ, Racster L, et al. Variability of the QuantiFERON(R)-TB gold in-tube test using automated and manual methods. PLoS One. 2014;9(1):e86721. [pmid: 24466211].
131 O'Shea MK, Fletcher TE, Beeching NJ, et al. Tuberculin skin testing and treatment modulates interferon-gamma release assay results for latent tuberculosis in migrants. PLoS One. 2014;9(5):e97366. [pmid: 24816576].
132 Cummings KJ, Smith TS, Shogren ES, et al. Prospective comparison of tuberculin skin test and QuantiFERON-TB Gold In-Tube assay for the detection of latent tuberculosis infection among healthcare workers in a low-incidence setting. Infect Control Hosp Epidemiol. Nov. 2009;30(11):1123-6. [pmid: 19803719].
133 Menzies D, Long R, Trajman A, et al. Adverse events with 4 months of rifampin therapy or 9 months of isoniazid therapy for latent tuberculosis infection: a randomized trial. Ann Intern Med. Nov. 18. 2008;149(10):689-97. [pmid: 19017587].
134 Sterling TR, Villarino ME, Borisov AS, et al. Three months of rifapentine and isoniazid for latent tuberculosis infection. N Engl J Med. Dec. 8. 2011;365(23):2155-66. [pmid: 22150035].
135 Thompson MJ. Efficacy of various durations of isoniazid preventive therapy for tuberculosis: five years of follow-up in the IUAT trial. International Union Against Tuberculosis Committee on Prophylaxis. Bull World Health Organ. 1982;60(4):555-64. [pmid: 6754120].
136 Mount FW, Ferebee SH. The effect of isoniazid prophylaxis on tuberculosis morbidity among household contacts of previously known cases of tuberculosis. Am Rev Respir Dis. Jun. 1962;85:821-7. [pmid: 14476668].
137 Ferebee SH, Mount FW. Tuberculosis morbidity in a controlled trial of the prophylactic use of isoniazid among household contacts. Am Rev Respir Dis. Apr. 1962;85:490-510. [pmid: 13892318].
138 Egsmose T, Ang'awa JO, Poti SJ. The use of isoniazid among household contacts of open cases of pulmonary tuberculosis. Bull World Health Organ. 1965;33(3):419-33. [pmid: 5321762].
139 Horwitz O, Payne PG, Wilbek E. Epidemiological basis of tuberculosis eradication. 4. The isoniazid trial in Greenland. Bull World Health Organ. 1966;35(4):509-26. [pmid: 5335457].
140 Comstock GW, Ferebee SH, Hammes LM. A controlled trial of community-wide isoniazid prophylaxis in Alaska. Am Rev Respir Dis. Jun. 1967;95(6):935-43. [pmid: 6026165].
141 Girling DJ, Chan SL, Hong Kong Chesst Service/Tuberculosis Research Centre, Madras/British Medical Research Council. A double-blind placebo-controlled clinical trial of three antituberculosis chemoprophylaxis regimens in patients with silicosis in Hong Kong. Am Rev Respir Dis. 1992;145:36-41. [pmid: 1731596].
142 John GT, Thomas PP, Thomas M, et al. A double-blind randomized controlled trial of primary isoniazid prophylaxis in dialysis and transplant patients. Transplantation. Jun. 15. 1994;57(11):1683-4. [pmid: 8009608].
143 Menzies D, Dion MJ, Rabinovitch B, et al. Treatment completion and costs of a randomized trial of rifampin for 4 months versus isoniazid for 9 months. Am J Respir Crit Care Med. Aug. 15. 2004;170(4):445-9. [pmid: 15172892].
144 White MC, Tulsky JP, Lee JR, et al. Isoniazid vs. rifampin for latent tuberculosis infection in jail inmates: toxicity and adherence. J Correct Health Care. Apr. 2012;18(2):131-42. [pmid: 22419641].
145 Bailey WC, Weill H, DeRouen TA, et al. The effect of isoniazid on transaminase levels. Ann Intern Med. Aug. 1974;81(2):200-2. [pmid: 4843577].
146 Byrd RB, Horn BR, Griggs GA, et al. Isoniazid chemoprophylaxis. Association with detection and incidence of liver toxicity. Arch Intern Med. Sep. 1977;137(9):1130-3. [pmid: 332099].
147 Krebs A. The IUAT trial on isoniazid preventive treatment in persons with fibrotic lung lesions. Bull Int Union Tuberc. 1976;51(1):193-201. [pmid: 801115].
148 Falk A, Fuchs G. Isoniazid (INH) prophylaxis in inactive pulmonary tuberculosis: report of a Veterans Administration Cooperative Study. Bull Int Union Tuberc. 1976;51(1):219-23. [pmid: 1030286].
149 Menzies D, Pai M, Comstock G. Meta-analysis: new tests for the diagnosis of latent tuberculosis infection: areas of uncertainty and recommendations for research. Ann Intern Med. Mar. 6. 2007;146(5):340-54. [pmid: 17339619].
150 Pai M, Zwerling A, Menzies D. Systematic review: T-cell-based assays for the diagnosis of latent tuberculosis infection: an update. Ann Intern Med. Aug. 5. 2008;149(3):177-84. [pmid: 18593687].
151 Diel R, Loddenkemper R, Nienhaus A. Evidence-based comparison of commercial interferon-gamma release assays for detecting active TB: a metaanalysis. Chest. Apr. 2010;137(4):952-68. [pmid: 20022968].
152 Diel R, Goletti D, Ferrara G, et al. Interferon-gamma release assays for the diagnosis of latent Mycobacterium tuberculosis infection: a systematic review and meta-analysis. Eur Respir J. Jan. 2011;37(1):88-99. [pmid: 21030451].
153 Linas BP, Wong AY, Freedberg KA, et al. Priorities for screening and treatment of latent tuberculosis infection in the United States. Am J Respir Crit Care Med. Sep. 1. 2011;184(5):590-601. [pmid: 21562129].
154 Stagg HR, Zenner D, Harris RJ, et al. Treatment of latent tuberculosis infection: a network meta-analysis. Ann Intern Med. Sep. 16. 2014;161(6):419-28. [pmid: 25111745].
155 Smieja MJ, Marchetti CA, Cook DJ, et al. Isoniazid for preventing tuberculosis in non-HIV infected persons. Cochrane Database Syst Rev. 2000;(2). Cd001363. [pmid: 10796642].
156 Polesky A, Farber HW, Gottlieb DJ, et al. Rifampin preventive therapy for tuberculosis in Boston's homeless. Am J Respir Crit Care Med. Nov. 1996;154(5):1473-7. [pmid: 8912767].