# Discussion

## Summary of Evidence

Tables 3–5 provide a summary of findings in this evidence review. These tables, which are presented by KQ, provide a summary of outcomes organized by test or intervention along with a description of precision, risk of bias, and applicability.

Table 3 Summary of Evidence of Accuracy and Reliability of the Tuberculin Skin Test and Interferon-Gamma Release Assays for Targeted^*^ Screening of Latent Tuberculosis Infection (KQ 2a)

Test or Intervention | Number of Studies (Observations) Study Design by Test or Outcome | Summary of Findings by Test or Outcome | Consistency/Precision | Reporting Bias | Overall Quality | Body of Evidence Limitations | Applicability
TST 5-mm Accuracy | Sn: 8 (803) Sp: 4 (5,196) Observational studies of test accuracy | Sn pooled: 0.79 (95% CI, 0.69 to 0.89; I^2^=94.6%) Sp in low-TB-burden countries: 0.94 (95% CI, 0.92 to 0.95) 0.95 (95% CI, 0.94 to 0.96) 0.97 (95% CI, 0.95 to 0.98) Sp in intermediate-TB-burden country: 0.30 (95% CI, 0.19 to 0.44) | Consistent but imprecise for Sn Consistent and precise for Sp in low-TB-burden countries | Undetected | Fair | Independent interpretation of test often not reported Description of participant characteristics highly variable across studies | TST using Mantoux procedure with intermediate-strength dose of PPD Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk populations (Sp)
TST 10-mm Accuracy | Sn: 11 (988) Sp: 9 (9,651) Observational studies of test accuracy | Sn pooled: 0.79 (95% CI, 0.71 to 0.87; I^2^=91.4%) Sp pooled: 0.97 (95% CI, 0.96 to 0.99; I^2^=94.3%)^†^ | Consistent but imprecise for Sn Consistent and precise for Sp in low-TB-burden countries | Undetected | Fair | Independent interpretation of test often not reported Description of participant characteristics highly variable across studies | TST using Mantoux procedure with intermediate-strength dose of PPD Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk populations (Sp)
TST 15-mm Accuracy | Sn: 7 (740) Sp: 12 (9,640) Observational studies of test accuracy | Sn pooled: 0.52 (95% CI, 0.35 to 0.68; I^2^=96.3%) Sp pooled: 0.99 (95% CI, 0.98 to 0.99; I^2^=91.7%)^‡^ | Inconsistent and imprecise for Sn Consistent and precise for Sp in low-TB-burden countries | Undetected | Fair | Independent interpretation of test often not reported Description of participant characteristics highly variable across studies | TST using Mantoux procedure with intermediate-strength dose of PPD Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk populations (Sp) The 15-mm threshold is not recommended in current practice for patients at high risk for TB infection
TST Reliability | Interrater reliability: 3 (3,142) Observational studies of test accuracy | Kappa: 0.69 and 0.79 in 2 studies assessing reliability of rater assessment of skin test reaction in healthy populations at low risk for TB Kappa: 0.52 to 0.78 of rater assessment of skin test reaction as assessed in different study with populations including subjects with active TB and healthy, low-risk subjects | Consistent for moderate to substantial agreement; precision unknown | Undetected | Fair | Reliability may be affected by the populations in which it is assessed | TST using Mantoux procedure with intermediate-strength dose of PPD TST administration and interpretation dependent on the use of appropriate, standardized technique
IGRA T-SPOT.TB Accuracy | Sn: 16 (984) Sp: 5 (1,810) Observational studies of test accuracy | Sn pooled: 0.90 (95% CI, 0.87 to 0.93; I^2^=63.6%) Sp pooled: 0.95 (95% CI, 0.92 to 0.98; I^2^=79.1%)^§^ | Consistent and precise for Sn and Sp | Undetected | Fair | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies Studies vary in how they report indeterminate results | Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk (Sp) populations T-SPOT.TB requires proper specimen handling prior to assay; interpretation of test can be done manually through visual inspection or through use of machines that automate interpretation FDA-approved threshold for positive test is higher than threshold used in non-U.S. studies
IGRA T-SPOT.TB Reliability | Interrater reliability: 2 (404) Reproducibility: 1 (130) Test-retest: 2 (296) Observational studies of test accuracy | Study conducted in active TB patients with manual interpretation, interrater reliability: 96% (kappa=0.92); manual vs. automatic interpretation, interrater reliability: 85.8% (kappa=0.73) Study conducted in immigrants who were close contacts of active TB patients: kappa >0.6 among 6 manual readers Discordant results in participants who had 2 samples drawn simultaneously (same lab and method of interpretation): 10/153 (6.5%) Study enrolling health care workers : 9/111 (8.1%) tests changed from negative to positive and 10/19 (52.6%) changed from positive to negative at 2 weeks. Study enrolling Nepalese military recruits, kappa for agreement between initial test and retest=0.66 (95% CI, 0.50 to 0.83) | Consistent for interrater reliability, unknown precision Consistency unknown for single study, unknown precision Inconsistent and imprecise for test-retest reliability | Undetected | Fair | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies Studies vary in how they report indeterminate results | T-SPOT.TB requires proper specimen handling prior to assay; interpretation of test can be done manually through visual inspection or through use of machine that automates interpretation
IGRA QFT-G Accuracy | Sn: 17 (1,073) Sp: 4 (699) Observational studies of test accuracy | Sn pooled: 0.77 (95% CI, 0.74 to 0.81; I^2^=55.3%) Sp pooled: 0.98^¶^ (95% CI, 0.90 to 1.0) | Consistent and precise for Sn Consistent and precise for Sp in low-TB-burden countries, imprecise in intermediate-TB-burden country | Undetected | Fair | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies Studies vary in how they report indeterminate results | Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk (Sp) populations QFT-G requires proper specimen handling prior to assay This generation of QFT test is no longer being marketed
IGRA QFT-GIT Accuracy | Sn: 24 (2,321) Sp: 4 (2,053) Observational studies of test accuracy | Sn pooled: 0.80 (95% CI, 0.77 to 0.84; I^2^=74.3%) Sp pooled: 0.97 (95% CI, 0.94 to 0.99; I^2^=93.4%) | Consistent and precise for Sn Consistent and precise for Sp in low-TB-burden countries, imprecise in intermediate-TB-burden country | Undetected | Fair | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies Studies vary in how they report indeterminate results | Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk (Sp) populations QFT-GIT requires proper specimen handling prior to assay
IGRA QFT-GIT Reliability | Interrater reliability: 1 (146) Reproducibility: 1 (130) Test-retest reliability: 2 (296) Interlaboratory reliability: 1 (91) Observational studies of test accuracy | Across all 4 tests (2 samples from each participant analyzed by manual and automated ELISA): 88.6% were concordant (16% concordant positive and 72.6% concordant negative); 11% were discordant Discordance by method of interpretation: automated vs. automated: 4.8% (kappa=0.85); manual vs. manual: 6.9% (kappa= 0.80); automated vs. manual, 3.4% to 9.0% across comparisons (kappa=0.73 to 0.90) Number of discordant results in participants who had 2 samples drawn simultaneously: 10/172 (5.8%) Study enrolling health care workers, 10/134 (7.5%) results changed from negative to positive and 5/15 (33.3%) changed from positive to negative at 2 weeks. In the other study enrolling Nepalese military recruits, kappa for agreement between initial test and retest=0.48 (95% CI, 0.26 to 0.70) Across 3 labs, 7/91 (7.7%) subjects had discordant results; kappas of pairwise lab sample comparisons were 0.87, 0.89, and 0.93 | Consistency unknown for single study assessing Interrater reliability, precision unknown Consistency unknown for single study assessing reproducibility, precision unknown Inconsistent and imprecise for test-retest reliability Consistency unknown for single study assessing interlaboratory reliability, precision unknown | Undetected | Fair | Studies vary in how they assess reliability outcomes | QFT-GIT requires proper specimen handling prior to assay

* Targeted refers to screening in subjects who have been identified as higher risk for infection; for example, recent arrivals (within the past 5 years) to the United States who were born in foreign countries.

† Pooled estimate includes one study conducted in an intermediate-TB-burden country with a much lower estimate (0.45) compared with the low-TB-burden countries included in the pooled estimate. The pooled estimate without this study was 0.98 (95% CI, 0.97 to 0.99; I^2^=91.2%).

‡ Pooled estimates includes 2 studies in intermediate-TB-burden countries with much lower estimates (0.60 and 0.57) compared with low-TB-burden countries included in the pooled estimate. The pooled estimate without these studies was the same but I^2^ was reduced to 88.7%.

§ Pooled estimate includes 2 low-, 2 intermediate-, and 1 mixed- (2 countries, 1 low- and 1 intermediate-) TB-burden countries. The estimates in the 2 intermediate-TB-burden countries were lower (0.85 and 0.73) compared with estimates in the other studies.

¶ Pooled estimate is from maximum-likelihood random-effects model since 2 studies included point estimates for specificity of 1.0. The I^2^ statistic is not calculated when using this model.

Abbreviations: CI=confidence interval; FDA=U.S. Food and Drug Administration; ELISA=enzyme-linked immunosorbent assay; KQ=key question; LTBI=latent tuberculosis infection; PPD=purified protein derivative; QFT-G=QuantiFERON-TB Gold (2nd-generation test); QFT-GIT=QuantiFERON-TB Gold In-Tube (3rd-generation test); Sn=sensitivity; Sp=specificity; TB=tuberculosis; TST= tuberculin skin test.

Table 4 Summary of Evidence for Treatment of Latent Tuberculosis Infection With CDC-Recommended Pharmacotherapy Treatment Regimens (KQ 3)

Test or Intervention | Number of Studies (Observations) Study Design by Test or Outcome | Summary of Findings by Test or Outcome | Consistency/Precision | Reporting Bias | Overall Quality | Body of Evidence Limitations | Applicability
INH vs. placebo | 1 RCT (27,830)^*^ Sensitivity analysis with 5 RCTs (36,823) | Developing active TB: Main analysis RR: 0.35 at 5 years followup (95% CI, 0.24 to 0.52) for INH × 24 weeks^†^ compared to placebo; NNT=112 Sensitivity analysis RR: 0.31 at 2 to 10 years followup^‡^ (95% CI, 0.24 to 0.41) | Consistency NA for the single study; reasonably precise for developing active TB Consistent across 5 RCTs used in sensitivity analysis for developing active TB (I^2^=0%); precise | Undetected | Good (fair to good for sensitivity analysis) | Studies used in sensitivity analysis used longer duration (1 year of INH)^§^ and some used doses lower or higher than currently recommended; 1 trial was poor quality for high risk of selection, attrition, and measurement bias and confounding | Study population in main analysis trial included those with fibrotic pulmonary lesions and a ≥6-mm TST; median age 50; trials in main and sensitivity analysis published >30 years ago (1963, 1965, 1968, 1978, 1982). Trials in sensitivity analysis enrolled HH contacts of active cases, veterans with inactive pulmonary TB, persons residing in mental institutions, and military members exposed to an active TB case.
INH vs. placebo | 1 RCT (27,830)^*^ | Deaths due to TB: 0 vs. 3; RR: 0.14 (95% CI, 0.01 to 2.78) for the combined isoniazid groups vs. placebo | Imprecise for deaths from TB | Undetected | Good | Small number of events | Same as above for main analysis applicability
INH vs. placebo | 1 RCT (27,830)^*^ | All-cause mortality: NR by group | | | | Data on all-cause mortality NR by group | Same as above for main analysis applicability
RIF vs. INH | 1 RCT (847) | Developing active TB: NR Deaths due to TB: 0 vs. 0 All-cause mortality: 0 vs. 1 | Consistency NA, single study; imprecise | Undetected | Good | Open label. Lacking data for outcome of developing active TB, no events for outcome of deaths from TB, and only 1 event for all-cause mortality outcome | Adults with a positive TST and physician recommendation for INH in Canada, Saudi Arabia, and Brazil. Just over half were ages 18 to 34 and just over half were male. Trial focused on harm outcomes; subjects only followed for duration of their treatment (4 or 9 months).
RPT + INH vs. INH | 1 RCT (6,886)^¶^ | Developing active TB: 5 vs. 10^**^ Deaths due to TB: NR All-cause mortality: 30 vs. 34; p=0.42 | Consistency NA for this single study; reasonably precise for developing active TB and all-cause mortality. NR for deaths from TB. | Undetected | Fair | Open label; single study, no data for deaths due to TB | Median age 37; just over half male; 57% white; combined intervention was directly observed once weekly for 3 months; high-risk subjects; most had a close contact with an active TB case; 25% were included solely because of recent TST conversion

* Of the 27,830 participants in the IUAT trial, the only trial meeting all eligibility criteria for KQ 3 that compared INH with placebo, 6,965 were treated with a CDC-approved regimen (INH 300 mg × 24 weeks). The IUAT trial randomized 27,830 participants to INH 300 mg × 12 weeks (6,956), INH 300 mg × 24 weeks (6,965), INH 300 mg × 52 weeks (6,919), or placebo (6,990).

† The relative risks for the other treatment groups developing active TB compared with placebo were 0.79 (95% CI, 0.58 to 1.06) and 0.25 (95% CI, 0.16 to 0.39) for 12 and 52 weeks of INH, respectively.

‡ Followup for the 5 RCTs included in the sensitivity analysis ranged from 2 to 10 years; one study followed patients for 2 years (Bush), one for 5 years (IUAT), two for 7 years (Falk, Veening), and one for 10 years (Ferebee).

§ No longer a CDC-recommended treatment regimen.

¶ This open-label, noninferiority trial randomized 7,731 subjects; we obtained data from the CDC for this table on the subset of participants most directly relevant for this review: the 6,886 adults (age ≥18 years) who were HIV negative and were TST or IGRA positive.

** The combination therapy group was found to be noninferior to the INH-only group.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; HH=household; INH=isoniazid; IUAT=International Union Against Tuberculosis; KQ=key question; NA=not applicable; RCT=randomized, controlled trial; RIF=rifampin; RPT=rifapentine; RR=relative risk; TB=tuberculosis; TST= tuberculin skin test.

Table 5 Summary of Evidence for Harms Associated With CDC-Recommended Pharmacotherapy Treatment Regimens for Latent Tuberculosis Infection (KQ 5)

Test or Intervention | Number of Studies (Observations) Study Design by Test or Outcome | Summary of Findings by Test or Outcome | Consistency/Precision | Reporting Bias | Overall Quality | Body of Evidence Limitations | Applicability
INH vs. placebo | 1 RCT (27,830)^*^ Sensitivity analysis with 4 RCTs (35,161) | Hepatotoxicity: Main analysis: RR: 4.59 at 5 years (95% CI, 2.03 to 10.39) for 24 weeks INH compared to placebo; NNH=279 Sensitivity analysis: Pooled RR: 5.04^†^ (95% CI, 2.50 to 10.15; I^2^=0%) | Consistency NA for the single study in main analysis consistent across 4 studies in sensitivity analysis; imprecise | Undetected | Fair for main analysis, fair to poor for sensitivity analyses | Harm ascertainment techniques not well described Studies used in sensitivity analysis limited by measurement and ascertainment bias | Study population in main analysis trial includes those with fibrotic pulmonary lesions and a ≥6-mm TST; median age 50; trial published in 1982. Trials in sensitivity analysis published in 1974, 1977, and 1978 and enrolled employees in a U.S. hospital, individuals meeting ATS criteria referred to a U.S. military medical center, and veterans with inactive pulmonary TB
INH vs. placebo | 1 RCT (27,830)^*^ | Death from hepatotoxicity^‡^: 0 in placebo group, 0.14 per 1,000 receiving INH; RR: 2.35 (95% CI, 0.12 to 45.46; NNH=6,947) | Consistency NA for the single study; imprecise | Undetected | Fair | Rare number of events Harm ascertainment techniques not well described | Same as above for main analysis
INH vs. placebo | 1 RCT (27,830)^*^ | Discontinuation of treatment due to adverse events: Main analysis: RR: 1.50^†^ (95% CI, 1.18 to 1.89; NNH=167) | Consistency NA for the single study; reasonably precise. | Undetected | Fair for main analysis | Harm ascertainment techniques not well described | Same as above for main analysis
INH vs. placebo | Sensitivity analysis with 4 RCTs (55,398) | Sensitivity analysis: Pooled RR: 1.58 (95% CI, 1.00 to 2.49; I^2^=70.2%) | Inconsistent across the 4 studies included in sensitivity analysis, reasonably precise | Undetected | Fair to poor for sensitivity analysis | Studies limited by lack of prespecification of harm outcomes, measurement and ascertainment bias | Trials in treatment discontinuation sensitivity analysis published in 1963, 1965, and 1977 and enrolled residents of mental institutions, HH contacts of active cases, and adults meeting ATS criteria for chemoprophylaxis
INH vs. placebo | 1 RCT (27,830)^*^ | GI adverse events: RR: 1.33^†^ (95% CI, 1.01 to 1.75) Sensitivity analysis: Different outcomes reported across studies; no differences among groups | Consistency NA for the single study; reasonably precise | Undetected | Fair to poor | GI harms not prespecified, measurement and ascertainment bias | Study population in main analysis trial includes those with fibrotic pulmonary lesions and a ≥6-mm TST; median age 50; trial published in 1982
INH vs. RIF | 3 RCTs (1,327) | Hepatotoxicity: Pooled RR: 3.29 (95% CI, 1.17 to 6.28; I^2^=0%) Death from hepatotoxicity: No events reported in any arms of any study | Consistent, imprecise | Undetected | Fair to good | 2 trials were open-label, 1 trial lost nearly half of participants to followup | Trials published in 2004, 2008, 2012; subjects had positive TST following Canadian guidelines in 2 trials, subjects in other trial were inmates diagnosed with LTBI at jail entry
INH vs. RIF | 3 RCTs (1,327) | Discontinuation of treatment due to adverse events: Pooled RR: 1.61 (95% CI, 0.57 to 4.57; I^2^=40.0%) | Inconsistent, imprecise | Undetected | Fair to good | 2 trials were open-label, 1 trial lost nearly half of participants to followup | Trials published in 2004, 2008, 2012; subjects had positive TST following Canadian guidelines in 2 trials, subjects in other trial were inmates diagnosed with LTBI at jail entry
INH vs. RIF | 2 RCTs (1,211) | GI adverse events: Pooled RR: 1.60 (95% CI, 0.76 to 3.40; I^2^=0%) | Inconsistent, imprecise | Undetected | Fair | 1 study lost nearly half of participants to followup; duration of followup may be inadequate for harms | Trials published in 2008 and 2012; subjects had positive TST following Canadian guidelines in 1 trial, subjects in other trial were inmates diagnosed with LTBI at jail entry
INH vs. RIF | 2 RCTs (480) | Other adverse events: Pooled RR: 0.82 (95% CI, 0.42 to 1.59; I^2^=0%) | Inconsistent, imprecise | Undetected | Fair | 1 study lost nearly half of participants to followup; duration of followup may be inadequate for harms, measurement and ascertainment bias | Trials published in 2004 and 2012; subjects had positive TST following Canadian guidelines in 1 trial, subjects in other trial were inmates diagnosed with LTBI at jail entry
RPT + INH vs. INH | 1 RCT (6,886)^§^ | Hepatotoxicity (grade 3 or 4): Calculated RR: 0.90 (95% CI, 0.75 to 1.08) Death from hepatotoxicity: 0.83 (95% CI, 0.51 to 1.35) | Consistency NA for the single study, imprecise | Undetected | Fair | Single study, masking unclear and high overall attrition | Trial published in 2011, data were from HIV-negative subgroup with TST or IGRA confirmation; combined intervention was directly observed once week × 3 months; high-risk individuals; most had close contact with an active TB case; 25% were included solely because of recent TST conversion
RPT + INH vs. INH | 1 RCT (6,886)^§^ | Discontinuation of treatment due to adverse events: Calculated RR: 1.28 (95% CI, 1.03 to 1.59) | Consistency NA for the single study, reasonably precise | Undetected | Fair | Single study, masking unclear and high overall attrition
RPT + INH vs. INH | 1 RCT (6,886)^§^ | Possible hypersensitivity: RR: 8.04 (95% CI, 4.88 to 13.26) | Consistency NA for the single study, imprecise | Undetected | Fair | Single study, masking unclear and high overall attrition

* Of the 27,830 participants in the IUAT trial, the only trial meeting all eligibility criteria for KQ 3 that compared INH with placebo, 6,965 were treated with a CDC-approved regimen (INH 300 mg × 24 weeks). The IUAT trial randomized 27,830 participants to INH 300 mg × 12 weeks (6,956), INH 300 mg × 24 weeks (6,965), INH 300 mg × 52 weeks (6,919), or placebo (6,990).

† Estimate includes combined data from all three INH study arms (12 weeks, 24 weeks, 52 weeks) in the IUAT trial.

‡ One additional RCT used in sensitivity analysis for this outcome reported no deaths from hepatotoxicity in either the INH or placebo arm.

§ Followup for the 5 RCTs included in the sensitivity analysis ranged from 2 to 10 years; one study followed patients for 2 years (Bush), one for 5 years (IUAT), two for 7 years (Falk, Veening), and one for 10 years (Ferebee).

Abbreviatons: ATS=American Thoracic Society; CDC=Centers for Disease Control and Prevention; CI=confidence interval; KQ=key question; IGRA=interferon-gamma release assay; INH=isoniazid; IUAT=International Union Against Tuberculosis; LTBI=latent tuberculosis infection; NA=not applicable; NNH=number needed to harm; RCT=randomized, controlled trial; RIF=rifampin; RPT=rifapentine; RR=relative risk; TB=tuberculosis; TST=tuberculin skin test.

### Evidence for Benefit and Harms of Screening

We did not identify any RCTs or prospective cohort studies directly assessing the effectiveness or harms of screening for LTBI compared with no screening in the populations and outcomes specified for this review.

### Accuracy and Reliability of Screening Tests

The evidence on accuracy and reliability was based on fair-quality evidence overall. Because of the lack of tests for the direct diagnosis of LTBI, evaluating accuracy of tests relies on extrapolation from test characteristics among populations with active, confirmed TB (sensitivity) or from healthy persons known to be free of TB risks and exposures (specificity). The evidence suggests that for the populations studied, currently available tests are moderately sensitive and, in countries with a low TB burden, highly specific. Sensitivity estimates for TST (at 5-mm and 10-mm but not 15-mm thresholds) and QFT IGRAs were consistent, with pooled estimates ranging from 0.77 to 0.80. Sensitivity estimates for the T-SPOT.TB IGRA test were higher at 0.90, and estimates of sensitivity for IGRA tests were more precise than those for TST. Pooled estimates for specificity of TST at 10- and 15-mm thresholds and all IGRA tests ranged from 0.95 to 0.99. We judged specificity estimates to be consistent and precise in countries with a low TB burden. Our findings for sensitivity and specificity are generally consistent with other systematic reviews evaluating accuracy, despite differences in study inclusion and exclusion criteria.149-152 We found limited evidence on the reliability of these tests and, of those identified, few assessed reliability in the same way.

The applicability of the evidence on accuracy and reliability of screening tests to primary care practice settings and populations is uncertain, since the lack of a direct test for LTBI requires test accuracy studies to be performed in specific populations (e.g., populations with active, confirmed TB; healthy, low-risk populations) to ensure the validity of findings. We found lower estimates for specificity in studies conducted in populations from countries with an intermediate TB burden. This could be the result of unintentional inclusion of subjects with unknown past TB exposure, thus increasing the frequency of positive results; inclusion of BCG-vaccinated subjects; thus increasing false-positive TST results; or because of other factors that affect the administration or interpretation of tests among populations in these countries.

Despite this uncertainty, the evidence is likely applicable to primary care practice settings that serve high-risk populations (e.g., public health settings, residents of high-risk congregate settings, clinics serving foreign-born populations), where the use of a highly specific test among a higher prevalence population minimizes false positives and results from a moderately sensitive test can be combined with a clinical risk assessment to determine the likelihood of infection to inform treatment decisions. In these settings, clinical risk assessment prior to testing may already be a part of standard clinical workflow, and clinic and laboratory staff may have extensive experience with appropriate testing techniques and interpretation. However, many primary care practice settings may not serve large populations at high risk for LTBI; thus, an approach that relies on an individualized clinical assessment for LTBI risk to inform decisions regarding testing may not be part of standard workflow. Systematic identification of high-risk persons cared for in low-prevalence practice settings may be challenging and associated with opportunity costs.

### Benefits and Harms of Treatment of LTBI

The best evidence on effectiveness of treatment of LTBI with a CDC-recommended regimen was from the IUAT trial, a large (N=27,830) good-quality study. It found a 65 percent relative reduction in progression to active TB at 5 years for 24 weeks of isoniazid compared with placebo (NNT, 112). Our sensitivity analysis adding four RCTs (that did not meet all of our eligibility criteria) that used a longer duration of treatment and some different doses than currently recommended found a similar reduction. The IUAT trial enrolled subjects with pulmonary fibrotic lesions, a group thought to be at the highest risk for progression to active TB. In this trial, subjects with smaller lesions progressed to active TB at lower rates than those with larger lesions. Further, the populations included in the other treatment studies used in our sensitivity analysis were not persons identified to have LTBI via screening in primary care settings; rather, they were household contacts of active cases,43 veterans with inactive pulmonary TB,41,148 persons residing in mental institutions,44 and military members exposed to an active TB case.42 Thus, the available evidence may not be applicable to persons in primary care settings who screen positive on TST or IGRA but have normal chest x-rays or who are not recent converters or close contacts. Thus, estimates of treatment effectiveness may represent the upper bounds of effectiveness, which may be lower in other screen-positive populations. Further, all of the RCTs that assessed the effectiveness of isoniazid compared with placebo were published more than 30 years ago (1963, 1965, 1968, 1978, and 1982). Most of them evaluated 1 year of treatment with isoniazid because that was the recommended treatment for many years; shorter durations and other regimens were later studied with a focus on reducing harms (and little attention to evidence on benefits). It is unclear whether changes in the prevalence of TB, treatments for active TB, or likelihood of LTBI progressing to active TB would significantly change estimates of effectiveness.

We found limited evidence on efficacy of other CDC-recommended regimens meeting our eligibility criteria and scant evidence on effectiveness of treatments for reducing mortality due to TB or all-cause mortality. No studies compared rifampin or rifapentine plus isoniazid with placebo or compared a 9-month course of isoniazid with placebo. However, the included head-to-head. open-label, noninferiority RCT (the PREVENT TB trial) that compared a combination of once-weekly rifapentine plus isoniazid for 3 months with daily isoniazid for 9 months found the combination therapy to be noninferior (with estimates trending in favor of combination therapy) to isoniazid alone for preventing the development of active TB.

The evidence on harms was of fair quality overall and suggests a 4.6-fold increased risk for hepatotoxicity for treatment with 6 months of isoniazid compared with placebo and a 3.6-fold increased risk compared with rifampin. Deaths due to hepatotoxicity were rare across all studies included such that estimates were imprecise. In the IUAT trial, all three subjects who died from hepatitis had continued to take isoniazid after liver abnormalities were recognized.135 Two studies used in sensitivity analysis for harms reported normalization of liver enzyme levels among subjects experiencing asymptomatic elevation145 or mild hepatitis.41,148 Discontinuation of treatment because of adverse events was modestly increased for isoniazid compared with placebo, but estimates of no difference between isoniazid and rifampin were inconsistent and imprecise. GI distress, an outcome that represents a heterogeneous group of harms in both type and severity, was inconsistently reported by included studies. Other harms reported were limited by inconsistent and imprecise findings. Other adverse events occurred infrequently and may be subject to more bias in determination than hepatotoxicity or discontinuation because of adverse events.

The overall benefits and harms of screening and treatment are influenced by several factors. The NNT is driven both by the effectiveness of treatment compared with no treatment and by the rate of progression to active TB among an untreated group. Given that treatment of LTBI has been the standard of care for decades, contemporary data for estimating efficacy/effectiveness are not available. A recent study to estimate the cost-effectiveness of screening for LTBI using TST and IGRA among different risk groups specified in current CDC screening guidelines reported similar difficulties in establishing robust estimates of TB reactivation and uncertainty in test characteristics as a result of the lack of a referent standard for diagnosis of LTBI.153 Proponents for screening suggest benefits on outcomes related to TB transmission and through case-finding of active TB that occurs during screening. However, we identified no studies meeting our study selection criteria that reported on outcomes related to TB transmission.

### Hypothetical Outcomes of a Screening Program

The hypothetical outcomes of a screening program for LTBI are illustrated in Table 6. These outcomes are a crude approach to estimating the overall benefits and harms of screening in a population, and several scenarios are illustrated to provide alternative outcomes based on differing prevalence of infection and differing rates of progression from latent to active TB. A detailed list of assumptions and relevant citations for assumptions are provided in the table notes.

Table 6 Projected 5-Year Outcomes of Screening 100,000 Asymptomatic Adults for Latent Tuberculosis Infection^a^

Outcome | Variable | Foreign-Born Population Screened | Foreign-Born Population Not Screened | Community, Noninstitutionalized Population Screened | Community, Noninstitutionalized Population Not Screened
Detection | Patients with LTBI^b^, n (95% CI) | 20,500 (16,100 to 25,800) | 20,500 (16,100 to 25,800) | 4,700 (3,400 to 6,300) | 4,700 (3,400 to 6,300)
Detection | Positive screening test, chest x-ray, and offered LTBI treatment^c^, n (n false positive/n true positive) | 18,580 (2,385/16,195) | NA | 6,572 (2,859/3,713) | NA
Benefits | Progression to active TB^d^, n (n false positive/n true positive) [range of estimate]^e^ | 79 (0/79) [62 to 99] | 225 (NA) [177 to 287] | 18 (0/18) [13 to 24] | 52 (NA) [37 to 69]
Benefits | NNT to prevent 1 case of LTBI from progressing to active TB^f^ | 111 | | 111
Benefits | Progression to active TB using alternative assumption for rate of LTBI reactivation^g^, n (n false positive/n true positive) [range of estimate]^e^ | 28 (0/28) [19 to 35] | 79 [55 to 100] | 5 (0/5) [4 to 7] | 16 (NA) [11 to 21]
Benefits | NNT to prevent 1 case of LTBI from progressing to active TB under alternative assumption for rate of LTBI reactivation^f,g^ | 314 | | 366
Benefits | TB transmission | Unknown | Unknown | Unknown | Unknown
Benefits | Death from TB | Unknown | Unknown | Unknown | Unknown
Harms | Hepatotoxicity^h^ (INH or placebo), n (n false positive/n true positive) [range of estimate]^e^ | 85 (11/74) [70 to 104] | 19 (NA) [15 to 23] | 30(13/17) [26 to 36] | 7 (NA) [6 to 8]
Harms | NNH to cause hepatotoxicity from treatment with INH^i^ | 279 | | 279
Harms | Hepatotoxicity (RIF or placebo)^j^, n (n false positive/n true positive) [range of estimate]^e^ | 26 (3/23) [21 to 32] | 19 (NA) [15 to 23] | 9 (4/5) [8 to 11] | 7 (NA) [6 to 8]
Harms | NNH to cause hepatotoxicity from treatment with RIF^i^ | 2,531 | | 2,531
Harms | Discontinuation due to adverse effects (INH or placebo)^k^, n (n false positive/n true positive) [range of estimate]^e^ | 334 (43/292) [274 to 407] | 223 (NA) [183 to 271] | 118 (51/67) [101 to 140] | 79 (NA) [67 to 93]
Harms | NNH to cause discontinuation due to adverse events from treatment with INH | 167 | | 167
Harms | Potential psychological harms | Unknown | | Unknown
Summary of estimated benefits and harms | | 52 to 146 active TB cases prevented^l^ 67 cases of hepatotoxicity caused if using INH for everyone; 9 of those cases caused by unnecessary treatment (for persons with false positives)^m^ 7 cases of hepatotoxicity caused if using RIF for everyone; 1 of those cases caused by unnecessary treatment (for persons with false positives)^m^ 111 cases of discontinuation due to adverse events caused if using INH for everyone; 14 of those caused by unnecessary treatment (for persons with false positives)^m^ | | 10 to 33 active TB cases prevented^l^ 24 cases of hepatotoxicity caused if using INH for everyone; 10 of those cases caused by unnecessary treatment (for persons with false positives)^m^ 3 cases of hepatotoxicity caused if using RIF for everyone; 1 of those cases caused by unnecessary treatment (for persons with false positives)^m^ 39 cases of discontinuation due to adverse events caused if using INH for everyone; 17 of those caused by unnecessary treatment (for persons with false positives)^m^

a Projected benefits and harms were determined for persons in whom screening had not previously been performed and who would be eligible for and offered treatment for LTBI based on a positive screening test. When relevant, projected outcomes are shown as overall and in parentheses for persons with false-positive tests and those with true-positive tests, to illustrate how many persons would undergo unnecessary intervention with resulting harm.

b The prevalence of LTBI is 4.7% and 20.5% for the U.S. overall population and foreign-born U.S. population, respectively, based on 2011–2012 NHANES.20 We use the foreign-born U.S. population as an example of outcomes among a higher-risk population because available estimates of prevalence and progression are readily available for this population, unlike other high-risk populations.

c Based on sensitivity (0.79) and specificity (0.97) for TST with 10-mm threshold for positive test, which is the threshold recommended for recent arrivals (within past 5 years) to the United States from high-risk areas based on current CDC recommendations.12 A small proportion of those x-rayed will have findings suggestive of active TB disease and will go on to receive further diagnostic evaluation and treatment. A precise estimate of this proportion is not available and we have assumed it to be zero.

d Estimates for benefits were based on the IUAT trial, which may have limited applicability to current clinical practice because the study population was composed of subjects with pulmonary fibrotic lesions. Rate of progression in the absence of treatment at 5 years was 1.39% in the placebo arm and 0.5% in the 24-week isoniazid treatment arm, for a relative risk reduction of 0.35. Patients with false-positive or false-negative screening results receive no benefit from treatment, thus progression to active TB is only relevant for true positives.

e This range is an estimate based on the lower and upper bounds of the 95% CI, for prevalence. That is, it provides the range of possible estimates given the precision of the LTBI prevalence estimates available.

f Number needed to treat is calculated as 1/absolute risk reduction between treatment and control groups.

g Because using the rate of progression to active TB from the IUAT trial may not reflect contemporary risk, we also used a more recent estimate based on the rate of nonclustered TB cases, a proxy for reactivation. The rate of progression is estimated at 0.084/100 person-years for the overall U.S. population and 0.098/100 person-years for the foreign-born U.S. population.8 We assumed the same relative risk reduction for treatment with isoniazid from the IUAT trial (0.35).

h We used rate of hepatotoxicity from the IUAT trial: 0.1% in the placebo group and 0.46% in the 24-week INH treatment group.135

i Number needed to harm is calculated as 1/absolute harm risk difference between treatment and control groups.

j Estimates of hepatotoxicity in the studies evaluating isoniazid vs. rifampin reported hepatotoxicity rates over a different time period, using different definitions, were conducted nearly 30 years after the IUAT trial, and the event rate in the INH treatment arm was much higher than the rates reported in the IUAT trial, likely because these studies were designed specifically to evaluate harms. For these reasons, these rates could not be directly used in this outcomes table to compare with the NNT calculated from the IUAT trial. Thus, we used the pooled RR for hepatotoxicity for INH vs. RIF of 3.29 from our meta-analysis to adjust the IUAT trial rate for hepatotoxicity among the INH-treated arm to obtain an indirect estimate of a 5-year risk of hepatotoxicity from RIF compared with placebo of 0.14%.

k We used estimates of discontinuation of treatment due to adverse events from the IUAT trial.135

l This range includes an estimate based on rates of LTBI progression in the absence of treatment from the IUAT trial and an estimate based on a more recent lower estimate of the rate of progression in the absence of treatment.

m Unnecessary treatment is determined by the number of persons for whom a false-positive test resulted in treatment that is unnecessary and for which they have no potential to benefit.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; LTBI=latent tuberculosis infection; NA=not applicable; NHANES=National Health and Nutrition Examination Survey; NNH=number needed to harm; NNT=number needed to treat; RIF=rifampin; RR=relative risk; TB=tuberculosis; TST=tuberculin skin test.

We calculated outcomes for two different prevalence estimates for LTBI (20.5% for the foreign-born U.S. population and 4.7% for the overall U.S. population) and provided the range of outcomes based on the lower and upper CIs associated with these prevalence estimates (shown in brackets in Table 6). For the sensitivity and specificity of tests, we use the pooled estimates from our meta-analysis for TST at the 10-mm threshold, although in practice, the threshold used is typically individualized to the risk of the person being screened. We assumed all persons who test positive receive a chest x-ray to rule out active disease and that a proportion of persons will not be offered treatment based on a history of prior treatment of LTBI or active TB disease. We assumed rates of progression in the absence of treatment based on rates of progression in the placebo arm of the IUAT trial (1.4% at 5 years) and an alternative rate of progression based on more recent estimates (0.084 cases per 100 person-years for overall population and 0.098 cases per 100 person-years for foreign-born U.S. population).8 We used an estimate for the RR reduction in progression to active TB for treatment with 6 months of isoniazid based on the IUAT trial (0.35). We assumed rates of hepatotoxicity and discontinuation due to adverse events based on estimates calculated for this review.

For the base case using the foreign-born U.S. population prevalence estimate and rate of progression from the IUAT trial, we estimated that for 100,000 asymptomatic patients screened and eligible for treatment, 18,580 will have a positive test, require a chest x-ray, and be offered treatment. Of these, 2,385 patients will have false-positive tests that do not have any potential to benefit from treatment. Of those treated, 79 patients will progress to active TB despite treatment compared with 225 patients if no screening and subsequent treatment were offered. This is equivalent to an NNT of 111. Under an alternative assumption regarding rate of progression to active TB, we estimated that fewer cases will progress to active TB with (28) or without (79) treatment, and the NNT increases to 314. We had insufficient evidence to estimate benefits relating to prevention of TB deaths, prevention of TB transmission, and improvements in quality of life.

With respect to harms, 85 patients treated with isoniazid for 6 months will experience hepatotoxicity compared with 19 patients if no screening and subsequent treatment were offered, for an NNH of 279. Likewise, 334 subjects would discontinue isoniazid treatment due to adverse events compared with 223 subjects if no screening and treatment were offered, for an NNH of 167. Fewer cases of hepatotoxicity would occur with treatment with rifampin (26) compared with no treatment (19), for an NNH of 2,531. We had insufficient data to estimate outcomes for other types of harms, such as psychological harms, peripheral neuropathy, hematologic reactions, and dermatologic or hypersensitivity reactions.

Overall, the estimated number of active TB cases prevented ranges from 52 to 146, depending on which assumption for progression to active TB is used. Sixty-seven cases of hepatotoxicity would be caused if treatment with isoniazid is used; nine of those cases would be caused by unnecessary treatment in persons with false-positive screening results and no potential to benefit from treatment. One hundred and eleven cases of treatment discontinuation due to adverse events would occur; 14 of those would occur in persons with no potential to benefit (false positives).

Table 6 shows hypothetical outcomes using estimates of LTBI prevalence for the overall U.S. community-dwelling population, a lower prevalence population than the U.S. foreign-born population. For this population, fewer absolute numbers of persons would screen positive and be subjected to treatment and thus experience treatment-related harms. However, more than 40 percent (2,859) of subjects offered treatment (6,572) would have false-positive tests and no potential for benefit yet be subjected to the risk of harms from treatment.

## Limitations of the Review

This review is limited in its ability to directly assess the effectiveness of targeted screening for LTBI because we identified no studies comparing screened against unscreened populations among the populations considered in this review. LTBI screening and treatment among some high-risk persons is a standard of practice. Thus, trials comparing screening with no screening in these populations have not been conducted.

We could not assess screening test characteristics specifically for LTBI because of the absence of a reference standard for direct diagnosis. We relied on extrapolation from studies in active TB populations for sensitivity and in healthy subjects for specificity, an approach consistent with other studies estimating sensitivity and specificity of these tests. We identified a substantial amount of statistical heterogeneity in some of our pooled estimates, although we believe this heterogeneity is not clinically meaningful, and we suspect inflation of I^2^ (the proportion of variation in study estimates due to heterogeneity) among specificity outcomes because of very precise individual study estimates.49 When possible, we stratified analyses by study features possibly contributing to the heterogeneity, but few studies were available for some of the strata used in analysis, and with rare exceptions, findings were not consistent for explaining heterogeneity across tests (or induration thresholds for TST). We did not stratify findings by reagent used for TST (PPD vs. RT-23); the equivalence between these two reagents has not been established in recent years and may have contributed to heterogeneity in findings.

The studies of screening tests in our review did not consistently report comorbidities of the study population tested. Although we excluded studies and results from populations with more than 25 percent HIV-infected persons, patients with active TB often have underlying comorbidities related to immunosuppression, and the extent to which sensitivity of tests is blunted by this underlying immunosuppression is not known and may result in lower estimates of sensitivity than would otherwise be found in populations with latent infection. On the other hand, the presence of active disease may result in more host sensitization than would occur compared with latent infection, such that this population may overestimate the true sensitivity of the tests for latent infection. We did not identify any eligible studies evaluating the sequential use of tests; studies that used more than one test typically performed both tests on the study population to assess concordance rates or used a second test only in the case of an indeterminate or unexpected result on the first test.

Evidence on reliability of tests was limited. For the T-SPOT.TB test, manual versus automated reading of specimens could affect reliability, but few studies using T-SPOT.TB formally evaluated this. Further, test-retest reliability may vary by baseline prevalence of LTBI; the U.S. study assessing this outcome had a higher rate of reversion from positive to negative compared with the study conducted among Nepalese immigrants. For TST, test-retest reliability is challenging to measure because repeat testing in patients with a positive test is not clinically recommended because of the risk of stimulating an even larger hypersensitivity reaction. Moreover, interpretation of repeat testing among subjects initially testing negative is complicated by the well-known booster phenomenon. Studies of reliability included in this review were not conducted in primary care settings. Both tests (TST and IGRA) have fairly detailed test procedures for administration, handling, and interpretation. The one study assessing IGRA interlaboratory reliability sent specimens to laboratories that have extensive expertise and experience with IGRA testing and interpretation. Thus, the applicability of reliability evidence to primary care practice settings or laboratories that may not have the expertise or economies of scale to perform tests with high fidelity to recommended instructions for testing is uncertain.

We identified no studies assessing the harms of screening compared with no screening. Potential harms include overdiagnosis and treatment of LTBI that would have never progressed to active TB. Potential harms also include incidental findings on chest x-ray in persons who screen positive for LTBI, which result in the need for followup computed tomography scans or serial x-rays for findings unrelated to TB disease, such as lung nodules. This review was also limited in its ability to determine the burden of repeat testing required for persons who have indeterminate results on IGRAs. Last, we did not identify any evidence about psychosocial harms in persons who screen positive and may experience anxiety or stigma associated with being labeled as infected with TB.

This review was limited to the evaluation of existing CDC-recommended LTBI treatment regimens. Isoniazid was established as an effective treatment of LTBI several decades ago; the IUAT trial and the RCTs in our sensitivity analysis were published more than 30 years ago. CDC-recommended treatments have evolved based on interval studies comparing shorter durations and alternative regimens against the standard isoniazid regimen to reduce harms, improve adherence, or both, rather than to assess efficacy. Since the original isoniazid trials were conducted, the prevalence of TB has declined, yet the prevalence of resistant strains among those infected has increased; thus, the applicability of evidence from an era before multidrug TB resistance is unclear. We identified little information on the rate of progression from LTBI to active TB in the modern era, which is an important determinant for making decisions about treatment.

Our review excluded treatments that are not recommended by the CDC and also excluded several populations (e.g., children, persons with HIV). A recent network meta-analysis of treatment of LTBI that used a mixed-treatment comparison methodology suggests that some of the more recently recommended regimens are efficacious for preventing active TB (e.g., rifampin for 3 to 4 months, rifapentine-isoniazid combination), potentially more so than isoniazid alone, and may have fewer adverse effects.154 This analysis included studies among children; HIV-infected persons; household or close contacts of persons with active TB without confirmed LTBI; and persons with renal transplant, silicosis, or rheumatoid arthritis who are taking immunosuppressive biologic medication, which were all populations excluded from the present review. The meta-analysis also included treatment regimens not eligible for our review. A systematic review conducted for the Cochrane Collaboration on isoniazid for the prevention of TB in non–HIV-infected persons found a significant reduction in active TB over 2 years or longer using data from 11 RCTs (RR, 0.40 [95% CI, 0.31 to 0.52]). The review included studies among children, household or close contacts of active TB patients in the absence of confirmed LTBI, persons with renal transplant, and persons with silicosis, which were all populations excluded from the present review.155

## Future Research Needs

Continuing declines in TB incidence in the United States during the past several decades suggest progress toward reaching the public health goal of TB elimination. Most active TB cases are reactivations of latent TB rather than new transmission. Risk for LTBI and progression to active TB is on a continuum, and although there is certainty about persons and populations at the absolute highest risk, there is uncertainty about LTBI prevalence and rates of progression in persons and populations at increased risk but perhaps not the highest absolute risk, such as persons with diabetes and smokers. More research to elucidate the epidemiology of LTBI in these groups could inform future screening and treatment strategies to better tailor individual screening and treatment recommendations. Future research to develop more accurate screening tests, more effective LTBI treatments with fewer harms and side effects, and treatments requiring shorter duration with higher rates of patient adherence would also improve the overall benefit of an LTBI screening program.

In addition to research to improve the accuracy of screening tests and the effectiveness or safety of treatment, research is needed to determine efficient ways of identifying candidates for LTBI testing that take advantage of varied data sources and alternative venues for risk assessment beyond primary care office settings. Primary care settings serving the general population are different from primary care provided in specialized clinics that care for high-risk populations (e.g., prison clinics, clinics serving large proportions of foreign-born populations) and TB-specific public health settings; thus, an approach to clinical risk assessment and testing that can be tailored based on setting and practice characteristics is needed. For example, operations research may be needed to identify efficient ways of identifying high-risk persons who are seen in low-prevalence community practice settings. Further, research that informs our understanding of the incremental net benefit of more or less frequent screening could also help determine optimal approaches to screening.

## Conclusion

We identified no studies that directly evaluated the benefits and harms of a screening program for LTBI compared with no screening among the populations considered in this review. Both types of currently available screening tests for LTBI (TST and IGRA) are moderately sensitive and, within countries with a low TB burden, are highly specific. Isoniazid treatment reduces the risk of progression to active TB in persons with LTBI and pulmonary fibrotic lesions. The evidence on benefit on other outcomes (e.g., TB mortality, all-cause mortality) or other treatment regimens is limited or not available for the populations considered in this review. Isoniazid is associated with higher rates of hepatotoxicity than placebo and rifampin regimens. Isoniazid is also associated with higher risk for discontinuation of treatment due to adverse events than placebo, but this risk was similar to the risk for rifampin regimens.