# Results

## Literature Search

We identified 4,408 unique records and assessed 614 full-text articles for eligibility (Figure 2). We excluded 541 studies for various reasons detailed in Appendix C and we included 72 published studies of good or fair quality in our main analyses (Appendix D). Of the included studies, 67 were primary studies of screening test characteristics (KQ 2a). Three studies were RCTs focused on the benefits (KQ 3) and five studies were focused on the harms (KQ 5) of pharmacotherapy for the treatment of LTBI. We identified no eligible studies for KQ 1 (direct evidence for screening for LTBI) or KQ 4 (harms of screening). Details of quality assessments are provided in Appendix E.

Figure 2 Preferred Reporting of Systematic Review and Meta-Analysis (PRISMA) Tree

^a^ 19 poor-quality and/or ineligible studies were excluded but used in sensitivity analyses.

Figure 2 is a flow chart that summarizes the search and selection of articles: There were 4,369 references identified through database searching (after duplicates removed). In addition, 37 references were identified through other sources. The titles and abstracts of 4,406 references were screened for potential inclusion. Of these, 3,794 were excluded and 612 were deemed appropriate for full-text review to determine eligibility. After full-text review, 541 were excluded: 20 for not original research, 267 for ineligible population(s), 90 for ineligible or no screening/intervention(s), 41 for ineligible or no comparator(s), 63 for ineligible or no outcome(s), 8 for ineligible setting, 36 for ineligible study design, 2 were irretrievable, and 14 for poor quality. Seventy-one studies of fair or good quality are included in this report's evidence synthesis. Nineteen poor quality and/or ineligible studies were excluded but used in sensitivity analyses.

## Results by KQ

### KQ 1 Direct Evidence for Targeted Screening for LTBI

We found no eligible studies that addressed this question.

### KQ 2a Accuracy and Reliability of Screening Tests

We identified 67 observational studies of good or fair quality assessing the sensitivity, specificity, or reliability of one or more of the included screening tests.

#### Sensitivity of Screening Tests

We relied on evidence from 50 primary studies of good or fair quality in subjects with bacteriologic-confirmed, active TB because no reference standard for direct diagnosis of LTBI exists.51-100

##### Study Characteristics

Thirteen studies estimated sensitivity for TST,51-55,57,62,69,70,73-75,98 16 studies for T-SPOT.TB,56,60, 61,64,67,69,71,75,78-80,82,83,86-88 16 studies for QFT-G,55,56,59,65-72,77,84,85,87,88 and 24 studies for QFT-GIT.51,57,58,63-65,73,74,76,81,83,86,88-96,98-100 Characteristics of studies are provided in Appendix D Tables 1 (TST) and 2 (IGRA). One study started using QFT-G but converted to using QFT-GIT midway through the study.97 Eight studies estimating sensitivity were conducted in countries with a high TB burden,51,57,58,63,76,78,95,96 29 were conducted in countries with an intermediate TB burden,55,64-73,75,79-85,88-94,97,98,100 and 10 were conducted in countries with a low TB burden,52-54,56, 59-62,74,77 including four in the United States. Three multinational studies were conducted in a mix of low- and intermediate-burden countries.86,87,99 Sixteen studies were conducted in countries with a Human Development Index of less than “very high.”51,57,58,63,69,70,75,76,78,82,83,87,90,91,95,96 Twenty-nine studies provided stratified results for the HIV-negative segment of their study population or excluded patients with HIV from the study population.51,53-57,60,62-64,66-70,73,74,76,77,80, 81,85,88,89,91,92,95,96,98 Three studies were conducted in a study population in which less than 25 percent of the study participants had received BCG vaccination.58,76,77 Thirteen studies included between 25 and 75 percent vaccinated populations54,55,57,62,63,65,67,68,72,74,91,93,94 and 12 studies included more than 75 percent vaccinated populations.51,56,69-71,75,84,85,87,95,96,98 Twenty-two studies did not report the BCG vaccination prevalence in the study population. The timing of testing with respect to starting antituberculosis treatment varied across studies by the following categories: prior to or within 7 days (20 studies),53,56,57,62,63,65,67,69-71,74,76,77,81,84,87,92,95,96,100 within 14 days (four studies),59,60,64,86 within 30 days (one study),75 or not reported (25 studies).51,52,54,55, 58,61,66,68,72,73,78-80,82,83,85,88-91,93,94,97-99

##### Results

We calculated pooled estimates for sensitivity of TST by induration threshold and of IGRA by assay (Table 1; Figures 3 and 4). The pooled sensitivity of TST was 0.79 (95% CI, 0.69 to 0.89; I^2^=94.6%) for a 5-mm threshold, 0.79 (95% CI, 0.71 to 0.87; I^2^=91.4%) for a 10-mm threshold, and 0.52 (95% CI, 0.35 to 0.68, I^2^=95.5%) for a 15-mm threshold. For the T-SPOT.TB IGRA, we found no difference in estimates based on whether the FDA or European threshold for positivity was used, so we combined all studies for a pooled estimate of 0.90 (95% CI, 0.87 to 0.93; I^2^=63.6%) (Appendix F Figure 19). We found lower estimates for sensitivity of the QFT tests; the pooled estimate for sensitivity of QFT-G was 0.77 (95% CI, 0.74 to 0.81; I^2^=55.3%) and was 0.80 (95% CI, 0.77 to 0.84; I^2^=74.3%) for QFT-GIT. The percent of IGRA tests with indeterminate results ranged from 3 to 7 percent in studies reporting this information.

Table 1 Summary of Sensitivity Estimates for Various Thresholds of the Tuberculin Skin Test and Interferon-Gamma Release Assays Among Patients With Bacteriologic-Confirmed Tuberculosis

Test | Number of Studies (Total N) | Pooled Sensitivity Estimate (95% CI); I^2^ | Individual Study Sensitivity Estimate (95% CI); N
TST (5-mm threshold) | 8 (803) | 0.79 (0.69 to 0.89)^*^; 94.6% | See Figure 3
TST (10-mm threshold) | 11 (988) | 0.79 (0.71 to 0.87); 91.4% | See Figure 3
TST (15-mm threshold) | 7 (740) | 0.52 (0.35 to 0.68); 95.5% | See Figure 3
IGRA: T-SPOT.TB | 16^†^ (984) | 0.90 (0.87 to 0.93); 63.6% | See Figure 4
IGRA: QFT-G | 17 (1,073) | 0.77 (0.74 to 0.81); 55.3% | See Figure 4
IGRA: QFT-GIT | 24 (2,321) | 0.80 (0.77 to 0.84); 74.3% | See Figure 4
IGRA: QFT-G and QFT-GIT | 1 | NA | 0.71 (0.64 to 0.77); 181^97^

* Estimates from a maximum-likelihood random-effects model yielded slightly different estimate (0.84 [95% CI, 0.68 to 0.92]).

† One study61 could not be included in the pooled estimate due to a point estimate for sensitivity of 1.0 (95% CI, 0.69 to 1.0). The estimate using the maximum likelihood approach, which can accommodate point estimates of 1.0, was similar (0.90 [95% CI, 0.86 to 0.93]).

Abbreviatons: CI=confidence interval; IGRA=interferon-gamma release assay; N=number of patients; NA=not applicable; QFT-G=QuantiFERON-TB Gold (2nd-generation test); QFT-GIT=QuantiFERON-TB Gold In-Tube (3rd-generation test); TST=tuberculin skin test.

Figure 3 Individual Study and Pooled Estimates of Sensitivity for Various Thresholds of the Tuberculin Skin Test for Tuberculosis Infection

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Figure 3 displays a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at 5-mm, 10-mm, and 15-mm thresholds for a positive test. The pooled sensitivity estimate for 8 studies at 5 mm is 0.79, with a 95% confidence interval of 0.69 to 0.89 and a sample size of 803. The pooled sensitivity estimate for 11 studies at 10 mm is 0.79, with a 95% confidence interval of 0.71 to 0.87 and a sample size of 988. The pooled sensitivity estimate for 7 studies at 15 mm is 0.52, with a 95% confidence interval of 0.35 to 0.68 and a sample size of 740.

Figure 4 Individual Study and Pooled Estimates of Sensitivity for Interferon-Gamma Release Assay Tests for Tuberculosis Infection

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; Int=intermediate; N=number; NR=not reported; QFT-G=QuantiFERON-TB Gold (2nd- generation test); QFT-GIT=QuantiFERON-TB Gold In-Tube (3rd-generation test); TB=tuberculosis.

Figure 4 is a forest plot of fair- or good-quality studies reporting sensitivity for three different commercial interferon-gamma release assay tests: T-SPOT.TB, QFT-G, and QFT-GIT. The pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93 and a sample size of 984. The pooled sensitivity estimate for 17 studies using QFT-G is 0.77, with a 95% confidence interval of 0.74 to 0.81 and a sample size of 1073. The pooled sensitivity estimate for 24 studies using QFT-GIT is 0.80, with a 95% confidence interval of 0.77 to 0.84 and a sample size of 2321. One study reported a sensitivity estimate using QFT-G and GFT-GIT combined of 0.71, with a 95% confidence interval of 0.64 to 0.77 and a sample size of 181.

In a sensitivity analysis, we added the 14 studies81,85,101-112 that were excluded for poor quality and found that estimates did not appreciably change (Appendix D Tables 5 and 6; Appendix F Figures 1 and 2). We repeated all analyses using a maximum likelihood–based method for random effects and found similar results, except for a slightly higher point estimate for TST at a 5-mm threshold (Appendix F Figures 4 and 5).

Because we found moderate to substantial statistical heterogeneity, we stratified results for all tests based on factors that were consistently reported across studies and could impact the accuracy of the test (Appendix F Figures 7–31). Factors that might lower sensitivity include testing that occurs after antituberculosis treatment has been started and higher proportion of study subjects with HIV or other immunosuppressing conditions. Other factors that might affect accuracy include country TB burden and BCG vaccination prevalence among the study population. Our analyses stratified by these two factors were similar because the prevalence of BCG vaccination among the study population is often correlated with the country's TB burden; BCG vaccination is common in countries with an intermediate and high TB burden compared with countries with a low TB burden.

The stratified analyses identified heterogeneity between strata for several of these factors but are limited by few studies in some of the strata we evaluated. Factors influencing sensitivity estimates were not consistent among all tests (or induration thresholds for TST), limiting our ability to draw definitive conclusions. For some tests, estimates for sensitivity were higher in countries with a low TB burden compared with countries with an intermediate or high TB burden. For example, sensitivity of TST at a 10-mm induration threshold was 0.88 (95% CI, 0.76 to 0.99; 3 studies, N=424) compared with 0.72 in countries with an intermediate burden (95% CI, 0.65 to 0.79; 6 studies, N=416) (Appendix F Figure 13). We could not identify sources of heterogeneity for sensitivity estimates that were consistently present across the studies of the three IGRA tests.

#### Specificity of Screening Tests

Similarly, because no direct test for LTBI exists, we relied on 18 primary studies in countries with a low or intermediate TB burden among healthy persons known to be free of TB risks and exposures to estimate specificity.53,54,69,75,86,93,113-124

##### Study Characteristics

Fourteen studies estimated specificity of TST,53,54,69,75,113-118,120-123 five studies for T-SPOT.TB,69, 75,86,121,123 three studies for QFT-G,69,118,119 and four studies for QFT-GIT.86,93,123,124 Characteristics of studies are described in Appendix D Tables 3 and 4. All studies were conducted in countries with a Human Development Index of “very high.” Three studies were conducted in countries with an intermediate TB burden;69,75,93 one study was conducted in two countries, one with a low TB burden and the other intermediate;86 and the remaining 14 studies were conducted in countries with a low TB burden (10 in the United States). Four studies were conducted in populations with more than 75 percent BCG vaccination,69,75,93,122 nine studies included less than 5 percent BCG-vaccinated participants,53,54,113,114,117,118,120,121,123 and BCG vaccination was not reported in five studies.86,116,119,124,125

##### Results

We calculated a pooled estimate for specificity of TST at a 10-mm threshold of 0.97 (95% CI, 0.96 to 0.99; I^2^=94.3%) and at a 15-mm threshold of 0.99 (95% CI, 0.98 to 0.99; I^2^=91.7%). The pooled estimate for specificity of T-SPOT.TB was 0.95 (95% CI, 0.92 to 0.98; I^2^=79.1%). The pooled estimate for specificity of QFT-G was 0.98 (95% CI, 0.90 to 1.0) and the pooled estimate for QFT-GIT was 0.97 (95% CI, 0.94 to 0.99; I^2^=93.4%). The limited number of available studies precluded quantitative synthesis for TST at a 5-mm threshold. Estimates are summarized in Table 2 and Figure 5. The percentage of IGRA tests with indeterminate results ranged from 0 to 3 percent in studies reporting this information.

Table 2 Summary of Specificity Estimates for Various Thresholds of the Tuberculin Skin Test and Interferon-Gamma Release Assays Among Healthy Subjects Without Tuberculosis Exposures or Risks

Test | Number of Studies (Total N for Pooled Studies) | Pooled Specificity Estimate (95% CI); I^2^ | Individual Study Specificity Estimate (95% CI); N
TST (5-mm threshold) | 4 | NA^*^ | 0.30 (0.19 to 0.44); 47^69^ 0.95 (0.94 to 0.96); 2,848^54^ 0.94 (0.92 to 0.95); 1,750^122^ 0.97 (0.95 to 0.98); 551^120^
TST (10-mm threshold) | 9^†^ (9,651) | 0.97 (0.96 to 0.99); 94.3% | See Figure 5
TST (15-mm threshold) | 12 (9,640) | 0.99 (0.98 to 0.99); 91.7% | See Figure 5
IGRA: T-SPOT.TB | 5 (1,810) | 0.95 (0.92 to 0.98)^‡^; 79.1% | See Figure 5
IGRA: QFT-G | 4 (699) | 0.98^§^ (0.90 to 1.0) | See Figure 5
IGRA: QFT-GIT | 4 (2,053) | 0.97 (0.94 to 0.99); 93.4% | See Figure 5

* Studies not pooled as one study estimate from an intermediate-TB-burden country was much lower than the estimates from low-TB-burden countries.

† One study121 could not be included in the DerSimonian and Laird pooled estimate because of a point estimate for specificity of 1.0 (95% CI, 0.99 to 1.00). The estimate using the maximum likelihood approach, which can accommodate point estimates of 1.0, was similar (0.97 [95% CI, 0.93 to 0.99]).

‡ Estimates from a maximum-likelihood random-effects model yielded a slightly different estimate (0.93 [95% CI, 0.85 to 0.97]).

§ Pooled estimate is from a maximum-likelihood random-effects model because two studies included point estimates for specificity of 1.0. The I^2^ statistic is not calculated when using this model.

Abbreviations: CI=confidence interval; IGRA=interferon-gamma release assay; N=number analyzed; NA=not applicable; QFT-G=QuantiFERON-TB Gold (2nd-generation test); QFT-GIT=QuantiFERON-TB Gold In-Tube (3rd-generation test); TST=tuberculin skin test.

Figure 5 Individual Study and Pooled Estimates of Specificity for Various Thresholds of the Tuberculin Skin Test and Interferon-Gamma Release Assay Tests for Tuberculosis Infection

^a^ Excluded from pooled estimate due to point estimate of 1.0.

^b^ Pooled estimate from maximum-likelihood estimate random-effects model because of two studies with point estimates of 1.0. No I^2^ statistic is calculated using this model.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; Int=intermediate; N=number; NR=not reported; QFT-G=QuantiFERON-TB Gold (2nd-generation test); QFT-GIT=QuantiFERON-TB Gold In-Tube (3rd-generation test); TB=tuberculosis; TST=tuberculin skin test.

Figure 5 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at 5-mm, 10-mm, and 15-mm thresholds for a positive test and for three different commercial interferon-gamma release assay tests: T-SPOT.TB, QFT-G, and QFT-GIT. The pooled specificity estimate for 9 studies of the tuberculin skin test at 10 mm is 0.97, with a 95% confidence interval of 0.96 to 0.99 and a sample size of 9651. The pooled specificity estimate for 12 studies of the tuberculin skin test at 15 mm is 0.99, with a 95% confidence interval of 0.98 to 0.99 and a sample size of 9640. The pooled specificity estimate for 5 studies using T-SPOT.TB is 0.95, with a 95% confidence interval of 0.92 to 0.98 and a sample size of 1810. The pooled specificity estimate for 4 studies using QFT-G is 0.98, with a 95% confidence interval of 0.90 to 1.00 and a sample size of 669. The pooled specificity estimate for 4 studies using QFT-GIT is 0.97, with a 95% confidence interval of 0.94 to 0.99 and a sample size of 2053.

As part of a sensitivity analysis, we added five studies94,103,105,108,126 that had been excluded for poor quality and found similar results (Appendix D Tables 7 and 8; Appendix F Figure 3). We repeated all analyses using a maximum likelihood–based method for random effects and found similar point estimates but with slightly larger CIs (Appendix F Figure 6). Because of substantial heterogeneity among studies, we stratified results based on country TB burden and BCG vaccination prevalence (Appendix F Figures 32–44). Across all tests, specificity was substantially lower in countries with an intermediate TB burden than in countries with a low TB burden, yet removing these studies had marginal effect on the overall pooled estimates and inconsistency as measured by I^2^. For example, at the TST threshold of 10 mm, we removed the one study conducted in a country with an intermediate TB burden that had a specificity of 0.45; the pooled estimate changed from 0.97 to 0.98 and the I^2^ statistic was reduced from 94.3 to 91.2 percent (Appendix F Table 34).

#### Reliability of Screening Tests

We identified nine studies of good or fair quality assessing the reliability of at least one of the included screening tests.75,113,114,123,127-131

##### Study Characteristics

Study characteristics are shown in Appendix D Table 9. Three studies assessed the interrater reliability of TST.113,114,123 Two studies assessed the interrater reliability of T-SPOT.TB,75,128 one assessed the interrater reliability of QFT-GIT,130 and one assessed the interlaboratory reliability of QFT-GIT.129 Two studies assessed the test-retest reliability of T-SPOT.TB and QFT-GIT 1 to 4 weeks after an initial test.127,131,132 Eight studies were conducted in countries with a low TB burden (seven in the United States and one in the Netherlands), one study was conducted in a country with an intermediate TB burden75 (Turkey), and one study enrolled Nepalese military recruits who had left Nepal and recently entered the United Kingdom.131 Two studies reported the percentage of the study population that had HIV; less than 1 percent in both studies were HIV positive.127,131 In two studies the majority of participants were BCG vaccinated.75,131

##### Results

Interrater reliability. Three studies (N=1,826,^123^ N=1,189,^114^ and N=127^113^) measured the interrater reliability of TST results by reporting the kappa statistic for agreement by TST reaction size; results ranged from 0.55 to 0.79, indicating moderate to substantial agreement between two observers. One study (N=91) found substantial agreement between two observers for manually reading T-SPOT.TB results (kappa=0.92) and manual versus automatic enzyme-linked immunosorbent spot (ELISpot) readings (kappa=0.73).75 One study (N=313) evaluated agreement among six individual ELISpot readers; all kappa values were greater than 0.6.^128^ One study (N=146) assessed interrater reliability for manual versus automated enzyme-linked immunosorbent assay readings for QFT-GIT; each study participant had two blood draws and each sample was sent for both automated and manual readings.130 Across all samples, 88.6 percent of results were concordant and 11.0 percent were discordant; the discordance rates for specific comparisons were 4.8 percent (between two different automated readings, kappa=0.85), 6.9 percent (between two different manual readings, kappa=0.80), and 3.4 percent (manual compared with automated readings, kappa ranged from 0.73 to 0.90 across comparisons).130

Interlaboratory reliability. One study (N= 91) evaluated the interlaboratory reliability of QFT-GIT by sending three blood specimens from each participant to three different laboratories noted to have extensive experience and proficiency with IGRA testing and interpretation.129 Across all three laboratories, 7.7 percent of participants had discordant results (none had indeterminate results); kappas of pairwise laboratory sample comparisons ranged from 0.87 to 0.93.^129^

Reproducibility and test-retest reliability. One study (N= 130) assessed the reliability of IGRA results by processing two blood samples from each study participant (using the same laboratory and same type of test interpretation); 5.8 percent of participants had discordant results for QFT-GIT and 6.5 percent had discordant results for T-SPOT.TB.127 Two studies measured the test-retest reliability of QFT-GIT. One study enrolled U.S. health care workers127 and one enrolled a population from a country with a high TB burden (Nepal).131,132 In the study (N=130) enrolling health care workers, 8 percent of baseline T-SPOT.TB negative tests changed to positive and 53 percent of positive tests changed to negative on repeat testing at 2 weeks; for QFT-GIT, 8 percent of negative tests changed to positive and 33 percent of positive tests changed to negative.127 Finally, in the study enrolling a Nepalese population, the kappa statistic for agreement between initial QFT-GIT test and retest at 1 week was 0.48 (95% CI, 0.26 to 0.70) and was 0.66 (95% CI, 0.5 to 0.83) for T-SPOT.TB.131

### KQ 2b Accuracy and Reliability of Sequential Screening Strategies

We found no eligible studies that addressed this question.

### KQ 3 Benefits of Treatment of LTBI

We included three RCTs (Thompson 1982, Menzies 2008, Sterling 2011) assessing treatment of LTBI that met all eligibility criteria (Appendix D Table 10).133-135 One compared isoniazid with placebo,135 one compared rifampin with isoniazid,133 and one compared rifapentine plus isoniazid with isoniazid alone.134

We identified four additional RCTs (Bush 1965, Falk 1978, Ferebee 1963, Veening 1968) that compared isoniazid with placebo that did not meet all eligibility criteria but were used in sensitivity analyses (Appendix D Table 13). For RCTs to be included in sensitivity analyses, we required that they either confirmed LTBI for subjects to be eligible (e.g., by enrolling only those who were tuberculin positive), reported data for subjects with confirmed LTBI (e.g., for the tuberculin-positive subset of subjects), or that the vast majority of subjects (>75%) were tuberculin positive. These trials met many of our eligibility criteria but used a longer duration of treatment than is currently recommended by the CDC41-44 (i.e., ≥1 year of isoniazid), and some used lower or higher doses than currently recommended42,43 or did not require LTBI confirmation for subjects to be eligible.41,43,44 One of the four trials was rated poor quality for high risk of selection bias, attrition bias, confounding, and measurement bias.42

Our searches identified additional RCTs that compared isoniazid with placebo, which we excluded from this review. Reasons for excluding studies from this review are listed in Appendix C. For example, several trials focused on the use of isoniazid among household contacts of active TB cases but did not require LTBI confirmation for study entry;136-138 more than half of the participants in these trials were children; trials evaluated 1 year or more of isoniazid treatment; and one trial used a higher dose138 than is currently recommended by the CDC. Two other trials randomized households or villages to evaluate the prophylactic use of isoniazid in areas with a high prevalence of active TB at the time of the study (Greenland139 or Alaska140). These two trials did not require LTBI confirmation for study entry. One trial evaluated an unusual isoniazid regimen (400 mg for 3 months, nothing for 3 months, then 400 mg for 3 months139); the other evaluated 1 year of isoniazid and included many children.140 Other excluded RCTs evaluated patients with silicosis141 or renal transplant and dialysis patients.142

#### Isoniazid Compared With Placebo

The International Union Against Tuberculosis (IUAT) trial was the single trial meeting all eligibility criteria that compared isoniazid with placebo.135 It randomized 27,830 adults from seven European countries with fibrotic pulmonary lesions but not active TB or previous antituberculosis treatment to four groups: isoniazid 300 mg daily for 12 weeks, isoniazid 300 mg daily for 24 weeks (currently a CDC-approved regimen), isoniazid 300 mg daily for 52 weeks, or placebo. Participants were required to have an induration of 6 mm or larger on TST. The median age was 50 years and 53 percent were men.

After 5 years of followup, 76 (1.1%), 34 (0.5%), 24 (0.3%), and 97 (1.4%) participants developed active TB in the four groups, respectively (Appendix D Table 11). The RRs for developing active TB compared with placebo were 0.79 (95% CI, 0.58 to 1.06), 0.35 (95% CI, 0.24 to 0.52), and 0.25 (95% CI, 0.16 to 0.39), respectively (Figure 6). For the 24-week CDC approved regimen, we calculated a number needed to treat (NNT) of 112 to prevent 1 case of active TB. Our sensitivity analyses using data from the 24- and 52-week groups from the IUAT trial and four additional RCTs, including a total of 36,823 participants, found an RR of 0.31 (95% CI, 0.24 to 0.41) and no statistical heterogeneity in effects between studies (I^2^=0.0%) (Figure 7; Appendix D Table 14).

Figure 6 Isoniazid Compared With Placebo: Relative Risk of Developing Active Tuberculosis in the IUAT Trial

Abbreviations: CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; RR=relative risk.

Figure 6 is a forest plot of the relative risks of developing active TB in the IUAT trial comparing isoniazid at three different treatment durations vs. placebo. The relative risk for developing active TB following 12 weeks of isoniazid compared with placebo was 0.79, with a 95% confidence interval of 0.58 to 1.06. The relative risk for developing active TB following 24 weeks of isoniazid compared with placebo was 0.35, with a 95% confidence interval of 0.24 to 0.52. The relative risk for developing active TB following 52 weeks of isoniazid compared with placebo was 0.25, with a 95% confidence interval of 0.16 to 0.39.

Figure 7 Isoniazid Compared With Placebo: Relative Risk of Developing Active Tuberculosis, Sensitivity Analysis Including Data From the IUAT Trial and Four Additional Randomized, Controlled Trials

Notes: For Thompson 1982^135^ (IUAT trial), we included data from the 24- and 52-week groups. For Bush 1965,^43^ we only used data for participants age ≥20 years. For Falk 1978,^41^ we used data for the subset with no previous tuberculosis therapy for participants in the isoniazid 1-year group (we did not include data for the isoniazid 2-year group). For Ferebee 1963,^44^ we used only the subset that was tuberculin positive; we were unable to get adult-only data to enter here (for the full study sample, 34 of the 51 cases in the placebo arm were among adults, and it was not reported how many of the 19 total cases in the isoniazid arm were among adults).

For trials other than the IUAT trial to be included in this sensitivity analysis, we required that they either confirmed LTBI for subjects to be eligible, reported data for subjects with confirmed LTBI, or that the vast majority of subjects (>75%) were tuberculin positive. These trials met many of our eligibility criteria but used a longer duration of treatment than is currently recommended by the Centers for Disease Control and Prevention (i.e., ≥1 year of isoniazid), and some used lower or higher doses than currently recommended42,43 or did not require LTBI confirmation for subjects to be eligible.41,43,44 One of the four trials was rated poor quality.42

Abbreviations: CI=confidence interval; LTBI=latent tuberculosis infection; INH=isoniazid; IUAT=International Union Against Tuberculosis; mths=months; RR=relative risk.

Figure 7 is a forest plot of the relative risks of developing active TB based on a sensitivity analysis using data from the IUAT trial plus four additional RCTs comparing isoniazid vs. placebo. The overall relative risk for developing active TB following treatment with isoniazid vs. placebo is 0.31, with a 95% confidence interval of 0.24 to 0.41.

The IUAT trial found that persons with larger fibrotic pulmonary lesions had a greater risk of developing active TB. The incidence of active TB in the placebo group was half as great among persons with lesions smaller than 2 cm^2^ (11.6 cases per 1,000 population) than among persons with larger lesions (21.3 cases per 1,000 population).

There were no deaths due to TB in any of the isoniazid groups in the IUAT trial; three persons died from TB in the placebo group. The RR for death due to TB was 0.14 (95% CI, 0.01 to 2.78) for each of the isoniazid groups compared with placebo. All-cause mortality was not reported separately for the four groups. The trial reported benefit-to-risk ratios (defined as cumulative TB cases prevented/cumulative hepatitis cases incurred) of 1.2, 2.6, and 2.1 for the isoniazid groups compared with placebo, respectively.

#### Rifampin Compared With Isoniazid

The one included RCT making this comparison was an open-label trial conducted in Canada, Brazil, and Saudi Arabia that randomized 847 participants to 4 months of rifampin or 9 months of isoniazid to compare adverse events and treatment completion.133 Because this RCT was focused largely on adverse events, it is described in greater detail with the results for KQ 5. We mention it briefly in this section because it reported zero deaths from TB in either group. It also reported all-cause mortality, with zero deaths in the rifampin group and one in the isoniazid group.

#### Rifapentine Plus Isoniazid Compared With Isoniazid Alone

The one included RCT making this comparison, the PREVENT TB study, was an open-label, noninferiority trial conducted in the United States, Canada, Brazil, and Spain that randomized 7,731 persons age 12 years or older to directly observed once-weekly rifapentine (900 mg) plus isoniazid (900 mg) for 3 months or to daily self-administered isoniazid (300 mg) for 9 months.134 The primary endpoint was development of confirmed TB. Subjects were primarily from the United States and Canada (89% of those randomized) and were high-risk persons with a positive TST. Most (71%) had a close contact with a patient with culture-confirmed, active TB within the past 2 years; 25 percent were included solely because of recent conversion to TST positivity. Less than 3 percent of participants were HIV positive; the participants with HIV were not required to have a positive TST. Risk factors for TB included a history of incarceration (5.1%), history of injection drug use (3.7%), and homelessness (27.8%).

Almost 90 percent of subjects randomized completed 33 months of followup. Active TB developed in seven persons in the combination therapy group and in 15 persons in the isoniazid-only group. The combination therapy group was found to be noninferior to the isoniazid-only group. The trial identified 70 deaths from any cause (31 vs. 39 deaths; p=0.22).

From among the 7,731 randomized, we obtained data from the CDC for the subset of participants most directly relevant for this review: the 6,886 adults (age ≥18 years) who were HIV negative and TST or IGRA positive. The median age for this subset was 37 years, 54.2 percent were male, and 57 percent were white. For this subset, active TB developed in five persons in the combination therapy group and in 10 persons in the isoniazid-only group. The combination therapy group was found to be noninferior to the isoniazid-only group. Overall mortality was similar for the two groups (30 vs. 34 deaths, respectively; p=0.42).

### KQ 4 Harms of Screening for LTBI

We did not identify any studies addressing this question.

### KQ 5 Harms of Treatment of LTBI

We included five RCTs assessing harms associated with the treatment of LTBI that met all eligibility criteria (Appendix D Table 10).133-135,143,144 One compared isoniazid with placebo,135 three compared rifampin with isoniazid,133,143,144 and one compared rifapentine plus isoniazid with isoniazid alone.134

We identified five additional RCTs that evaluated harms associated with treatment of LTBI that did not meet all eligibility criteria but were used in sensitivity analyses (Appendix D Table 13). Criteria for RCTs to be included in sensitivity analyses for KQ 5 are the same as those described for KQ 3. The five additional trials met many of our eligibility criteria, but four of the five trials used a longer duration of treatment than is currently recommended by the CDC41,43,44,145 (i.e., ≥1 year of isoniazid), one used a shorter duration than is currently recommend by the CDC (3 months of isoniazid),146 and some used a lower dose than currently recommended43 or did not require LTBI confirmation for subjects to be eligible.41,43,44,145,146 We rated two of these trials as fair quality145,146 and the other three as poor quality.41,43,44 Our searches identified additional RCTs and one observational study that compared isoniazid with placebo, which we excluded from this review. Reasons for excluding studies from this review are listed in Appendix C.

From this body of evidence, we were able to quantitatively synthesize harms related to hepatotoxicity and discontinuation of medication due to adverse events. Studies also reported a variety of gastrointestinal (GI) adverse events, but we were unable to quantitatively synthesize these outcomes because of heterogeneity in how they were measured across included studies. For example, GI adverse events were reported as a single combined value per treatment arm in one study,43 as rates of treatment discontinuation due to GI events in another study,147 and by separate types of GI events (i.e., nausea, clay-colored stools, or anorexia) with no summary rate in a third study.146 No studies reported harms related to peripheral neuropathy or development of drug-resistant TB.

#### Isoniazid Compared With Placebo

The IUAT trial was the single trial meeting all eligibility criteria that compared isoniazid with placebo.135,147 Study characteristics for this trial were previously described (see KQ 3 results); the quality of this study was rated as fair for KQ 5 outcomes because harm outcomes were not prespecified and ascertainment techniques were not adequately described, except for the hepatotoxicity outcomes.

##### Hepatotoxicity

The IUAT trial reported rates of hepatotoxicity development (Appendix D Table 12).135 The RRs for developing hepatotoxicity associated with isoniazid compared with placebo were 3.45 (95% CI, 1.49 to 7.99) for 12 weeks of treatment, 4.59 (95% CI, 2.03 to 10.39) for 24 weeks of treatment, and 6.21 (95% CI, 2.79 to 13.79) for 52 weeks of treatment (Figure 8). For the study arms comparing the 24-week CDC-approved regimen with placebo (N=13,955), we calculated that 1 case of hepatotoxicity would result from treating 279 persons with isoniazid (i.e., a number needed to harm [NNH] of 279). Our sensitivity analyses using data from the IUAT trial (three treatment arms combined) and three additional RCTs,41,145,146 including a total of 35,161 participants, found an RR of 5.04 (95% CI, 2.50 to 10.15) and no statistical heterogeneity among studies (I^2^=0.0%; p=0.630) (Appendix G Figure 1).

Figure 8 Isoniazid Compared With Placebo: Relative Risk of Developing Hepatotoxicity in the IUAT Trial

Notes: For Thompson 1982^135^ (IUAT trial), we included data from the 12-, 24-, and 52-week groups. A definition for hepatotoxicity (presented as “hepatitis” in this study) was not reported.

Abbreviations: CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; RR=relative risk.

Figure 8 is a forest plot of the relative risks of developing hepatotoxicity in the IUAT trial comparing isoniazid at three different treatment durations vs. placebo. The relative risks for developing hepatotoxicity associated with isoniazid compared with placebo were 3.45 with a 95% confidence interval of 1.49 to 7.99 for 12 weeks of treatment, 4.59 with a 95% confidence interval of 2.03 to 10.39 for 24 weeks of treatment, and 6.21 with a 95% confidence interval of 2.79 to 13.79 for 52 weeks of treatment.

The one RCT included in the main analysis comparing isoniazid with placebo for treatment of LTBI135 reported mortality rates from hepatotoxicity of 0.03 percent, 0.0 percent, and 0.01 percent for the 12-, 24-, and 52-week isoniazid treatment groups, respectively. This study had zero deaths from hepatotoxicity among placebo-treated patients. The authors reported that the mortality rate from hepatitis associated with isoniazid was 0.14 deaths per 1,000 persons receiving isoniazid, for a calculated RR of 2.35 (95% CI, 0.12 to 45.46; NNH, 6,947).

##### Treatment Discontinuation Because of Adverse Events

Rates of treatment discontinuation because of adverse events in the IUAT trial were presented only for all three isoniazid treatment groups combined. A total of 345 patients (1.8%) receiving isoniazid discontinued treatment because of adverse events compared with 84 patients (1.2%) receiving placebo. The RR of discontinuation due to adverse events among patients treated with isoniazid versus placebo was 1.50 (95% CI, 1.18 to 1.89; 1 RCT, N=27,830; NNH, 167). Our sensitivity analysis using data from the IUAT trial and three additional RCTs,43,44,146 including a total of 55,398 participants, found an RR of 1.58 (95% CI, 1.00 to 2.49; I^2^=70.2) (Appendix G Figure 2).

##### GI Adverse Events

The IUAT trial reported that 1.2 percent of isoniazid patients and 0.9 percent of placebo patients discontinued treatment due to GI distress.147 The RR of discontinuation due to GI distress among isoniazid versus placebo patients was 1.33 (95% CI, 1.01 to 1.75). Among studies included in sensitivity analyses, one43 reported GI adverse events (0.7% in isoniazid group vs. 0.3% in placebo group) and one146 reported nausea (3.3% in isoniazid group vs. 1.7% in placebo group), clay-colored stools (10.0% in isoniazid group vs. 5.0% in placebo group), and anorexia (8.3% in both isoniazid and placebo groups).

##### Other Harms

No other adverse events were reported in the IUAT trial.135 A variety of other adverse events were reported in the RCTs included in sensitivity analyses. Rates of other adverse events were generally similar among isoniazid and placebo patients (Appendix D Table 15). One study reported an increased risk for rash (0.9% of isoniazid patients and 0.3% of placebo patients; RR, 2.7 [95% CI, 1.27 to 5.73]).41,148

#### Rifampin Compared With Isoniazid

Three open-label RCTs compared rifampin with isoniazid (Appendix D Table 10). One trial conducted in Canada (N=116) compared 4 months of rifampin (10 mg/kg of body weight, up to 600 mg/day) with 9 months of isoniazid (5 mg/kg, up to 300 mg/day).143 Participants were age 18 years or older with documented LTBI; more than half were male. A later study by the same authors conducted in Canada, Brazil, and Saudi Arabia randomized 847 participants to the same two treatments.133 Participants were age 18 years or older with documented LTBI; just over half were male. The third trial randomized inmates (N=365) in the San Francisco City and County Jail diagnosed with LTBI at jail entry to 9 months of isoniazid (900 mg twice per week) or 4 months of rifampin (600 mg/day).144 Ninety-three percent of study participants were male.

##### Hepatotoxicity

Rates of hepatotoxicity in these three RCTs among patients receiving isoniazid were 5.2 percent,143 3.7 percent,133 and 11.4 percent144 (Appendix D Table 12). Rates among rifampin-treated patients were 0.0 percent, 0.7 percent, and 4.4 percent, respectively. The RRs of hepatotoxicity from these three RCTs of isoniazid compared with rifampin were 7.00 (95% CI, 0.37 to 132.56), 5.25 (95% CI, 1.54 to 17.87), and 2.57 (95% CI, 1.17 to 5.65), respectively. Our meta-analysis of these three RCTs (total N=1,327) found a greater risk of hepatotoxicity for patients treated with isoniazid than for those treated with rifampin (RR, 3.29 [95% CI, 1.72 to 6.28]; I^2^=0.0%) (Figure 9). All studies reported zero deaths from hepatotoxicity.

Figure 9 Isoniazid Compared With Rifampin: Relative Risk of Developing Hepatotoxicity, Data From Three Randomized, Controlled Trials

Notes: For Menzies 2004, hepatotoxicity was defined as liver transaminase (alanine transaminase) levels more than 3 times the upper limits of normal with symptoms, or transaminase levels more than 5 times the upper limits of normal without symptoms. For Menzies 2008, hepatotoxicity includes both grade 3 and grade 4 hepatotoxicity. Liver aminotransferase levels that increased to 5 to 10 or 3 to 10 times the upper limit of normal in the presence of compatible symptoms met criteria for grade 3 hepatotoxicity, whereas those that exceeded 10 times the upper limit of normal met criteria for grade 4 toxicity. For White 2012, hepatotoxicity was defined as liver function tests greater than 3 times the upper limit of normal.

Abbreviations: CI=confidence interval; INH=isoniazid; RIF=rifampin; RR=relative risk.

Figure 9 is a forest plot of the relative risks of developing hepatotoxicity in three RCTs comparing isoniazid with rifampin. The overall relative risk for developing hepatotoxicity associated with isoniazid treatment vs. rifampin treatment is 3.29, with a 95% confidence interval of 1.72 to 6.28.

##### Treatment Discontinuation Because of Adverse Events

Rates of discontinuation because of adverse events were reported in all three included RCTs. Rates were 13.8 percent (isoniazid) and 3.4 percent (rifampin);143 5.6 percent (isoniazid) and 3.8 percent (rifampin);133 and 0.0 percent (isoniazid) and 1.1 percent (rifampin)144 (Appendix D Table 12). The RR of discontinuation due to adverse events for isoniazid compared with rifampin for these three studies was 4.0 (95% CI, 0.89 to 18.04), 1.48 (95% CI, 0.80 to 2.74), and 0.20 (95% CI, 0.01 to 4.05), respectively. Our meta-analysis found no statistically significant difference between treatments (RR, 1.61 [95% CI, 0.57 to 4.57]; I^2^=40.0%; N=1,327) (Figure 10).

Figure 10 Isoniazid Compared With Rifampin: Relative Risk of Treatment Discontinuation Due to Adverse Events, Data From Three Randomized, Controlled Trials

Notes: For Menzies 2004, adverse events that resulted in permanent discontinuation of therapy were hepatitis, severe nausea and vomiting, persistent debilitating fatigue, and rash. For Menzies 2008, a blinded review panel judged the type and severity of the adverse event and its likely relationship to the study drug. The total presented reflects permanent discontinuation of therapy due to any adverse event (grade 1–4) judged to be probably drug related. These adverse events were hepatotoxicity, hematologic, drug interaction, rash, and gastrointestinal intolerance. For White 2012, treatment discontinuation adverse events were elevated liver function tests and nausea/vomiting.

Abbreviations: CI=confidence interval; INH=isoniazid; RIF=rifampin; RR=relative risk.

Figure 10 is a forest plot of the relative risks of treatment discontinuation in three RCTs comparing isoniazid with rifampin. The overall relative risk for treatment discontinuation associated with isoniazid vs. rifampin treatment is 1.61, with a 95% confidence interval of 0.57 to 4.57.

##### GI Adverse Events

Among the three included RCTs, one reported GI adverse events in 3.4 percent of the study population, not separated by treatment arm.143 One reported grade 1/2 GI intolerance among 0.2 percent of rifampin patients and 0.5 percent of isoniazid patients.133 The third study reported GI adverse events among 9 percent of rifampin patients and 10 percent of isoniazid patients.144 The pooled RR among the two studies reporting adverse events by treatment arm was 1.60 (95% CI, 0.76 to 3.40; I^2^=0%; N=1,211).

##### Other Harms

The three RCTs in the main analysis reported on various other harms (Appendix D Table 12). None of these harms involved statistically significant differences in RR for isoniazid compared with rifampin. The pooled RR for adverse events categorized as “other” by two RCTs was 0.82 (95% CI, 0.42 to 1.59; 3 RCTs; I^2^=0%; N=480).143,144

#### Rifapentine Plus Isoniazid Compared With Isoniazid

The one included RCT making this comparison, the PREVENT TB study, was an open-label, noninferiority trial conducted in the United States, Canada, Brazil, and Spain that randomized 7,731 persons age 12 years or older to directly observed once-weekly rifapentine at 900 mg plus isoniazid at 900 mg for 3 months, or to daily self-administered isoniazid at 300 mg for 9 months.134 More details regarding this study are presented in the results section on benefits of treatment (KQ 3).

##### Hepatotoxicity

Rates of grade 3 and 4 hepatotoxicity were 4.9 and 1.0 percent in the rifapentine plus isoniazid arm and 5.5 and 1.1 percent in the isoniazid-only arm, respectively. The RR for grade 3 or 4 hepatotoxicity was 0.90 (95% CI, 0.75 to 1.08). Mortality from hepatotoxicity was reported in 1.0 percent of isoniazid patients and 0.8 percent of isoniazid plus rifapentine patients (RR, 0.83 [95% CI, 0.51 to 1.35]).

##### Treatment Discontinuation Because of Adverse Events

Rates of discontinuation because of adverse events were 5.2 percent in the rifapentine plus isoniazid arm and 4.1 percent in the isoniazid-only arm. The RR of treatment discontinuation due to adverse events for the rifapentine plus isoniazid versus isoniazid-only arm was 1.28 (95% CI, 1.03 to 1.59).

##### Other Harms

Possible hypersensitivity was reported in 0.5 percent of isoniazid patients and 4.1 percent of isoniazid plus rifapentine patients. The RR of possible hypersensitivity for rifapentine plus isoniazid versus isoniazid-only patients was 8.04 (95% CI, 4.88 to 13.26).