# Methods

## KQs and Analytic Framework

The Evidence-based Practice Center investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and KQs for this review. The analytic framework illustrates the KQs that guided the review (Figure 1).

1 Is there direct evidence that targeted screening for LTBI in primary care settings in asymptomatic adults at increased risk for developing active TB disease (e.g., individuals in populations with a high prevalence of active TB disease or with documented increased risk for progression from LTBI to active TB disease) improves quality of life or reduces active TB disease incidence, transmission of TB, or disease-specific or overall mortality?
2a What is the accuracy and reliability of the TST or IGRA for screening asymptomatic adults who are at increased risk for developing active TB disease?
2b What is the accuracy and reliability of sequential screening strategies that include both TST and IGRA testing in asymptomatic adults who are at increased risk for developing active TB disease?
3 Does treatment of LTBI with CDC-recommended pharmacotherapy regimens improve quality of life or reduce progression to active TB disease, transmission of TB, or disease-specific or overall mortality?
4 Are there harms associated with screening for LTBI?
  a. Do these harms differ by screening method or strategy?
  b. Do these harms differ by population?
5 Are there harms associated with treatment of LTBI with CDC-recommended pharmacotherapy regimens?

Figure 1 Analytic Framework: Screening for Latent Tuberculosis Infection in Adults

Abbreviations: IGRA=interferon-gamma release assay; KQ=key question; LTBI=latent tuberculosis infection; QOL=quality of life; TB=tuberculosis; TST=tuberculin skin test.

Figure 1 is an analytic framework. The framework begins on the left with our population of interest: asymptomatic adults belonging to populations at increased risk. On the right side is the text “Screening: TST or IGRA.” A horizontal line connects “Screening: TST or IGRA” to an outcome box on the far right containing the text “Active TB disease;” “Reduction in transmission;” “Improved Quality of Life;” and “Reduced Mortality” to illustrate the focus of KQ1. A second horizontal arrow extends directly from the text “Screening: TST or IGRA” to a curved edge box labeled “LTBI” to illustrate the focus of KQ2. An arrow with a curvy line descends from the text “Screening: TST or IGRA” to an oval containing the text “Harms” to illustrate the focus of KQ4. A horizontal arrow labeled “Treatment” connects the curved edge box that includes the text “LTBI” to the outcome box on the far right that contains the text “Active TB disease;” “Reduction in transmission;” “Improved QOL;” and “Reduced Mortality” to illustrate the focus of KQ3. Below the horizontal line labeled “Treatment” descends a curvy line that connects to an oval labeled “Harms” to illustrate the focus of KQ5.

## Data Sources and Searches

With the assistance of a librarian with extensive experience conducting searches in support of systematic reviews, we searched PubMed/MEDLINE and the Cochrane Library for English-language articles published through August 3, 2015. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are listed in Appendix B1. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies that met our inclusion criteria, and added all previously unidentified relevant articles. We reviewed all studies suggested by peer reviewers or public comment respondents and, if appropriate, incorporated them into the final review. Since August 2015, ongoing surveillance has been conducted through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and therefore the related USPSTF recommendation. The last surveillance was conducted on May 31, 2016, and no new studies were identified.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs (Appendix B2). We excluded studies in which more than 25 percent of the study population was younger than age 18 years or known to be HIV positive, unless results were stratified by these characteristics. For KQ 1, we included RCTs or prospective cohort studies that compared screening with no screening in primary care settings and focused on asymptomatic adults belonging to populations at increased risk for developing active TB (e.g., injection drug users, persons who are homeless or residing in homeless shelters, former prisoners, persons born in or former residents of countries with high TB prevalence, and persons who work with such individuals). We excluded studies of close contacts of persons with active TB because testing and treatment of such populations is considered part of contact tracing for public health as opposed to a primary care function. We also excluded studies of persons with underlying immunosuppression and for whom LTBI screening and treatment would be part of standard disease management by specialty care providers (e.g., persons with HIV, head and neck cancer, leukemia or lymphoma, silicosis, history of or planned organ transplant, planned or active use of tumor necrosis factor-alpha inhibitors, and planned or active use of chemotherapy) because testing and treatment typically need to be individualized and managed with respect to the patient's comorbidities and medication regimens.

For KQ 2, because there is no direct test for LTBI,26 we relied on data from studies of persons with bacteriologic-confirmed, active TB to determine sensitivity or studies of healthy subjects known to be at low risk for TB and free of TB exposure to determine specificity. We included studies assessing the accuracy or reliability of three IGRAs (T-SPOT.TB, QFT-G, and QFT-GIT) using the commercially specified threshold but also reported results based on other thresholds when available. For studies assessing the accuracy of the TST using the Mantoux method, we required the use of intermediate-strength PPD. Systematic reviews or primary studies of test accuracy were eligible for KQ 2.

For KQs 3 and 5, we included RCTs of persons with LTBI comparing a CDC-recommended treatment (medication, dose, and duration) with placebo, delayed treatment, no treatment, or another CDC-recommended treatment. For KQ 5, prospective cohort studies and case-control studies were also eligible. For KQ 4, systematic reviews, RCTs, and prospective cohort studies reporting false-positive results leading to unnecessary testing (e.g., chest x-ray) or treatment, labeling, stigma, anxiety, or cellulitis were eligible.

For KQs 1, 3, 4, and 5, we included studies conducted in primary care settings in countries categorized as “very high” on the Human Development Index (as defined by the United Nations Human Development Programme). We defined primary care broadly to include public health settings or specialized clinics providing primary care functions (e.g., prison clinics). For KQ 2 sensitivity outcomes, we did not set any exclusion criteria based on setting or country; for KQ 2 specificity outcomes, we excluded studies conducted in countries with a high TB burden as defined by the World Health Organization (Appendix B2).30

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. Two investigators independently reviewed the full text to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

We assessed the quality of studies as good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3).31 Two independent reviewers assigned quality ratings for each study. Disagreements were resolved by discussion with an experienced team member. For our main analyses, we included only studies rated as having good or fair quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular or narrative format. To determine whether meta-analyses were appropriate, we assessed both the number of studies available and the clinical and methodologic heterogeneity of the studies following established guidance.32 To do this, we qualitatively assessed the populations, similarities and differences in screening tests or treatments used, and similarities in outcomes and timing of outcomes assessed.

For KQ 2, when at least three similar studies were available, we conducted quantitative synthesis of studies with random-effects models using the inverse-variance weighted method (DerSimonian and Laird) to determine pooled estimates of sensitivity and specificity.33 We generated pooled estimates by test for sensitivity and stratified by important covariates, such as the timing of testing with respect to when pharmacotherapy for TB was started,26 the prevalence of HIV among the study population, the TB burden in the country where the study was conducted, and, for T-SPOT.TB, the threshold used for positivity (FDA or European threshold).34,35 For specificity, we also generated pooled estimates by test and stratified by important covariates such as the prevalence of BCG vaccination in the study population and the TB burden of the country in which the study was conducted. For T-SPOT.TB, we also generated estimates stratified by the threshold for positivity. We qualitatively summarized reliability outcomes and sensitivity and specificity outcomes for some tests or induration thresholds using tables and narrative because we did not have a sufficient number of studies to conduct quantitative syntheses.

We conducted several types of sensitivity analyses. First, because DerSimonian and Laird random-effects models may not perform well for small meta-analyses (when few studies are included), we conducted sensitivity analyses using maximum likelihood random-effects methods.36-40 Results were essentially the same as for our main analyses, with some minor variation in width of CIs for some estimates. Therefore, the results from these analyses are only provided in the appendix and are not discussed in the text. Next, we did not include studies rated as poor quality in any main analyses but did include them in sensitivity analyses for KQ 2.

For KQ 3 and for most comparisons and outcomes related to KQ 5, we did not conduct meta-analyses for our main analysis because we did not have a sufficient number of studies meeting all eligibility criteria that made the same comparison and reported similar outcomes. Therefore, we synthesized the included studies qualitatively, using narrative and tables. We calculated the RR for outcomes of interest (e.g., development of active TB disease, mortality from TB, development of hepatotoxicity) using the number of all randomized patients as the denominator to reflect a true intention-to-treat analysis. For our main analyses for KQ 5, we conducted quantitative synthesis of RCTs comparing isoniazid with rifampin for the following outcomes: hepatotoxicity and discontinuation due to adverse events. For sensitivity analyses for KQs 3 and 5, we conducted quantitative synthesis of RCTs by adding excluded studies that compared isoniazid with placebo that met many of our inclusion criteria but used a longer duration of treatment than is currently recommended (e.g., ≥1 year of isoniazid),41-44 used lower or higher doses than currently recommended,42,43 or did not require LTBI confirmation for subjects to be eligible.41,43,44 For RCTs to be included in sensitivity analyses, we required that they either confirmed LTBI for subjects to be eligible (e.g., by enrolling only those who were tuberculin positive), reported data for subjects with confirmed LTBI (e.g., for the tuberculin-positive subset of subjects), or that the vast majority of subjects (>75%) were tuberculin positive. For these analyses, we used random-effects models with the inverse-variance weighted method (DerSimonian and Laird) to estimate RRs.45 We conducted quantitative synthesis for the following outcomes: development of active TB disease, hepatotoxicity (e.g., isoniazid-induced hepatitis), and discontinuation of treatment due to adverse events. Because DerSimonian and Laird random-effects models may not perform well for small meta-analyses (when few studies are included), we also conducted sensitivity analyses using profile likelihood random-effects methods.36-40 Results were essentially the same as for those using DerSimonian and Laird random-effects models, with some minor variation in width of CIs for some estimates.

For all quantitative syntheses, the chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess statistical heterogeneity in effects between studies.46,47 An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 to 100 percent represents considerable heterogeneity.48 The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence for heterogeneity (e.g., p-value from the chi-squared test or a CI for I^2^). However, as precision and the number of subjects increase, I^2^ may become inflated toward 100 percent and may not reflect clinically relevant heterogeneity.49

All quantitative analyses were conducted using Stata® version 13.1 (StataCorp, College Station, TX).50

## Expert Review and Public Comment

The draft analytic framework and draft research questions were made available for public comment and subsequently revised. A draft of this report was made available for public comment and reviewed by content and methodologic experts, USPSTF members, CDC experts, and AHRQ Medical Officers. It was revised based on comments received.

## USPSTF and CDC Involvement

This review was cofunded by AHRQ and the CDC. AHRQ and CDC staff and members of the USPSTF participated in developing the scope of the work and reviewed draft reports, but the authors are solely responsible for the content.