# Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) last made a recommendation on latent tuberculosis (TB) screening in 1996. With new tests and treatments for latent TB infection (LTBI), an updated assessment of the evidence to inform recommendations on screening is warranted.

The purpose of this report is to systematically review the current evidence on targeted screening for and treatment of LTBI in populations and settings relevant to primary care in the United States. In this report, we summarize the evidence on the benefits and harms of screening for LTBI in selected high-risk adult populations, the test characteristics of U.S. Food and Drug Administration (FDA)-approved screening tests, and the benefits and harms of Centers for Disease Control and Prevention (CDC)-recommended treatments for LTBI. This review also identifies key gaps in this scientific literature.

This review was scoped to provide the USPSTF with answers to key questions (KQs) needed to inform a recommendation about LTBI screening in asymptomatic, generally healthy adults in settings relevant to primary care. Thus, the review does not focus on the testing of close contacts of persons with active TB or medically vulnerable populations for whom LTBI testing is considered part of disease management. Further, this review does not focus on important issues related to TB epidemiology, such as risk of transmission, the public health infrastructure for TB, or adherence to all steps involved in testing and treatment.

## Condition Definition

TB is a disease caused by Mycobacterium tuberculosis that is spread through airborne transmission. TB usually affects the lungs but can also affect other parts of the body, such as the brain, kidneys, or spine. When a person with active pulmonary TB coughs or sneezes, droplet nuclei containing M. tuberculosis are expelled into the air. If another person inhales air containing these droplet nuclei, three conditions are possible: clearance of the organism; onset of active disease (primary TB disease); or latent infection without signs, symptoms, or radiographic or bacteriologic evidence of TB disease.1 Persons with LTBI are not infectious to others. LTBI can later reactivate when previously dormant M. tuberculosis, seeded at the time of exposure, proliferate and progress to cause active TB disease.

## Etiology and Natural History

After exposure to M. tuberculosis, approximately 30 percent of persons are thought to develop LTBI, as diagnosed based on a positive tuberculin skin test (TST).2,3 Five to 10 percent of healthy (immunocompetent) persons with a positive TST will progress from LTBI to active TB disease (referred to as reactivation) in their lifetime. This estimate is based on epidemiologic data and data from placebo arms of treatment trials conducted before treatment of LTBI was routinely recommended.4,5 However, this range underestimates the risk of progression to active TB for some patients and overestimates the risk for others, because risks vary greatly according to age, the size of the TST reaction, and the presence or absence of specific medical conditions.6

A recently published observational study of contacts of persons with active TB in Amsterdam who were diagnosed with LTBI between 2002 and 2011 reported a 5-year risk of incident TB of 2.4 percent (95% confidence interval [CI], 1.2 to 4.7) among those who did not take preventive therapy.7 A recent report using 2006–2008 U.S. data estimated the rate of TB reactivation among persons with LTBI as 0.084 cases per 100 person-years (95% CI, 0.083 to 0.085).8 Among persons who tested positive versus negative for HIV, rates were 1.82 (95% CI, 1.74 to 1.89) and 0.073 (95% CI, 0.070 to 0.075) cases per 100 person-years, respectively. Reactivation rates were higher among foreign-born persons (0.098 cases per 100 person-years [95% CI, 0.096 to 0.10]) than among those born in the United States (0.082 cases per 100 person-years [95% CI, 0.080 to 0.083]).

### Risk Factors

Persons may be considered “high risk” for LTBI for several reasons.1,9,10 Some may be high risk because of increased likelihood of exposure to active TB. Others may be high risk because of increased likelihood of latent infection if exposed because of medical conditions or other factors that influence the immune system. Some persons with increased chance of latent infection due to underlying immune factors may also have an increased risk of LTBI reactivation. The estimates for prevalence of LTBI among some higher-risk populations and estimates for risk of reactivation of LTBI are frequently based on older studies that may not correspond to current risks and practice patterns.

Risks for incident LTBI associated with increased exposure to active TB include being born outside the United States, having lower household income or less than a high school education, being male, being a member of a racial/ethnic minority population, being an active smoker, and living with someone with active TB.11 Substantially increased exposure to active TB has also been observed among homeless persons, injection drug users, persons with HIV, and residents or employees of a high-risk congregate setting (e.g., prison, long-term care facility, hospital, homeless shelter).9

Risks associated with a higher likelihood of latent infection if exposed, reactivation to active TB, or both vary.9 These risks include HIV infection, injection drug use, radiographic evidence of prior healed TB, low body weight (10% below ideal), and certain medical conditions (e.g., silicosis, poorly controlled diabetes mellitus, chronic renal failure, gastrectomy, solid organ transplant, smoking, head and neck cancer, and conditions that require prolonged use of corticosteroids or other immunosuppressive agents).1,6,9,10 However, there is uncertainty in the estimated risk of developing active TB in persons with these conditions. One review found that estimates of the relative risk (RR) of developing active TB in persons with medical conditions that impair the host's immune system are either lower than expected or have significant methodological flaws (e.g., failure to distinguish among the risk of exposure, risk of infection, and risk of reactivation; small sample sizes).6 This same review offers RR estimates for reactivation to active TB for a number of high-risk populations; the two populations most relevant to primary care settings are Hispanic patients with poorly controlled diabetes (RR, 1.7 [95% CI, 1.5 to 2.2]) and smokers (RR 1.5 [95% CI, 1.1 to 2.2]).12

## Prevalence and Burden

The prevalence and burden of active TB disease affects the prevalence and burden of LTBI. TB is a substantial health issue globally, with nearly 9 million cases of active TB and 1.5 million TB-related deaths worldwide in 2013.^13^ In the United States, active TB is a much more limited health problem, with cases declining in recent decades. In 2015, a total of 9,536 new active TB cases were reported in the United States, corresponding to an incidence rate of 3.0 cases per 100,000 population.14 There were 555 deaths from TB disease in the United States in 2013, the most recent year for which these data are available.15 The proportion of TB deaths occurring among HIV-infected persons compared with non–HIV-infected persons is difficult to estimate because deaths among coinfected persons are typically attributed in vital statistics to HIV infection, as opposed to TB disease. Further, HIV status is unknown in some active TB cases.16,17 In 2014, the prevalence of unknown HIV status among TB cases was 14 percent and the prevalence of HIV among cases of active TB with known HIV status was 6.3 percent.18

Among persons with known national origin, 6,335 active TB cases were among foreign-born persons (66.2% of all cases) in 2015, for a rate of 15.1 cases per 100,000 population compared with 1.2 cases per 100,000 population among U.S.-born persons.14 Active TB rates also vary by race/ethnicity; rates per 100,000 U.S.-born population in 2015 were 0.7, 2.0, 2.0, 4.0, 8.4, and 6.8 among non-Hispanic whites, Hispanics or Latinos, Asians, non-Hispanic blacks or African Americans, Native Hawaiians or other Pacific Islanders, and American Indians or Alaska Natives, respectively.14 Rates per 100,000 foreign-born U.S. population in 2015 were 3.7, 11.5, 29.9, and 27.7 among non-Hispanic whites, Hispanics or Latinos, Asians, and non-Hispanic blacks or African Americans, respectively. The incidence of active TB varies significantly by geographical location (state) within the United States: California, Texas, New York, and Florida combined accounted for more than half of all U.S. TB cases reported in 2015.^14^ Among persons with active TB age 15 years or older in 2014, 5.5 percent were homeless, 2.2 percent were long-term care facility residents, and 4.2 percent were in a correctional facility.18

Estimating the prevalence of LTBI overall and among higher-risk groups is challenging because no direct test for latent M. tuberculosis exists and latent infection is not reportable to the CDC's National Notifiable Disease Surveillance System.19 Unlike active TB disease, which is diagnosed on the basis of clinical signs and symptoms and confirmed by bacteriologic or molecular identification of M. tuberculosis from fluid or tissue specimens, existing tests for latent infection measure memory T cell response, an indirect measure of host sensitization to M. tuberculosis.10 In general, estimates of the prevalence of LTBI are based on studies using TST and/or interferon-gamma release assay (IGRA) to define infection.

The largest prevalence studies use data from the National Health and Nutrition Examination Survey (NHANES), a nationally representative sample of the civilian, noninstitutionalized U.S. population, to estimate the prevalence of LTBI based on an induration of 10 mm or larger on TST or a positive IGRA. Using 2011–2012 NHANES data, the population prevalence of LTBI among persons age 6 years or older is 4.7 percent (95% CI, 3.4 to 6.3) based on a positive TST alone, 5.0 percent (95% CI, 4.2 to 5.8) based on a positive IGRA alone, and 2.1 percent (95% CI, 1.5 to 2.8) based on a positive TST and IGRA. Among the foreign-born U.S. population age 6 years or older, the prevalence of LTBI is 20.5 percent (95% CI, 16.1 to 25.8) based on a positive TST alone, 15.9 percent (95% CI, 13.5 to 18.7) based on a positive IGRA alone, and 9.3 percent (95% CI, 7.4 to 11.7) based on a positive TST and IGRA.20 Other than foreign-born persons, NHANES does not include enough persons at higher risk for TB in the sample; thus, nationally representative population estimates among higher-risk groups other than foreign-born persons are not available.

Published estimates of LTBI prevalence among higher-risk groups may have limited generalizability based on the specific population(s) used to collect the estimates, the number of participants included, the tests and definitions for a positive test, and whether studies were conducted within a single or multicenter setting. For example, a retrospective study estimated the LTBI prevalence among the homeless New York City population over the years 1992 to 2005 to be 27.1 percent based on convincing self-reported history of positive TST, but prevalence based on actual testing with TST (threshold for positivity was not specified) was 12.5 percent.21 A review published in May 2015 offers LTBI prevalence and active TB disease incidence estimates by high-risk categories based on studies published in English, French, or Spanish between 2009 and 2014. These estimates vary by test used (TST or IGRA) and in some cases are based on a single study. These estimates are summarized in Appendix A Table 1.^10^

## Rationale for Screening

The prevention of active TB by treating LTBI is a major goal of the national strategy for eliminating TB in the United States.22,23 The CDC does not recommend universal or untargeted population screening for LTBI. That is, the CDC discourages the use of tests for LTBI among persons and populations at low risk for TB infection, and discourages a testing approach that is independent of a risk assessment.1 Rather, the CDC recommends screening for LTBI among population subgroups with higher prevalence of LTBI (i.e., prevalence substantially greater than that of the general U.S. population) or in persons who have increased risk of progression from LTBI to active TB disease.

### Screening Strategies

For the purposes of this review, we define screening as the use of a test in asymptomatic persons for the purpose of identifying candidates for medication to prevent progression to active TB. No direct test for the presence of latent M. tuberculosis is available as a reference standard for LTBI screening tests. The diagnosis of LTBI is based on medical and social history, physical examination, and TST or IGRA results (both discussed below). The presence of active TB disease should be excluded before treatment of LTBI is initiated; failure to do so may result in inadequate treatment and development of drug resistance.1 Chest x-ray is often recommended in patients who have a positive screening test for LTBI, along with a symptom questionnaire to help differentiate LTBI and active TB disease.

#### TST

TST is administered by injecting 0.10 mL of an intermediate-strength dose of purified protein derivative (PPD) intradermally using the Mantoux technique, with interpretation within 48 to 72 hours. In the United States, an intermediate-strength dose is 5 tuberculin units (TU) of PPD-S. In other countries, PPD RT-23 is used, and an approximately equivalent intermediate-strength dose is 2 to 2.5 TU.24,25 If a person is infected with TB, a delayed-type hypersensitivity reaction is typically detectable 2 to 8 weeks after initial infection. Health care providers should be trained in the administration and interpretation of TST.9

Based on the sensitivity and specificity of the TST and the prevalence of TB in different groups, three cut-points have been recommended for defining a positive reaction: 5 mm or larger, 10 mm or larger, and 15 mm or larger of induration.1,9 A TST reaction of 5 mm or larger of induration is considered positive in persons with the highest risk of developing active TB: patients with HIV infection; patients with organ transplants and other immunosuppressed patients (e.g., patients taking the equivalent of ≥15 mg/day of prednisone for 1 month or those taking tumor necrosis factor-alpha antagonists); patients with recent contact with a person who has infectious TB disease; or persons with fibrotic changes on a chest x-ray consistent with prior TB. A TST reaction of 10 mm or larger of induration is considered positive for LTBI in the following persons: recent arrivals to the United States (within the last 5 years) from countries with a high TB prevalence; injection drug users; residents or employees of high-risk congregate settings (e.g., correctional facilities, long-term care facilities, hospitals and other health care settings, residential facilities for persons with HIV infection, and homeless shelters); and persons with clinical conditions that increase the risk of progression to TB disease.1 A TST reaction of 15 mm or larger of induration is considered positive in persons with no known risk factors for TB.1,9

#### IGRAs

IGRAs are performed using fresh, whole-blood specimens. Blood is mixed with assay peptides that simulate antigens derived from M. tuberculosis. If infected with M. tuberculosis, white blood cells recognize the simulated antigens and release interferon-gamma. Currently, two FDA-approved IGRAs are commercially available: QuantiFERON-TB® Gold In-Tube (QFT-GIT) (Qiagen, Germantown, MD), approved by the FDA in 2007, and T-SPOT.TB® (Oxford Immunotec Global, Marlborough, MA), approved by the FDA in 2010.^1,26^ The antigens used by both commercially available tests (ESAT-6 and CFP-10) are absent in the bacille Calmette–Guérin (BCG) vaccine and most nontuberculosis mycobacteria. QFT-GIT was approved as a modification to the second-generation test approved in 2005 (QuantiFERON-TB Gold [QFT-G]) and includes an additional antigen (TB7.7).

The interpretation of IGRA tests is based on the measured amount of interferon-gamma released (QFT-G and QFT-GIT) or on the number of visible spots that form in response to cells that release interferon-gamma (T-SPOT.TB). The CDC recommends that laboratories provide both the qualitative and quantitative results. Qualitative results are reported as positive, negative, indeterminate, or borderline. Quantitative results are reported as numerical values that include a response to the TB antigen and two controls (nil and mitogen). Quantitative results may be useful for clinical decisionmaking in individual cases, in combination with risk factors. IGRAs have some advantages over TST. They require a single patient visit to conduct the test, results can be available within 24 hours, they do not cause a “booster phenomenon,” and they are unaffected by BCG vaccination and most environmental mycobacteria.1 However, blood samples must be processed relatively quickly (within 8 to 30 hours after collection), and limited data exist in certain groups (e.g., persons recently exposed to TB, immunocompromised persons, and persons who will be tested repeatedly).

Among persons at higher risk for TB, the CDC considers IGRAs the preferred method of testing for groups who have poor rates of return for TST reading and interpretation (e.g., homeless persons) and persons who have received BCG vaccination.1 The CDC indicates that either TST or IGRAs can be used for other high-risk persons. The CDC does not recommend routine testing with both TST and IGRAs but suggests situations where results from both tests could be useful. For example, IGRA testing might follow a positive TST among persons who have a low risk of both infection and progression from infection to TB disease, or follow a negative TST when the risk for infection, progression to disease, and/or a poor outcome is high, such as among HIV-infected persons.1

Because no direct test for LTBI infection exists, the test characteristics for both TST and IGRAs are difficult to establish for latent infection. Sensitivity is generally extrapolated from the sensitivity of these tests in populations with active TB. Similarly, specificity is generally extrapolated from evaluating the test within populations of healthy persons, free of TB risks or exposures, and without underlying medical conditions that increase risk for TB infection.

## Treatment Approaches

Persons who screen positive for LTBI and in whom active infection has been excluded are generally offered treatment with antituberculosis medications.9 For decades, isoniazid was the only medication used for treating LTBI. However, concerns about adverse events, primarily hepatotoxicity, and difficulty with patient adherence to long treatment regimens prompted the evaluation of alternative regimens.

The American Thoracic Society, the CDC, and the Infectious Diseases Society of America recommend several regimens for treating LTBI; these regimens vary by drug, dose frequency, and duration of treatment.27 The regimens include isoniazid and drugs in the rifamycin class (rifampin and rifapentine). In 2011, the CDC issued additional recommendations based on findings from three randomized, controlled trials (RCTs) that demonstrated that a weekly regimen with isoniazid and rifapentine for 12 weeks was as effective as traditional 6- or 9-month isoniazid regimens for healthy persons.28 The recommended regimens for treating LTBI in adults are summarized in Appendix A Table 2.

## Current Clinical Practice in the United States

Current guidelines from several organizations reflect a movement toward targeted testing and treatment. In developed countries with a low prevalence of TB such as the United States, most authorities recommend that LTBI screening be done only among high-risk groups and when treatment is feasible. In 2005, the CDC, in collaboration with the American Thoracic Society and the Infectious Diseases Society of America, issued its most recent joint recommendations for controlling TB.27 In 2011, the CDC convened an expert panel to review evidence from new trials that resulted in a recommendation for a new alternative regimen (weekly isoniazid/rifapentine for 12 weeks).27,28 In 2015, the World Health Organization released new guidelines on the management of LTBI that offer a public health approach for testing, treating, and managing LTBI primarily geared toward high- and upper middle-income countries.29 These guidelines recommend testing for and treatment of LTBI in persons at the highest risk of progression to active disease, including persons with HIV, close contacts of persons with active pulmonary TB, and patients with selected conditions or those undergoing treatment commonly associated with immunosuppression (e.g., transplant, antitumor necrosis factor treatments).

Estimates for the current prevalence of screening for LTBI in primary care settings are not available. Further, estimates of the proportion of high-risk groups and persons cared for in primary care settings are difficult to determine and likely vary by the type of primary care setting (e.g., a public health clinic or safety net provider in a region of the United States with a high TB burden vs. a private primary care practice in a community with a low TB burden).

## Previous USPSTF Recommendation

In 1996, the USPSTF recommended screening with TST in asymptomatic high-risk persons (A recommendation) and BCG vaccination only for selected high-risk persons (B recommendation). Prior to the present update, the USPSTF Web site referred to the CDC for this recommendation, stating, “The USPSTF recognizes the importance of targeted screening for tuberculosis. However, the USPSTF does not wish to duplicate the work of the Centers for Disease Control and Prevention (CDC) in this area and will not update its 1996 recommendations.”