# KQ 5 Supplemental Analyses

Appendix G Figure 1 Isoniazid Compared With Placebo, Relative Risk of Developing Hepatotoxicity: Sensitivity Analysis Including Data From Four Randomized, Controlled Trials

Notes: For Thompson 1982 (IUAT trial), we included data from the 12-, 24-, and 52-week groups. A definition for hepatotoxicity (presented as “hepatitis” in this study) was not reported for this study. For Bailey 1974 and Byrd 1977, hepatotoxicity was defined as SGOT >100 mU/mL. For Falk 1978, hepatotoxicity was defined only as “mild hepatitis.”

Abbreviations: CI=confidence interval; INH=isoniazid; RR=relative risk.

Appendix G Figure 1 is a forest plot of the relative risks of developing hepatotoxicity from a sensitivity analysis including data from four RCTs comparing isoniazid vs. placebo. The overall relative risk for developing hepatotoxicity associated with isoniazid treatment vs. placebo is 5.04, with a 95% confidence interval of 2.50 to 10.15.

Appendix G Figure 2 Isoniazid Compared With Placebo, Relative Risk of Treatment Discontinuation Due to Adverse Events: Sensitivity Analysis Including Data From Four Randomized, Controlled Trials

Notes: For Thompson 1982 (IUAT trial), rates of discontinuation due to adverse events were reported only as a combined value across the three treatment duration groups (12-, 24-, and 52-week). For Bush 1965, treatment discontinuation due to adverse events was categorized as gastrointestinal, rash, and other. For Byrd 1977, treatment discontinuation was due to “symptomatology,” which included hepatotoxicity and mild nausea/abdominal cramps. For Ferebee 1963, discontinuation due to adverse events corresponded to participants stopping medication due to being “sick” from pills.

Abbreviations: CI=confidence interval; INH=isoniazid; RR=relative risk.

Appendix G Figure 12 is a forest plot of the relative risks of treatment discontinuation from a sensitivity analysis including data from four RCTs comparing isoniazid vs. placebo. The overall relative risk for treatment discontinuation associated with isoniazid treatment vs. placebo is 1.58, with a 95% confidence interval of 1.00 to 2.49.