# KQ 2 Supplemental Analyses

Appendix F Figure 1 Sensitivity for Various Thresholds of TST for Tuberculosis Infection, Including Poor-Quality Studies

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 1 is a forest plot of poor-, fair-, or good-quality studies reporting sensitivity for the tuberculin skin test at 5-mm, 10-mm, and 15-mm thresholds for a positive test. The pooled sensitivity estimate for 9 studies at 5 mm is 0.78, with a 95% confidence interval of 0.68 to 0.88. The pooled sensitivity estimate for 15 studies at 10 mm is 0.78, with a 95% confidence interval of 0.72 to 0.85. The pooled sensitivity estimate for 6 studies at 15 mm is 0.50, with a 95% confidence interval of 0.30 to 0.69. The pooled sensitivity estimate for 2 studies at varying thresholds is 0.73, with a 95% confidence interval of 0.66 to 0.81.

Appendix F Figure 2 Sensitivity for Various Thresholds of IGRA Tests for Tuberculosis Infection, Including Poor-Quality Studies

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 2 is a forest plot of poor-, fair-, or good-quality studies reporting sensitivity for three different commercial interferon-gamma release assay tests: T-SPOT.TB, QFT-G, and QFT-GIT. The pooled sensitivity estimate for 19 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93. The pooled sensitivity estimate for 20 studies using QFT-G is 0.78, with a 95% confidence interval of 0.74 to 0.81. The pooled sensitivity estimate for 28 studies using QFT-GIT is 0.81, with a 95% confidence interval of 0.78 to 0.85.

Appendix F Figure 3 Specificity for Various Thresholds of TST and IGRA Tests for Tuberculosis Infection, Including Poor-Quality Studies

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 3 is a forest plot of poor-, fair-, or good-quality studies reporting specificity for the tuberculin skin test at 5-mm, 10-mm, and 15-mm thresholds for a positive test and for three different commercial interferon-gamma release assay tests: T-SPOT.TB, QFT-G, and QFT-GIT. The pooled specificity estimate for 4 studies using the tuberculin skin test at 5 mm is 0.90, with a 95% confidence interval of 0.86 to 0.94. The pooled specificity estimate for 11 studies using the tuberculin skin test at 10 mm is 0.96, with a 95% confidence interval of 0.95 to 0.98. The pooled specificity estimate for 13 studies using the tuberculin skin test at 15 mm is 0.98, with a 95% confidence interval of 0.98 to 0.99. The pooled specificity estimate for 6 studies using T-SPOT.TB is 0.95, with a 95% confidence interval of 0.92 to 0.98. The pooled specificity estimate for 5 studies using QFT-G is 0.95, with a 95% confidence interval of 0.90 to 1.01. The pooled specificity estimate for 7 studies using QFT-GIT is 0.97, with a 95% confidence interval of 0.94 to 0.99.

Appendix F Figure 4 Sensitivity for Various Thresholds of TST for Tuberculosis Infection Using Maximum Likelihood Random-Effects Model

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 4 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at 5- mm, 10-mm, and 15-mm thresholds for a positive test using a maximum likelihood random-effects model. The pooled sensitivity estimate for 8 studies at 5 mm is 0.84, with a 95% confidence interval of 0.68 to 0.92. The pooled sensitivity estimate for 11 studies at 10 mm is 0.81, with a 95% confidence interval of 0.71 to 0.87. The pooled sensitivity estimate for 6 studies at 15 mm is 0.50, with a 95% confidence interval of 0.33 to 0.68.

Appendix F Figure 5 Sensitivity for Various Thresholds of IGRA Tests for Tuberculosis Infection Using Maximum Likelihood Random-Effects Model

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 5 is a forest plot of fair- or good-quality studies reporting sensitivity for three different commercial interferon-gamma release assay tests: T-SPOT.TB, QFT-G, and QFT-GIT, using a maximum likelihood random- effects model. The pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.86 to 0.93. The pooled sensitivity estimate for 17 studies using QFT-G is 0.77, with a 95% confidence interval of 0.73 to 0.81. The pooled sensitivity estimate for 24 studies using QFT-GIT is 0.81, with a 95% confidence interval of 0.77 to 0.84.

Appendix F Figure 6 Specificity for Various Thresholds of TST and IGRA Tests for Tuberculosis Infection Using Maximum Likelihood Random-Effects Model

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 6 is a forest plot of fair- or good-quality studies reporting sensitivity forthe tuberculin skin test at 5-mm, 10-mm, and 15-mm thresholds for a positive test and for three different commercial interferon-gamma release assay tests: T-SPOT.TB, QFT-G, and QFT-GIT using a maximum likelihood random-effects model. The pooled specificity estimate for 4 studies using the tuberculin skin test at 5 mm is 0.89, with a 95% confidence interval of 0.61 to 0.98. The pooled specificity estimate for 9 studies using the tuberculin skin test at 10 mm is 0.97, with a 95% confidence interval of 0.93 to 0.99. The pooled specificity estimate for 12 studies using the tuberculin skin test at 15 mm is 0.98, with a 95% confidence interval of 0.93 to 0.99. The pooled specificity estimate for 5 studies using T-SPOT.TB is 0.93, with a 95% confidence interval of 0.85 to 0.97. The pooled specificity estimate for 4 studies using QFT-G is 0.98, with a 95% confidence interval of 0.90 to 1.00. The pooled specificity estimate for 4 studies using QFT-GIT is 0.97, with a 95% confidence interval of 0.84 to 0.99.

Appendix F Figure 7 Sensitivity for TST at 5-mm Threshold, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; HIV=human immunodeficiency virus; NR=not reported; TB=tuberculosis.

Appendix F Figure 7 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 5-mm threshold for a positive test stratified by timing of testing with respect to antituberculosis treatment. The pooled sensitivity estimate for 4 studies with testing prior to or within 7 days of treatment is 0.75, with a 95% confidence interval of 0.68 to 0.81. The sensitivity estimate for 1 study with testing prior to or within 30 days of treatment is 0.87, with a 95% confidence interval of 0.71 to 0.95 and a sample size of 31. The pooled sensitivity estimate for 3 studies with timing of testing not reported is 0.85, with a 95% confidence interval of 0.71 to 0.99. The overall pooled sensitivity estimate for 8 studies is 0.79, with a 95% confidence interval of 0.69 to 0.90.

Appendix F Figure 8 Sensitivity for TST at 5-mm Threshold, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 8 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 5-mm threshold for a positive test stratified by HIV prevalence of the study population. The pooled sensitivity estimate for 6 studies -with HIV prevalence at 0% is 0.79, with a 95% confidence interval of 0.67 to 0.91. The sensitivity estimate for 1 study with HIV prevalence <25% is 0.74, with a 95% confidence interval of 0.62 to 0.83 and a sample size of 69. The sensitivity estimate for 1 study with HIV prevalence not reported is 0.87, with a 95% confidence interval of 0.71 to 0.95 and a sample size of 31. The overall pooled sensitivity estimate for 8 studies is 0.79, with a 95% confidence interval of 0.69 to 0.90.

Appendix F Figure 9 Sensitivity for TST at 5-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 9 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 5-mm threshold for a positive test stratified by country TB burden of the study setting. The sensitivity estimate for 1 study conducted in a high TB-burden country is 0.89, with a 95% confidence interval of 0.83 to 0.94 and a sample size of 132. The pooled sensitivity estimate for 3 studies conducted in intermediate TB-burden countries is 0.76, with a 95% confidence interval of 0.62 to 0.91. The pooled sensitivity estimate for 4 studies conducted in low TB-burden countries is 0.79, with a 95% confidence interval of 0.60 to 0.98. The overall pooled sensitivity estimate for 8 studies is 0.79, with a 95% confidence interval of 0.69 to 0.90.

Appendix F Figure 10 Sensitivity for TST at 5-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 10 is titled “Sensitivity of tuberculin skin test at 5 mm stratified by country BCG vaccination prevalence of the study population.” The figure displays a forest plot of fair or good quality studies reporting sensitivity for tuberculin skin test at a 5 mm threshold for a positive test stratified by country BCG vaccination prevalence of the study population. The pooled sensitivity estimate for 7 studies at 5 mm in a study population with BCG vaccination prevalence > 25% is 0.81 with a 95% confidence interval of 0.71 to 0.91. The sensitivity estimate for 1 study at 5 mm in study population with BCG vaccination prevalence not reported is 0.65 with a 95% confidence interval of 0.52 to 0.76 with a sample size of 57. The overall pooled sensitivity estimate for 8 studies at 5 mm is 0.79 with a 95% confidence interval of 0.69 to 0.90.

Appendix F Figure 11 Sensitivity for TST at 10-mm Threshold, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 11 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 10-mm threshold for a positive test stratified by timing of testing with respect to antituberculosis treatment. The pooled sensitivity estimate for 4 studies with testing prior to or within 7 days of treatment is 0.74, with a 95% confidence interval of 0.62 to 0.87. The sensitivity estimate for 1 study with testing prior to or within 30 days of treatment is 0.84, with a 95% confidence interval of 0.67 to 0.93 and a sample size of 31. The pooled sensitivity estimate for 6 studies with timing of testing not reported is 0.81, with a 95% confidence interval of 0.71 to 0.91. The overall pooled sensitivity estimate for 11 studies is 0.79, with a 95% confidence interval of 0.71 to 0.87.

Appendix F Figure 12 Sensitivity for TST at 10-mm Threshold, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 12 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 10-mm threshold for a positive test stratified by HIV prevalence of the study population. The pooled sensitivity estimate for 8 studies with HIV prevalence at 0% is 0.77, with a 95% confidence interval of 0.67 to 0.87. The sensitivity estimate for 1 study with HIV prevalence <25% is 0.71, with a 95% confidence interval of 0.59 to 0.80 and a sample size of 69. The pooled sensitivity estimate for 2 studies with HIV prevalence not reported is 0.91, with a 95% confidence interval of 0.84 to 0.97. The overall pooled sensitivity estimate for 11 studies is 0.79, with a 95% confidence interval of 0.71 to 0.87.

Appendix F Figure 13 Sensitivity for TST at 10-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; mm=millimeter; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 13 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 10-mm threshold for a positive test stratified by country TB burden of the study setting. The pooled sensitivity estimate for 2 studies set in high TB-burden countries is 0.84, with a 95% confidence interval of 0.78 to 0.90. The pooled sensitivity estimate for 6 studies set in intermediate TB-burden countries is 0.72, with a 95% confidence interval of 0.65 to 0.79. The pooled sensitivity estimate for 3 studies set in low TB-burden countries is 0.88, with a 95% confidence interval of 0.76 to 0.99. The overall pooled sensitivity estimate for 11 studies is 0.79, with a 95% confidence interval of 0.71 to 0.87.

Appendix F Figure 14 Sensitivity for TST at 10-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 14 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 10-mm threshold for a positive test stratified by the BCG vaccination prevalence of the study population. The pooled sensitivity estimate for 9 studies in a study population with BCG vaccination prevalence >25% is 0.77, with a 95% confidence interval of 0.68 to 0.87. The pooled sensitivity estimate for 2 studies in a study population with BCG vaccination prevalence not reported is 0.83, with a 95% confidence interval of 0.78 to 0.88. The overall pooled sensitivity estimate for 11 studies is 0.79, with a 95% confidence interval of 0.71 to 0.87.

Appendix F Figure 15 Sensitivity for TST at 15-mm Threshold, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 15 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 15-mm threshold for a positive test stratified by timing of testing with respect to antituberculosis treatment. The pooled sensitivity estimate for 2 studies with testing prior to or within 7 days of treatment is 0.50, with a 95% confidence interval of 0.43 to 0.58. The sensitivity estimate for 1 study with testing prior to or within 30 days of treatment is 0.26, with a 95% confidence interval of 0.14 to 0.43 and a sample size of 31. The pooled sensitivity estimate for 4 studies with timing of testing not reported is 0.57, with a 95% confidence interval of 0.35 to 0.80.

Appendix F Figure 16 Sensitivity for TST at 15-mm Threshold, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 16 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 15-mm threshold for a positive test stratified by HIV prevalence of the study population. The pooled sensitivity estimate for 5 studies with HIV prevalence at 0% is 0.54, with a 95% confidence interval of 0.34 to 0.74. The sensitivity estimate for 1 study with HIV prevalence <25% is 0.62, with a 95% confidence interval of 0.51 to 0.73 and a sample size of 69. The sensitivity estimate for 1 study with HIV prevalence not reported is 0.26, with a 95% confidence interval of 0.14 to 0.43 and a sample size of 31.

Appendix F Figure 17 Sensitivity for TST at 15-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 17 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 15-mm threshold for a positive test stratified by country TB burden of the study setting. The sensitivity estimate for 1 study set in a high TB-burden country is 0.52, with a 95% confidence interval of 0.44 to 0.61 and a sample size of 132. The pooled sensitivity estimate for 4 studies set in intermediate TB-burden countries is 0.41, with a 95% confidence interval of 0.21 to 0.61. The pooled sensitivity estimate for 2 studies set in low TB-burden countries is 0.78, with a 95% confidence interval of 0.73 to 0.82.

Appendix F Figure 18 Sensitivity for TST at 15-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 18 is a forest plot of fair- or good-quality studies reporting sensitivity for the tuberculin skin test at a 15-mm threshold for a positive test stratified by the BCG vaccination prevalence of the study population. The sensitivity estimates for 7 studies in a study population with BCG vaccination prevalence >25% are as follows: Berkel (2005) is 0.80, with a 95% confidence interval of 0.75 to 0.84 and a sample size of 312; Kang (2005) is 0.70, with a 95% confidence interval of 0.57 to 0.81 and a sample size of 54; Mazurek (2007) is 0.62, with a 95% confidence interval of 0.51 to 0.73 and a sample size of 69; Soysal (2008) is 0.41, with a 95% confidence interval of 0.32 to 0.51 and a sample size of 99; Dilektasli (2010) is 0.26, with a 95% confidence interval of 0.14 to 0.43 and a sample size of 31; Painter (2013) is 0.52, with a 95% confidence interval of 0.44 to 0.61 and a sample size of 132; and Wlodarcyzk (2014) is 0.26, with a 95% confidence interval of 0.15 to 0.40 and a sample size of 43.

Appendix F Figure 19 Sensitivity of T-SPOT.TB Test, Stratified by Threshold Used for Positive Test

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 19 is a forest plot of fair- or good-quality studies reporting sensitivity for the T-SPOT.TB test stratified by threshold used for positive test. The pooled sensitivity estimate for 12 studies using the European threshold is 0.90, with a 95% confidence interval of 0.87 to 0.94. The pooled sensitivity estimate for 4 studies using the FDA threshold is 0.89, with a 95% confidence interval of 0.85 to 0.94. The overall pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93.

Appendix F Figure 20 Sensitivity of T-SPOT.TB Test, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; FDA=U.S. Food and Drug Administration; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 20 is a forest plot of fair- or good-quality studies reporting sensitivity for the T-SPOT.TB test stratified by timing of testing with respect to antituberculosis treatment. The pooled sensitivity estimate for 5 studies with testing prior to or within 7 days of treatment is 0.91, with a 95% confidence interval of 0.86 to 0.96. The pooled sensitivity estimate for 3 studies with testing prior to or within 14 days of treatment is 0.95, with a 95% confidence interval of 0.91 to 0.99. The sensitivity estimate for 1 study with testing prior to or within 30 days of treatment is 0.74, with a 95% confidence interval of 0.57 to 0.86 and a sample size of 31. The pooled sensitivity estimate for 7 studies with timing of testing not reported is 0.88, with a 95% confidence interval of 0.84 to 0.92. The overall pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93.

Appendix F Figure 21 Sensitivity of T-SPOT.TB Test, Stratified by HIV Prevalence of the Study Population

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; FDA=U.S. Food and Drug Administration; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 21 is a forest plot of fair- or good-quality studies reporting sensitivity for the T-SPOT.TB test stratified by HIV prevalence of the study population. The pooled sensitivity estimate for 7 studies with HIV prevalence at 0% is 0.92, with a 95% confidence interval of 0.88 to 0.96. The pooled sensitivity estimate for 6 studies with HIV prevalence up to 25% is 0.88, with a 95% confidence interval of 0.85 to 0.92. The pooled sensitivity estimate for 3 studies with HIV prevalence not reported is 0.93, with a 95% confidence interval of 0.88 to 0.99. The overall pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93.

Appendix F Figure 22 Sensitivity of T-SPOT.TB Test, Stratified by Country TB Burden of the Study Setting

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; FDA=U.S. Food and Drug Administration; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 22 is a forest plot of fair- or good-quality studies reporting sensitivity for the T-SPOT.TB test stratified by country TB burden of the study setting. The pooled sensitivity estimate for 10 studies set in intermediate TB-burden countries is 0.89, with a 95% confidence interval of 0.85 to 0.93. The sensitivity estimate for 1 study set in a high TB-burden country is 0.86, with a 95% confidence interval of 0.72 to 0.93 and a sample size of 42. The pooled sensitivity estimate for 3 studies set in low TB-burden countries is 0.98, with a 95% confidence interval of 0.95 to 1.01. The pooled sensitivity estimate for 3 studies set in mixed (low/intermediate) TB-burden countries is 0.92, with a 95% confidence interval of 0.86 to 0.97. The overall pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93.

Appendix F Figure 23 Sensitivity of T-SPOT.TB Test, Stratified by BCG Vaccination Prevalence of the Study Population

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; FDA=U.S. Food and Drug Administration; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 23 is a forest plot of fair- or good-quality studies reporting sensitivity for the T-SPOT.TB test stratified by the BCG vaccination prevalence of the study population. The pooled sensitivity estimate for 6 studies in a study population with BCG vaccination prevalence >25% is 0.89, with a 95% confidence interval of 0.83 to 0.95. The pooled sensitivity estimate for 10 studies in a study population with BCG vaccination prevalence not reported is 0.91, with a 95% confidence interval of 0.87 to 0.95. The overall pooled sensitivity estimate for 16 studies using T-SPOT.TB is 0.90, with a 95% confidence interval of 0.87 to 0.93.

Appendix F Figure 24 Sensitivity of QFT-Gold (2nd-Generation) Test, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 24 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-Gold test stratified by timing of testing with respect to antituberculosis treatment. The pooled sensitivity estimate for 10 studies with testing prior to or within 7 days of treatment is 0.76, with a 95% confidence interval of 0.71 to 0.80. The sensitivity estimate for 1 study with testing prior to or within 14 days of treatment is 0.62, with a 95% confidence interval of 0.46 to 0.76 and a sample size of 37. The pooled sensitivity estimate for 6 studies with timing of testing not reported is 0.83, with a 95% confidence interval of 0.79 to 0.87. The overall pooled sensitivity estimate for 17 studies using the QFT-Gold test is 0.77, with a 95% confidence interval of 0.74 to 0.81.

Appendix F Figure 25 Sensitivity of QFT-Gold (2nd-Generation) Test, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported.

Appendix F Figure 25 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-Gold test stratified by HIV prevalence of the study population. The pooled sensitivity estimate for 10 studies with HIV prevalence at 0% is 0.81, with a 95% confidence interval of 0.78 to 0.84. The pooled sensitivity estimate for 6 studies with HIV prevalence up to 25% is 0.71, with a 95% confidence interval of 0.65 to 0.77. The sensitivity estimate for 1 study with HIV prevalence not reported is 0.87, with a 95% confidence interval of 0.75 to 0.94 and a sample size of 47. The overall pooled sensitivity estimate for 17 studies using the QFT-Gold test is 0.77, with a 95% confidence interval of 0.74 to 0.81.

Appendix F Figure 26 Sensitivity of QFT-Gold (2nd-Generation) Test, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 26 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-Gold test stratified by country TB burden of the study setting. The pooled sensitivity estimate for 12 studies set in intermediate TB-burden countries is 0.80, with a 95% confidence interval of 0.77 to 0.84. The pooled sensitivity estimate for 4 studies set in low TB-burden countries is 0.71, with a 95% confidence interval of 0.63 to 0.78. The sensitivity estimate for 1 study set in a mixed (low/intermediate) TB-burden country is 0.70, with a 95% confidence interval of 0.63 to 0.77 and a sample size of 169. The overall pooled sensitivity estimate for 17 studies using the QFT-Gold test is 0.7,7 with a 95% confidence interval of 0.74 to 0.81.

Appendix F Figure 27 Sensitivity of QFT-Gold (2nd-Generation) Test, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 27 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-Gold test stratified by the BCG vaccination prevalence of the study population. The sensitivity estimate for 1 study in a study population with BCG vaccination prevalence <25% is 0.72, with a 95% confidence interval of 0.60 to 0.82 and a study sample size of 65. The pooled sensitivity estimate for 13 studies in a study population with BCG vaccination prevalence >25% is 0.78, with a 95% confidence interval of 0.74 to 0.83. The pooled sensitivity estimate for 3 studies in a study population with BCG vaccination prevalence not reported is 0.74, with a 95% confidence interval of 0.62 to 0.86. The overall pooled sensitivity estimate for 17 studies using the QFT-Gold test is 0.77, with a 95% confidence interval of 0.74 to 0.81.

Appendix F Figure 28 Sensitivity of QFT-Gold In-Tube (3rd-Generation) Test, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 28 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-GIT test stratified by timing of testing with respect to antituberculosis treatment. The pooled sensitivity estimate for 10 studies with testing prior to or within 7 days of treatment is 0.79, with a 95% confidence interval of 0.73 to 0.85. The pooled sensitivity estimate for 2 studies with testing prior to or within 14 days of treatment is 0.79, with a 95% confidence interval of 0.75 to 0.83. The pooled sensitivity estimate for 12 studies with timing of testing not reported is 0.82, with a 95% confidence interval of 0.77 to 0.87. The pooled sensitivity estimate for 24 studies using QFT-GIT is 0.80, with a 95% confidence interval of 0.77 to 0.84

Appendix F Figure 29 Sensitivity of QFT-Gold In-Tube (3rd-Generation) Test, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 29 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-GIT test stratified by HIV prevalence of the study population. The pooled sensitivity estimate for 15 studies with HIV prevalence at 0% is 0.81, with a 95% confidence interval of 0.77 to 0.85. The pooled sensitivity estimate for 5 studies with HIV prevalence up to 25% is 0.74, with a 95% confidence interval of 0.64 to 0.83. The pooled sensitivity estimate for 4 studies with HIV prevalence not reported is 0.88, with a 95% confidence interval of 0.83 to 0.93. The pooled sensitivity estimate for 24 studies using QFT-GIT is 0.80, with a 95% confidence interval of 0.77 to 0.84

Appendix F Figure 30 Sensitivity of QFT-Gold In-Tube (3rd-Generation) Test, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 30 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-GIT test stratified by country TB burden of the study setting. The pooled sensitivity estimate for 7 studies set in high TB-burden countries is 0.77, with a 95% confidence interval of 0.70 to 0.84. The pooled sensitivity estimate for 14 studies set in intermediate TB-burden countries is 0.80, with a 95% confidence interval of 0.76 to 0.85. The sensitivity estimate for 1 study set in a low TB-burden country is 0.88, with a 95% confidence interval of 0.78 to 0.94 and a sample size of 60. The pooled sensitivity estimate for 2 studies set in mixed (low/intermediate) TB-burden countries is 0.83, with a 95% confidence interval of 0.78 to 0.88. The pooled sensitivity estimate for 24 studies using QFT-GIT is 0.80, with a 95% confidence interval of 0.77 to 0.84

Appendix F Figure 31 Sensitivity of QFT-Gold In-Tube (3rd-Generation) Test, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; d=day; ES=effect size; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 31 is a forest plot of fair- or good-quality studies reporting sensitivity for the QFT-GIT test stratified by the BCG vaccination prevalence of the study population. The pooled sensitivity estimate for 2 studies in a study population with BCG vaccination prevalence <25% is 0.64, with a 95% confidence interval of 0.55 to 0.73. The pooled sensitivity estimate for 11 studies in a study population with BCG vaccination prevalence >25% is 0.85, with a 95% confidence interval of 0.82 to 0.88. The pooled sensitivity estimate for 11 studies in a study population with BCG vaccination prevalence not reported is 0.80, with a 95% confidence interval of 0.75 to 0.85. The pooled sensitivity estimate for 24 studies using QFT-GIT is 0.80, with a 95% confidence interval of 0.77 to 0.84

Appendix F Figure 32 Specificity of TST at 5-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; N=number; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 32 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at a 5-mm threshold for a positive test stratified by country TB burden of the study setting. The specificity estimate for 1 study set in an intermediate TB-burden country is 0.30, with a 95% confidence interval of 0.19 to 0.44 and a sample size of 47. The pooled specificity estimate for 3 studies set in low TB-burden countries is 0.95, with a 95% confidence interval of 0.94 to 0.97.

Appendix F Figure 33 Specificity of TST at 5-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; N=number; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 33 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at a 5-mm threshold for a positive test stratified by the BCG vaccination prevalence of the study population. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence <25% is as follows: Berkel (2005) is 0.95, with a 95% confidence interval of 0.94 to 0.96; and Mazurek (2007) is 0.97, with a 95% confidence interval of 0.95 to 0.98. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence >25% is as follows: Soysal (2008) is 0.30, with a 95% confidence interval of 0.19 to 0.44; and Katsenos (2010) is 0.94, with a 95% confidence interval of 0.92 to 0.95.

Appendix F Figure 34 Specificity of TST at 10-mm Threshold, Stratified by Country TB Burden of the Study Setting

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; N=number; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 34 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at a 10-mm threshold for a positive test stratified by country TB burden of the study setting. The specificity estimate for 1 study set in an intermediate TB-burden country is 0.45, with a 95% confidence interval of 0.31 to 0.59. The pooled specificity estimate for 8 studies set in low TB-burden countries is 0.98, with a 95% confidence interval of 0.97 to 0.99.

Appendix F Figure 35 Specificity of TST at 10-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Population

^a^ Excluded from pooled estimate due to point estimate of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; N=number; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 35 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at a 10-mm threshold for a positive test stratified by the BCG vaccination prevalence of the study population. The specificity estimates for 7 studies in a study population with BCG vaccination prevalence <25% are as follows: Villarino (1999) is 0.99, with a 95% confidence interval of 0.98 to 0.99; Villarino (2000) is 0.98, with a 95% confidence interval of 0.98 to 0.99; Fietta (2003) is 0.95, with a 95% confidence interval of 0.84 to 0.99; Berkel (2005) is 0.97, with a 95% confidence interval of 0.96 to 0.98; Mazurek (2007) is 0.98, with a 95% confidence interval of 0.97 to 0.99; Mancuso (2012) is 0.99, with a 95% confidence interval of 0.98 to 0.99; and Bienek (2009) is 1.00, with a 95% confidence interval of 0.99 to 1.00. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence >25% are as follows: Soysal (2008) is 0.45, with a 95% confidence interval of 0.31 to 0.59; and Katsenos (2010) is 0.95, with a 95% confidence interval of 0.93 to 0.95.

Appendix F Figure 36 Specificity of TST at 15-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; N=number; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 36 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at a 15-mm threshold for a positive test stratified by country TB burden of the study setting. The pooled specificity estimate for 2 studies set in intermediate TB-burden countries is 0.58, with a 95% confidence interval of 0.47 to 0.69. The pooled specificity estimate for 10 studies set in low TB-burden countries is 0.99, with a 95% confidence interval of 0.98 to 0.99.

Appendix F Figure 37 Specificity of TST at 15-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; N=number; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 37 is a forest plot of fair- or good-quality studies reporting specificity for the tuberculin skin test at a 15-mm threshold for a positive test stratified by the BCG vaccination prevalence of the study population. The specificity estimates for 7 studies in a study population with BCG vaccination prevalence <25% are as follows: Villarino (1999) is 1.00, with a 95% confidence interval of 0.99 to 1.00 and a sample size of 1555; Villarino (2000) is 1.00, with a 95% confidence interval of 0.99 to 1.00 and a sample size of 1189; Taggart (2004) is 0.92, with a 95% confidence interval of 0.83 to 0.97 and a sample size of 66; Berkel (2005) is 0.99, with a 95% confidence interval of 0.98 to 0.99 and a sample size of 2848; Taggart (2006) is 0.96, with a 95% confidence interval of 0.90 to 0.99 and a sample size of 81; Mazurek (2007) is 0.99, with a 95% confidence interval of 0.98 to 1.00 and a sample size of 551; and Mancuso (2012) is 0.99, with a 95% confidence interval of 0.99 to 1.00 and a sample size of 1373. The specificity estimates for 3 studies in a study population with BCG vaccination prevalence >25% are as follows: Soysal (2008) is 0.60, with a 95% confidence interval of 0.45 to 0.72 and a sample size of 47; Dilektasli (2010) is 0.57, with a 95% confidence interval of 0.39 to 0.73 and a sample size of 30; and Katsneos (2010) is 0.97, with a 95% confidence interval of 0.96 to 0.97 and a sample size of 1750. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence not reported are as follows: Mazurek (2001) is 0.98, with a 95% confidence interval of 0.93 to 0.99 and a sample size of 98; and Bellete (2002) is 0.96, with a 95% confidence interval of 0.87 to 0.99 and a sample size of 52.

Appendix F Figure 38 Specificity of IGRA (T-SPOT.TB) Test, Stratified by Threshold Used to Consider Test Positive

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; FDA=U.S. Food and Drug Administration; IGRA=interferon-gamma release assay; N=number; TB=tuberculosis.

Appendix F Figure 38 is a forest plot of fair- or good-quality studies reporting specificity for the T-SPOT.TB test stratified by threshold used for positive test. The pooled specificity estimate for 2 studies using the European threshold is 0.98, with a 95% confidence interval of 0.95 to 1.00. The pooled specificity estimate for 2 studies using the FDA threshold is 0.97, with a 95% confidence interval of 0.96 to 0.98. The specificity estimate for 1 study using a threshold not reported is 0.73, with a 95% confidence interval of 0.56 to 0.86 and a study sample size of 30.

Appendix F Figure 39 Specificity of IGRA (T-SPOT.TB) Test, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; IGRA=interferon-gamma release assay; N=number; TB=tuberculosis.

Appendix F Figure 39 is a forest plot of fair- or good-quality studies reporting specificity for the T-SPOT.TB test stratified by country TB burden of the study setting. The specificity estimates for 2 studies set in intermediate TB-burden countries are as follows: Soysal (2008) is 0.85, with a 95% confidence interval of 0.72 to 0.92 and a sample size of 46; and Dilektasli (2010) is 0.73, with a 95% confidence interval of 0.56 to 0.86 and a sample size of 30. The specificity estimates for 2 studies set in low TB-burden countries is as follows: Bienek (2009) is 0.95, with a 95% confidence interval of 0.91 to 0.97 and a sample size of 291; and Mancuso (2010) is 0.97, with a 95% confidence interval of 0.96 to 0.98 and a sample size of 1373. The pooled specificity estimate for 1 study set in a mixed (low/intermediate) TB-burden country is 0.99, with a 95% confidence interval of 0.92 to 1.00.

Appendix F Figure 40 Specificity of IGRA (T-SPOT.TB) Test, Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; FDA=U.S. Food and Drug Administration; IGRA=interferon-gamma release assay; N=number; TB=tuberculosis.

Appendix F Figure 40 is a forest plot of fair- or good-quality studies reporting specificity for the T-SPOT.TB test stratified by the BCG vaccination prevalence of the study population. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence <25% are as follows: Bienek (2009) is 0.95, with a 95% confidence interval of 0.91 to 0.97 and a study sample size of 291; and Mancuso (2012) is 0.97, with a 95% confidence interval of 0.96 to 0.98 and a study sample size of 1373. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence >25% are as follows: Soysal (2008) is 0.85, with a 95% confidence interval of 0.72 to 0.92 and a study sample size of 46; and Dilektasli (2010) is 0.73, with a 95% confidence interval of 0.56 to 0.86 and a study sample size of 30. The specificity estimate for 1 study in a study population with BCG vaccination prevalence not reported is 0.99, with a 95% confidence interval of 0.92 to 1.00 and a study sample size of 70.

Appendix F Figure 41 Specificity of QFT-Gold (2nd-Generation), Stratified by Country TB Burden of the Study Setting

^a^ Subgroup pooled estimate using maximum likelihood estimator because of two point estimates of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 41 is a forest plot of fair- or good-quality studies reporting specificity for the QFT-Gold test stratified by country TB burden of the study setting. The specificity estimate for 1 study set in intermediate TB-burden countries is 0.89, with a 95% confidence interval of 0.77 to 0.96 and a study sample size of 47. The pooled specificity estimate for 3 studies set in low TB-burden countries is 0.98, with a 95% confidence interval of 0.97 to 0.99.

Appendix F Figure 42 Specificity of QFT-Gold (2nd-Generation), Stratified by BCG Vaccination Prevalence of the Study Population

^a^ Pooled estimate using maximum likelihood estimator because of two point estimates of 1.0.

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; IGRA=interferon-gamma release assay; N=number; TB=tuberculosis.

Appendix F Figure 42 is a forest plot of fair- or good-quality studies reporting specificity for the QFT-Gold test stratified by the BCG vaccination prevalence of the study population. The specificity estimate for 2 studies in a study population with BCG vaccination prevalence <25% are as follows: Taggart (2006) is 1.00, with a 95% confidence interval of 0.96 to 1.00 and a study sample size of 81; and Mazurek (2007) is 0.98, with a 95% confidence interval of 0.96 to 0.99 and a study sample size of 555. The specificity estimate of 1 study in a study population with BCG vaccination prevalence >25% is 0.89, with a 95% confidence interval of 0.77 to 0.96 and a study sample size of 47. The specificity estimate for 1 study in a study population with BCG vaccination prevalence not reported is 1.00, with a 95% confidence interval of 0.79 to 1.00.

Appendix F Figure 43 Specificity of QFT-Gold In-Tube (3rd-Generation), Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; IGRA=interferon-gamma release assay; N=number; NR=not reported; TB=tuberculosis.

Appendix F Figure 43 is a forest plot of fair- or good-quality studies reporting specificity for the QFT-GIT test stratified by country TB burden of the study setting. The specificity estimate for 1 study set in an intermediate TB-burden country is 0.60, with a 95% confidence interval of 0.49 to 0.71 and a sample size of 73. The pooled specificity estimate for 2 studies set in low TB-burden countries is 0.99, with a 95% confidence interval of 0.98 to 0.99. The specificity estimate for 1 study set in a mixed (low/intermediate) TB-burden country is 0.99, with a 95% confidence interval of 0.95 to 1.00 and a study sample size of 101.

Appendix F Figure 44 Specificity of QFT-Gold In-Tube (3rd-Generation), Stratified by BCG Vaccination Prevalence of the Study Population

Abbreviations: BCG=bacille Calmette-Guérin; CI=confidence interval; ES=effect size; IGRA=interferon-gamma release assay; N=number; TB=tuberculosis.

Appendix F Figure 44 is a forest plot of fair- or good-quality studies reporting specificity for the QFT-GIT test stratified by the BCG vaccination prevalence of the study population. The specificity estimate for 1 study in a study population with BCG vaccination prevalence <25% is 0.99, with a 95% confidence interval of 0.98 to 0.99 and a study sample size of 1354. The specificity estimate for 1 study in a study population with BCG vaccination prevalence >25% is 0.60, with a 95% confidence interval of 0.49 to 0.71 and a study sample size of 73. The specificity estimates for 2 studies in a study population with BCG vaccination prevalence not reported are as follows: Ruhwald (2001) is 0.99, with a 95% confidence interval of 0.95 to 1.00 and a study sample size of 101; and Lempp (2015) is 0.98, with a 95% confidence interval of 0.97 to 0.99 and a study sample size of 525.