# Quality Ratings

Appendix E Table 1 Quality Ratings for Studies of Accuracy and Reliability of Screening Tests for Tuberculosis (KQ 2)

Appendix E Table 2 Quality Ratings for Randomized, Controlled Trials (KQs 3, 5): Main Analysis, Part 1

Appendix E Table 3 Quality Ratings for Randomized, Controlled Trials (KQs 3, 5): Main Analysis, Part 2

Appendix E Table 4 Additional Quality Ratings for Randomized, Controlled Trials for Harms (KQ 5): Main Analysis

Appendix E Table 5 Quality Ratings for Randomized, Controlled Trials Used Only in Sensitivity Analysis (KQs 3, 5), Part 1

Appendix E Table 6 Quality Ratings for Randomized, Controlled Trials Used Only in Sensitivity Analysis (KQs 3, 5), Part 2

Appendix E Table 7 Additional Quality Ratings for Randomized, Controlled Trials Used Only in Sensitivity Analysis for Harms

Appendix E Table 8 Quality Ratings for Observational Studies Used Only in Sensitivity Analysis for Harms (KQ 5), Part 1

Appendix E Table 9 Quality Ratings for Observational Studies Used Only in Sensitivity Analysis for Harms (KQ 5), Part 2