# Evidence Tables

Appendix D Table 1 Studies of Sensitivity of TST Screening Tests for Tuberculosis (KQ 2)

Appendix D Table 2 Studies of Sensitivity of IGRA Screening Tests for Tuberculosis (KQ 2)

Appendix D Table 3 Studies of Specificity of TST Screening Tests for Tuberculosis (KQ 2)

Appendix D Table 4 Studies of Specificity of IGRA Screening Tests for Tuberculosis (KQ 2)

Appendix D Table 5 Studies of Sensitivity of TST Screening Tests for Tuberculosis (KQ 2), Sensitivity Analysis

Appendix D Table 6 Studies of Sensitivity of IGRA Screening Tests for Tuberculosis (KQ 2), Sensitivity Analysis

Appendix D Table 7 Studies of Specificity of TST Screening Tests for Tuberculosis (KQ 2), Sensitivity Analysis

Appendix D Table 8 Studies of Specificity of IGRA Screening Tests for Tuberculosis (KQ 2), Sensitivity Analysis

Appendix D Table 9 Studies of Reliability of Screening Tests for Tuberculosis (KQ 2)

Appendix D Table 10 Characteristics of Included Randomized, Controlled Trials (KQs 3, 5), Main Analysis

Appendix D Table 11 Characteristics of Included Randomized, Controlled Trials for Benefits (KQ 3), Main Analysis

Appendix D Table 12 Characteristics of Included Randomized, Controlled Trials for Harms (KQ 5), Main Analysis

Appendix D Table 13 Characteristics of Randomized, Controlled Trials Used Only in Sensitivity Analyses (KQs 3, 5)

Appendix D Table 14 Characteristics of Randomized, Controlled Trials Used Only in Sensitivity Analyses for Benefits (KQ 3)

Appendix D Table 15 Characteristics of Randomized, Controlled Trials Used Only in Sensitivity Analyses for Harms (KQ 5)