# Excluded Studies

X1. | Not original research
X2. | Ineligible Population
X3. | Ineligible or No Screening/Intervention(s)
X4. | Ineligible or No Comparator(s)
X5. | Ineligible or No Outcome(s)
X6. | Ineligible Setting
X7. | Ineligible Study Design
X8. | Could Not Obtain Full Text
X9. | Poor Quality

1 Sharma SK, Sharma A, Kadhiravan T, et al. Rifamycins (rifampicin, rifabutin and rifapentine) compared to isoniazid for preventing tuberculosis in HIV-negative people at risk of active TB. Cochrane Database Syst Rev. 2013;7. Cd007545. Exclusion Code: X7. [pmid: 23828580].
2 Longhi RM, Zembrzuski VM, Basta PC, et al. Genetic polymorphism and immune response to tuberculosis in indigenous populations: a brief review. Braz J Infect Dis. May-Jun. 2013;17(3):363-8. Exclusion Code: X3. [pmid: 23665009].
3 Cohen D, Corbett E. Evidence supports TB test, so what now?. Cochrane Database Syst Rev. 2013;2:Ed000051. Exclusion Code: X1. [pmid: 23450616].
4 Steingart KR, Sohn H, Schiller I, et al. Xpert(R) MTB/RIF assay for pulmonary tuberculosis and rifampicin resistance in adults. Cochrane Database Syst Rev. 2013;1. Cd009593. Exclusion Code: X3. [pmid: 23440842].
5 Munoz L, Santin M. Interferon-gamma release assays versus tuberculin skin test for targeting people for tuberculosis preventive treatment: an evidence-based review. J Infect. Apr. 2013;66(4):381-7. Exclusion Code: X5. [pmid: 23298892].
6 Horne DJ, Pinto LM, Arentz M, et al. Diagnostic accuracy and reproducibility of WHO-endorsed phenotypic drug susceptibility testing methods for first-line and second-line antituberculosis drugs. J Clin Microbiol. Feb. 2013;51(2):393-401. Exclusion Code: X3. [pmid: 23152548].
7 Rogerson TE, Chen S, Kok J, et al. Tests for latent tuberculosis in people with ESRD: a systematic review. Am J Kidney Dis. Jan. 2013;61(1):33-43. Exclusion Code: X5. [pmid: 23068425].
8 Dai Y, Feng Y, Xu R, et al. Evaluation of interferon-gamma release assays for the diagnosis of tuberculosis: an updated meta-analysis. Eur J Clin Microbiol Infect Dis. Nov. 2012;31(11):3127-37. Exclusion Code: X2. [pmid: 22833244].
9 Diel R, Loddenkemper R, Nienhaus A. Predictive value of interferon-gamma release assays and tuberculin skin testing for progression from latent TB infection to disease state: a meta-analysis. Chest. Jul. 2012;142(1):63-75. Exclusion Code: X2. [pmid: 22490872].
10 Fan L, Chen Z, Hao XH, et al. Interferon-gamma release assays for the diagnosis of extrapulmonary tuberculosis: a systematic review and meta-analysis. FEMS Immunol Med Microbiol. Aug. 2012;65(3):456-66. Exclusion Code: X2. [pmid: 22487051].
11 Chang K, Lu W, Wang J, et al. Rapid and effective diagnosis of tuberculosis and rifampicin resistance with Xpert MTB/RIF assay: a meta-analysis. J Infect. Jun. 2012;64(6):580-8. Exclusion Code: X3. [pmid: 22381459].
12 Shahidi N, Fu YT, Qian H, et al. Performance of interferon-gamma release assays in patients with inflammatory bowel disease: a systematic review and meta-analysis. Inflamm Bowel Dis. Nov. 2012;18(11):2034-42. Exclusion Code: X2. [pmid: 22294550].
13 Fenner L, Rieder HL. Isoniazid preventive therapy for all: are we ready?. Int J Tuberc Lung Dis. Oct. 2011;15(10):1281-2. Exclusion Code: X1. [pmid: 22283884].
14 Amerio P, Amoruso G, Bardazzi F, et al. Detection and management of latent tuberculosis infections before biologic therapy for psoriasis. J Dermatolog Treat. Aug. 2013;24(4):305-11. Exclusion Code: X1. [pmid: 22208431].
15 Nienhaus A, Schablon A, Costa JT, et al. Systematic review of cost and cost-effectiveness of different TB-screening strategies. BMC Health Serv Res. 2011;11:247. Exclusion Code: X5. [pmid: 21961888].
16 Mrozek N, Pereira B, Soubrier M, et al. Screening of tuberculosis before biologics. Med Mal Infect. Jan. 2012;42(1):1-4. Exclusion Code: X7. [pmid: 21907513].
17 Rangaka MX, Wilkinson KA, Glynn JR, et al. Predictive value of interferon-gamma release assays for incident active tuberculosis: a systematic review and meta-analysis. Lancet Infect Dis. Jan. 2012;12(1):45-55. Exclusion Code: X5. [pmid: 21846592].
18 Zhou Q, Chen YQ, Qin SM, et al. Diagnostic accuracy of T-cell interferon-gamma release assays in tuberculous pleurisy: a meta-analysis. Respirology. Apr. 2011;16(3):473-80. Exclusion Code: X4. [pmid: 21299686].
19 Zwerling A, van den Hof S, Scholten J, et al. Interferon-gamma release assays for tuberculosis screening of healthcare workers: a systematic review. Thorax. Jan. 2012;67(1):62-70. Exclusion Code: X2. [pmid: 21228420].
20 Diel R, Goletti D, Ferrara G, et al. Interferon-gamma release assays for the diagnosis of latent Mycobacterium tuberculosis infection: a systematic review and meta-analysis. Eur Respir J. Jan. 2011;37(1):88-99. Exclusion Code: X2. [pmid: 21030451].
21 Kunst H, Khan KS. Age-related risk of hepatotoxicity in the treatment of latent tuberculosis infection: a systematic review. Int J Tuberc Lung Dis. Nov. 2010;14(11):1374-81. Exclusion Code: X7. [pmid: 20937175].
22 Erkens CG, Kamphorst M, Abubakar I, et al. Tuberculosis contact investigation in low prevalence countries: a European consensus. Eur Respir J. Oct. 2010;36(4):925-49. Exclusion Code: X1. [pmid: 20889463].
23 Freeman RJ, Mancuso JD, Riddle MS, et al. Systematic review and meta-analysis of TST conversion risk in deployed military and long-term civilian travelers. J Travel Med. Jul-Aug. 2010;17(4):233-42. Exclusion Code: X2. [pmid: 20636596].
24 Greenaway C, Sandoe A, Vissandjee B, et al. Tuberculosis: evidence review for newly arriving immigrants and refugees. Cmaj. Sep. 6. 2011;183(12):E939-51. Exclusion Code: X7. [pmid: 20634392].
25 Mazurek GH, Jereb J, Vernon A, et al. Updated guidelines for using Interferon Gamma Release Assays to detect Mycobacterium tuberculosis infection - United States, 2010. MMWR Recomm Rep. Jun. 25. 2010;59(RR-5):1-25. Exclusion Code: X1. [pmid: 20577159].
26 Chang KC, Leung CC. Systematic review of interferon-gamma release assays in tuberculosis: focus on likelihood ratios. Thorax. Mar. 2010;65(3):271-6. Exclusion Code: X2. [pmid: 20335301].
27 Diel R, Loddenkemper R, Nienhaus A. Evidence-based comparison of commercial interferon-gamma release assays for detecting active TB: a metaanalysis. Chest. Apr. 2010;137(4):952-68. Exclusion Code: X2. [pmid: 20022968].
28 Ziakas PD, Mylonakis E. 4 months of rifampin compared with 9 months of isoniazid for the management of latent tuberculosis infection: a meta-analysis and cost-effectiveness study that focuses on compliance and liver toxicity. Clin Infect Dis. Dec. 15. 2009;49(12):1883-9. Exclusion Code: X7. [pmid: 19911936].
29 Bliven EE, Podewils LJ. The role of chronic hepatitis in isoniazid hepatotoxicity during treatment for latent tuberculosis infection. Int J Tuberc Lung Dis. Sep. 2009;13(9):1054-60. Exclusion Code: X7. [pmid: 19723392].
30 Sadatsafavi M, Shahidi N, Marra F, et al. A statistical method was used for the meta-analysis of tests for latent TB in the absence of a gold standard, combining random-effect and latent-class methods to estimate test accuracy. J Clin Epidemiol. Mar. 2010;63(3):257-69. Exclusion Code: X5. [pmid: 19692208].
31 Pai M, Ramsay A, O'Brien R. Evidence-based tuberculosis diagnosis. PLoS Med. Jul. 22. 2008;5(7):e156. Exclusion Code: X1. [pmid: 18651788].
32 Pai M, Zwerling A, Menzies D. Systematic review: T-cell-based assays for the diagnosis of latent tuberculosis infection: an update. Ann Intern Med. Aug. 5. 2008;149(3):177-84. Exclusion Code: X2. [pmid: 18593687].
33 Madariaga MG, Jalali Z, Swindells S. Clinical utility of interferon gamma assay in the diagnosis of tuberculosis. J Am Board Fam Med. Nov-Dec. 2007;20(6):540-7. Exclusion Code: X7. [pmid: 17954861].
34 Menzies D, Pai M, Comstock G. Meta-analysis: new tests for the diagnosis of latent tuberculosis infection: areas of uncertainty and recommendations for research. Ann Intern Med. Mar. 6. 2007;146(5):340-54. Exclusion Code: X2. [pmid: 17339619].
35 Dinnes J, Deeks J, Kunst H, et al. A systematic review of rapid diagnostic tests for the detection of tuberculosis infection. Health Technol Assess. Jan. 2007;11(3):1-196. Exclusion Code: X3. [pmid: 17266837].
36 Farhat M, Greenaway C, Pai M, et al. False-positive tuberculin skin tests: what is the absolute effect of BCG and non-tuberculous mycobacteria?. Int J Tuberc Lung Dis. Nov. 2006;10(11):1192-204. Exclusion Code: X2. [pmid: 17131776].
37 Gao XF, Wang L, Liu GJ, et al. Rifampicin plus pyrazinamide versus isoniazid for treating latent tuberculosis infection: a meta-analysis. Int J Tuberc Lung Dis. Oct. 2006;10(10):1080-90. Exclusion Code: X7. [pmid: 17044199].
38 Balcells ME, Thomas SL, Godfrey-Faussett P, et al. Isoniazid preventive therapy and risk for resistant tuberculosis. Emerg Infect Dis. May. 2006;12(5):744-51. Exclusion Code: X2. [pmid: 16704830].
39 Fraser A, Paul M, Attamna A, et al. Treatment of latent tuberculosis in persons at risk for multidrug-resistant tuberculosis: systematic review. Int J Tuberc Lung Dis. Jan. 2006;10(1):19-23. Exclusion Code: X2. [pmid: 16466032].
40 Ena J, Valls V. Short-course therapy with rifampin plus isoniazid, compared with standard therapy with isoniazid, for latent tuberculosis infection: a meta-analysis. Clin Infect Dis. Mar. 1. 2005;40(5):670-6. Exclusion Code: X4. [pmid: 15714411].
41 Pai M, Riley LW, Colford JM Jr. Interferon-gamma assays in the immunodiagnosis of tuberculosis: a systematic review. Lancet Infect Dis. Dec. 2004;4(12):761-76. Exclusion Code: X2. [pmid: 15567126].
42 Smieja MJ, Marchetti CA, Cook DJ, et al. Isoniazid for preventing tuberculosis in non-HIV infected persons. Cochrane Database Syst Rev. 2000;(2). Cd001363. Exclusion Code: X7. [pmid: 10796642].
43 Temple ME, Nahata MC. Rifapentine: its role in the treatment of tuberculosis. Ann Pharmacother. Nov. 1999;33(11):1203-10. Exclusion Code: X2. [pmid: 10573321].
44 Steele MA, Burk RF, DesPrez RM. Toxic hepatitis with isoniazid and rifampin. A meta-analysis. Chest. Feb. 1991;99(2):465-71. Exclusion Code: X7. [pmid: 1824929].
45 O'Shea MK, Fletcher TE, Tupper D, et al. Screening for latent tuberculosis and gastrointestinal parasite infections in Gurkha recruits: research driving policy change. J R Army Med Corps. Jun. 2014;160(2):180-2. Exclusion Code: X2. [pmid: 24607484].
46 Ang M, Wong WL, Kiew SY, et al. Prospective head-to-head study comparing 2 commercial interferon gamma release assays for the diagnosis of tuberculous uveitis. Am J Ophthalmol. Jun. 2014;157(6):1306-14. 14.e1. 4. Exclusion Code: X2. [pmid: 24508163].
47 Auld SC, Click ES, Heilig CM, et al. Tuberculin skin test result and risk of death among persons with active TB. PLoS One. 2013;8(11):e78779. Exclusion Code: X5. [pmid: 24244358].
48 Auld SC, Click ES, Heilig CM, et al. Association between tuberculin skin test result and clinical presentation of tuberculosis disease. BMC Infect Dis. 2013;13:460. Exclusion Code: X2. [pmid: 24093965].
49 Moran-Mendoza O, Tello-Zavala MC, Rivera-Camarillo M, et al. Comparison of different methods and times for reading the tuberculin skin test. Int J Tuberc Lung Dis. Oct. 2013;17(10):1273-8. Exclusion Code: X5. [pmid: 24025377].
50 Slater ML, Welland G, Pai M, et al. Challenges with QuantiFERON-TB Gold assay for large-scale, routine screening of U.S. healthcare workers. Am J Respir Crit Care Med. Oct. 15. 2013;188(8):1005-10. Exclusion Code: X2. [pmid: 23978270].
51 Gaur RL, Pai M, Banaei N. Impact of blood volume, tube shaking, and incubation time on reproducibility of QuantiFERON-TB gold in-tube assay. J Clin Microbiol. Nov. 2013;51(11):3521-6. Exclusion Code: X4. [pmid: 23966505].
52 Lee YM, Park KH, Kim SM, et al. Risk factors for false-negative results of T-SPOT.TB and tuberculin skin test in extrapulmonary tuberculosis. Infection. Dec. 2013;41(6):1089-95. Exclusion Code: X2. [pmid: 23943073].
53 Shu CC, Wu VC, Yang FJ, et al. Dynamic changes in positive interferon-gamma release assay in a dialysis population: An observational cohort study. J Infect. Dec. 2013;67(6):529-35. Exclusion Code: X2. [pmid: 23933475].
54 Duque A, Lin SY, Desmond E, et al. Evaluation of the BD Bactec MGIT 320 system for detection of mycobacteria and drug susceptibility testing of Mycobacterium tuberculosis. J Clin Microbiol. Oct. 2013;51(10):3403-5. Exclusion Code: X2. [pmid: 23863564].
55 Dobler CC. What do we know about the outcomes of tuberculosis contact investigations in NSW?. N S W Public Health Bull. Jul. 2013;24(1):34-7. Exclusion Code: X2. [pmid: 23849028].
56 Ang M, Wong WL, Li X, et al. Interferon gamma release assay for the diagnosis of uveitis associated with tuberculosis: a Bayesian evaluation in the absence of a gold standard. Br J Ophthalmol. Aug. 2013;97(8):1062-7. Exclusion Code: X2. [pmid: 23723411].
57 Guglielmetti L, Cazzadori A, Conti M, et al. Lymphocyte subpopulations in active tuberculosis: association with disease severity and the QFT-GIT assay. Int J Tuberc Lung Dis. Jun. 2013;17(6):825-8. Exclusion Code: X3. [pmid: 23676170].
58 Zwerling A, Benedetti A, Cojocariu M, et al. Repeat IGRA testing in Canadian health workers: conversions or unexplained variability?. PLoS One. 2013;8(1):e54748. Exclusion Code: X5. [pmid: 23382955].
59 Aabye MG, Latorre I, Diaz J, et al. Dried plasma spots in the diagnosis of tuberculosis: IP-10 release assay on filter paper. Eur Respir J. Aug. 2013;42(2):495-503. Exclusion Code: X2. [pmid: 23349445].
60 Chawla H, Lobato MN, Sosa LE, et al. Predictors for a positive QuantiFERON-TB-Gold test in BCG-vaccinated adults with a positive tuberculin skin test. J Infect Public Health. Dec. 2012;5(6):369-73. Exclusion Code: X2. [pmid: 23287606].
61 Lytras T, Spala G, Bonovas S, et al. Evaluation of tuberculosis underreporting in Greece through comparison with anti-tuberculosis drug consumption. PLoS One. 2012;7(11):e50033. Exclusion Code: X2. [pmid: 23185524].
62 Tiernan JF, Gilhooley S, Jones ME, et al. Does an interferon-gamma release assay change practice in possible latent tuberculosis?. Qjm. Feb. 2013;106(2):139-46. Exclusion Code: X5. [pmid: 23159840].
63 del Campo MT, Fouad H, Solis-Bravo MM, et al. Cost-effectiveness of different screening strategies (single or dual) for the diagnosis of tuberculosis infection in healthcare workers. Infect Control Hosp Epidemiol. Dec. 2012;33(12):1226-34. Exclusion Code: X5. [pmid: 23143360].
64 Li H, Yang L, Zheng CY, et al. Use of bronchoalveolar lavage enzyme-linked immunospot for diagnosis of smear-negative pulmonary tuberculosis. Int J Tuberc Lung Dis. Dec. 2012;16(12):1668-73. Exclusion Code: X9. [pmid: 23131267].
65 Kamiya H, Ikushima S, Kondo K, et al. Diagnostic performance of interferon-gamma release assays in elderly populations in comparison with younger populations. J Infect Chemother. Apr. 2013;19(2):217-22. Exclusion Code: X9. [pmid: 23108426].
66 Kim SY, Park MS, Kim YS, et al. Conversion rates of an interferon-gamma release assay and the tuberculin skin test in the serial monitoring of healthcare workers. Infection. Apr. 2013;41(2):511-6. Exclusion Code: X5. [pmid: 23104257].
67 Chan PC, Yang CH, Chang LY, et al. Lower prevalence of tuberculosis infection in BCG vaccinees: a cross-sectional study in adult prison inmates. Thorax. Mar. 2013;68(3):263-8. Exclusion Code: X2. [pmid: 23019256].
68 Shrestha R, Gyawali P, Yadav BK, et al. In-vitro assessment of cell-mediated immunity by demonstrating effector-t cells for diagnosis of tuberculosis in Nepalese subjects. Nepal Med Coll J. Dec. 2011;13(4):275-8. Exclusion Code: X9. [pmid: 23016479].
69 He GX, Wang LX, Chai SJ, et al. Risk factors associated with tuberculosis infection among health care workers in Inner Mongolia, China. Int J Tuberc Lung Dis. Nov. 2012;16(11):1485-91. Exclusion Code: X5. [pmid: 22964074].
70 Haldar P, Thuraisingam H, Patel H, et al. Single-step QuantiFERON screening of adult contacts: a prospective cohort study of tuberculosis risk. Thorax. Mar. 2013;68(3):240-6. Exclusion Code: X2. [pmid: 22956558].
71 Campainha S, Gomes T, Carvalho A, et al. Negative predictive value of TST and IGRA in anti-TNF treated patients. Eur Respir J. Sep. 2012;40(3):790-1. Exclusion Code: X2. [pmid: 22941549].
72 Zwerling A, Cojocariu M, McIntosh F, et al. TB screening in Canadian health care workers using interferon-gamma release assays. PLoS One. 2012;7(8):e43014. Exclusion Code: X5. [pmid: 22916197].
73 Shu CC, Wu VC, Yang FJ, et al. Predictors and prevalence of latent tuberculosis infection in patients receiving long-term hemodialysis and peritoneal dialysis. PLoS One. 2012;7(8):e42592. Exclusion Code: X5. [pmid: 22916137].
74 Rose MV, Kimaro G, Kroidl I, et al. Evaluation of QuantiFERON microtube, using 0.9 mL blood, for diagnosing tuberculosis infection. Eur Respir J. Apr. 2013;41(4):909-16. Exclusion Code: X2. [pmid: 22878880].
75 Jo KW, Jeon K, Kang YA, et al. Poor correlation between tuberculin skin tests and interferon-gamma assays in close contacts of patients with multidrug-resistant tuberculosis. Respirology. Oct. 2012;17(7):1125-30. Exclusion Code: X2. [pmid: 22758779].
76 Banfield S, Pascoe E, Thambiran A, et al. Factors associated with the performance of a blood-based interferon-gamma release assay in diagnosing tuberculosis. PLoS One. 2012;7(6):e38556. Exclusion Code: X5. [pmid: 22701664].
77 Pareek M, Bond M, Shorey J, et al. Community-based evaluation of immigrant tuberculosis screening using interferon gamma release assays and tuberculin skin testing: observational study and economic analysis. Thorax. Mar. 2013;68(3):230-9. Exclusion Code: X2. [pmid: 22693179].
78 Gautam M, Darroch J, Bassett P, et al. Tuberculosis infection in the indigenous elderly White UK population: a study of IGRAs. Int J Tuberc Lung Dis. Apr. 2012;16(4):564. Exclusion Code: X7. [pmid: 22640515].
79 Lee SW, Lee SH, Yim JJ. Serial interferon-gamma release assays after chemoprophylaxis in a tuberculosis outbreak cohort. Infection. Aug. 2012;40(4):431-5. Exclusion Code: X5. [pmid: 22585454].
80 Turtle L, Kemp T, Davies GR, et al. In routine UK hospital practice T-SPOT.TB is useful in some patients with a modest pre-test probability of active tuberculosis. Eur J Intern Med. Jun. 2012;23(4):363-7. Exclusion Code: X9. [pmid: 22560387].
81 Chan PC, Yang CH, Chang LY, et al. Latent tuberculosis infection treatment for prison inmates: a randomised controlled trial. Int J Tuberc Lung Dis. May. 2012;16(5):633-8. Exclusion Code: X6. [pmid: 22410137].
82 Ang M, Wong W, Ngan CC, et al. Interferon-gamma release assay as a diagnostic test for tuberculosis-associated uveitis. Eye (Lond). May. 2012;26(5):658-65. Exclusion Code: X2. [pmid: 22302066].
83 Welch RJ, Lawless KM, Litwin CM. Antituberculosis IgG antibodies as a marker of active Mycobacterium tuberculosis disease. Clin Vaccine Immunol. Apr. 2012;19(4):522-6. Exclusion Code: X2. [pmid: 22301692].
84 Leiro-Fernandez V, Valverde D, Vazquez-Gallardo R, et al. N-acetyltransferase 2 polymorphisms and risk of anti-tuberculosis drug-induced hepatotoxicity in Caucasians. Int J Tuberc Lung Dis. Oct. 2011;15(10):1403-8. Exclusion Code: X7. [pmid: 22283902].
85 Altunoren O, Kahraman H, Sayarlioglu H, et al. The affecting factors and comparison of tuberculin skin test in peritoneal dialysis and hemodialysis patients. Ren Fail. 2012;34(3):304-7. Exclusion Code: X5. [pmid: 22260191].
86 Noorbakhsh S, Mousavi J, Barati M, et al. Evaluation of an interferon-gamma release assay in young contacts of active tuberculosis cases. East Mediterr Health J. Sep. 2011;17(9):714-8. Exclusion Code: X5. [pmid: 22259925].
87 Abu-Taleb AM, El-Sokkary RH, El Tarhouny SA. Interferon-gamma release assay for detection of latent tuberculosis infection in casual and close contacts of tuberculosis cases. East Mediterr Health J. Oct. 2011;17(10):749-53. Exclusion Code: X2. [pmid: 22256408].
88 Nogueira PA, Abrahao RM, Galesi VM. Tuberculosis and latent tuberculosis in prison inmates. Rev Saude Publica. Feb. 2012;46(1):119-27. Exclusion Code: X5. [pmid: 22252791].
89 Marco A, Sole N, Orcau A, et al. Prevalence of latent tuberculosis infection in inmates recently incarcerated in a men's prison in Barcelona. Int J Tuberc Lung Dis. Jan. 2012;16(1):60-4. Exclusion Code: X2. [pmid: 22236847].
90 Wang JY, Shu CC, Lee CH, et al. Interferon-gamma release assay and Rifampicin therapy for household contacts of tuberculosis. J Infect. Mar. 2012;64(3):291-8. Exclusion Code: X2. [pmid: 22207002].
91 Maden E, Bekci TT, Kesli R, et al. Evaluation of performance of quantiferon assay and tuberculin skin test in end stage renal disease patients receiving hemodialysis. New Microbiol. Oct. 2011;34(4):351-6. Exclusion Code: X2. [pmid: 22143808].
92 Yilmaz N, Zehra Aydin S, Inanc N, et al. Comparison of QuantiFERON-TB Gold test and tuberculin skin test for the identification of latent Mycobacterium tuberculosis infection in lupus patients. Lupus. Apr. 2012;21(5):491-5. Exclusion Code: X2. [pmid: 22140142].
93 Joshi R, Narang U, Zwerling A, et al. Predictive value of latent tuberculosis tests in Indian healthcare workers: a cohort study. Eur Respir J. Dec. 2011;38(6):1475-7. Exclusion Code: X6. [pmid: 22130764].
94 Khalil EA, Elnour AA, Musa AM, et al. Tuberculous lymphadenitis: skin delayed-type hypersensitivity reaction and cellular immune responses. West Afr J Med. May-Jun. 2011;30(3):193-6. Exclusion Code: X2. [pmid: 22120485].
95 Banach DB, Harris TG. Indeterminate QuantiFERON(R)-TB Gold results in a public health clinic setting. Int J Tuberc Lung Dis. Dec. 2011;15(12):1623-30. Exclusion Code: X2. [pmid: 22118169].
96 Grinsdale JA, Ho CS, Banouvong H, et al. Programmatic impact of using QuantiFERON(R)-TB Gold in routine contact investigation activities. Int J Tuberc Lung Dis. Dec. 2011;15(12):1614-20. Exclusion Code: X2. [pmid: 22118167].
97 Gupta D, Kumar S, Aggarwal AN, et al. Interferon gamma release assay (QuantiFERON-TB Gold In Tube) in patients of sarcoidosis from a population with high prevalence of tuberculosis infection. Sarcoidosis Vasc Diffuse Lung Dis. Oct. 2011;28(2):95-101. Exclusion Code: X3. [pmid: 22117500].
98 Worjoloh A, Kato-Maeda M, Osmond D, et al. Interferon gamma release assay compared with the tuberculin skin test for latent tuberculosis detection in pregnancy. Obstet Gynecol. Dec. 2011;118(6):1363-70. Exclusion Code: X2. [pmid: 22105266].
99 Gonzalez-Salazar F, Vargas-Villarreal J, Garcialuna-Martinez FJ, et al. Snapshot of Quantiferon TB gold testing in Northern Mexico. Tuberculosis (Edinb). Dec. Suppl 1. 2011;91:S34-7. Exclusion Code: X2. [pmid: 22099419].
100 Friedrich SO, von Groote-Bidlingmaier F, Diacon AH. Xpert MTB/RIF assay for diagnosis of pleural tuberculosis. J Clin Microbiol. Dec. 2011;49(12):4341-2. Exclusion Code: X3. [pmid: 21998430].
101 Hussain R, Ansari A, Talat N, et al. CCL2/MCP-I genotype-phenotype relationship in latent tuberculosis infection. PLoS One. 2011;6(10):e25803. Exclusion Code: X6. [pmid: 21991356].
102 Soysal A, Toprak D, Koc M, et al. Diagnosing latent tuberculosis infection in haemodialysis patients: T-cell based assay (T-SPOT.TB) or tuberculin skin test?. Nephrol Dial Transplant. Apr. 2012;27(4):1645-50. Exclusion Code: X6. [pmid: 21931124].
103 Schablon A, Diel R, Diner G, et al. Specificity of a whole blood IGRA in German nursing students. BMC Infect Dis. 2011;11:245. Exclusion Code: X2. [pmid: 21929799].
104 Fresard I, Bridevaux PO, Rochat T, et al. Adverse effects and adherence to treatment of rifampicin 4 months vs isoniazid 6 months for latent tuberculosis: a retrospective analysis. Swiss Med Wkly. 2011;141:w13240. Exclusion Code: X7. [pmid: 21842452].
105 Soares Pires F, Pinto C, Duarte R. Who misses the second step of evaluation in tuberculosis contact screening?. Eur Respir J. Aug. 2011;38(2):474-6. Exclusion Code: X5. [pmid: 21804166].
106 Mancuso JD, Tribble D, Mazurek GH, et al. Impact of targeted testing for latent tuberculosis infection using commercially available diagnostics. Clin Infect Dis. Aug. 1. 2011;53(3):234-44. Exclusion Code: X5. [pmid: 21765072].
107 Kim SH, Lee SO, Park JB, et al. A prospective longitudinal study evaluating the usefulness of a T-cell-based assay for latent tuberculosis infection in kidney transplant recipients. Am J Transplant. Sep. 2011;11(9):1927-35. Exclusion Code: X2. [pmid: 21749641].
108 Weinfurter P, Blumberg HM, Goldbaum G, et al. Predictors of discordant tuberculin skin test and QuantiFERON(R)-TB Gold In-Tube results in various high-risk groups. Int J Tuberc Lung Dis. Aug. 2011;15(8):1056-61. Exclusion Code: X2. [pmid: 21740668].
109 Doberne D, Gaur RL, Banaei N. Preanalytical delay reduces sensitivity of QuantiFERON-TB gold in-tube assay for detection of latent tuberculosis infection. J Clin Microbiol. Aug. 2011;49(8):3061-4. Exclusion Code: X3. [pmid: 21697332].
110 Bradshaw L, Davies E, Devine M, et al. The role of the interferon gamma release assay in assessing recent tuberculosis transmission in a hospital incident. PLoS One. 2011;6(6):e20770. Exclusion Code: X4. [pmid: 21695149].
111 Sauzullo I, Massetti AP, Mengoni F, et al. Influence of previous tuberculin skin test on serial IFN-gamma release assays. Tuberculosis (Edinb). Jul. 2011;91(4):322-6. Exclusion Code: X5. [pmid: 21664872].
112 de Andrade Lima E, de Andrade Lima M, de Lorena VM, et al. Evaluation of an IFN-gamma assay in the diagnosis of latent tuberculosis in patients with psoriasis in a highly endemic setting. Acta Derm Venereol. Oct. 2011;91(6):694-7. Exclusion Code: X5. [pmid: 21629971].
113 Komiya K, Ariga H, Nagai H, et al. Reversion rates of QuantiFERON-TB Gold are related to pre-treatment IFN-gamma levels. J Infect. Jul. 2011;63(1):48-53. Exclusion Code: X4. [pmid: 21624664].
114 Milman N, Soborg B, Svendsen CB, et al. Quantiferon test for tuberculosis screening in sarcoidosis patients. Scand J Infect Dis. Sep. 2011;43(9):728-35. Exclusion Code: X2. [pmid: 21619424].
115 Ringshausen FC, Nienhaus A, Torres Costa J, et al. Within-subject variability of Mycobacterium tuberculosis-specific gamma interferon responses in German health care workers. Clin Vaccine Immunol. Jul. 2011;18(7):1176-82. Exclusion Code: X2. [pmid: 21593237].
116 Kim YS, Kim YH, Kim WH, et al. Diagnostic utility of anti-Saccharomyces cerevisiae antibody (ASCA) and Interferon-gamma assay in the differential diagnosis of Crohn's disease and intestinal tuberculosis. Clin Chim Acta. Aug. 17. 2011;412(17-18):1527-32. Exclusion Code: X2. [pmid: 21575618].
117 Risk of tuberculosis among contacts of isoniazid-resistant and isoniazid-susceptible cases. Int J Tuberc Lung Dis. Jun. 2011;15(6):782-8. Exclusion Code: X2. [pmid: 21575299].
118 Takeda N, Nojima T, Terao C, et al. Interferon-gamma release assay for diagnosing Mycobacterium tuberculosis infections in patients with systemic lupus erythematosus. Lupus. Jul. 2011;20(8):792-800. Exclusion Code: X2. [pmid: 21562022].
119 Caglayan V, Ak O, Dabak G, et al. Comparison of tuberculin skin testing and QuantiFERON-TB Gold-In Tube test in health care workers. Tuberk Toraks. 2011;59(1):43-7. Exclusion Code: X2. [pmid: 21554229].
120 Pareek M, Watson JP, Ormerod LP, et al. Screening of immigrants in the UK for imported latent tuberculosis: a multicentre cohort study and cost-effectiveness analysis. Lancet Infect Dis. Jun. 2011;11(6):435-44. Exclusion Code: X4. [pmid: 21514236].
121 Lee JE, Kim HJ, Lee SW. The clinical utility of tuberculin skin test and interferon-gamma release assay in the diagnosis of active tuberculosis among young adults: a prospective observational study. BMC Infect Dis. 2011;11:96. Exclusion Code: X2. [pmid: 21501477].
122 Jafari C, Kessler P, Sotgiu G, et al. Impact of a Mycobacterium tuberculosis-specific interferon-gamma release assay in bronchoalveolar lavage fluid for a rapid diagnosis of tuberculosis. J Intern Med. Sep. 2011;270(3):254-62. Exclusion Code: X5. [pmid: 21418341].
123 Kim HJ, Yoon HI, Park KU, et al. The impact of previous tuberculosis history on T-SPOT.TB(R) interferon-gamma release assay results. Int J Tuberc Lung Dis. Apr. 2011;15(4):510-6. Exclusion Code: X2. [pmid: 21396211].
124 Ling DI, Pai M, Davids V, et al. Are interferon-gamma release assays useful for diagnosing active tuberculosis in a high-burden setting?. Eur Respir J. Sep. 2011;38(3):649-56. Exclusion Code: X2. [pmid: 21349910].
125 Smith BM, Schwartzman K, Bartlett G, et al. Adverse events associated with treatment of latent tuberculosis in the general population. Cmaj. Feb. 22. 2011;183(3):E173-9. Exclusion Code: X7. [pmid: 21220436].
126 Anibarro L, Trigo M, Villaverde C, et al. Interferon-gamma release assays in tuberculosis contacts: is there a window period?. Eur Respir J. Jan. 2011;37(1):215-7. Exclusion Code: X2. [pmid: 21205718].
127 Gilham L, France J, Stirling A, et al. Tuberculosis screening before biologics -- T-SPOT for all?. J Rheumatol. Jan. 2011;38(1):179. Exclusion Code: X2. [pmid: 21196587].
128 Leung EC, Leung CC, Leung WW, et al. Role of whole-blood interferon-gamma release assay in the diagnosis of smear-negative tuberculosis. Int J Tuberc Lung Dis. Dec. 2010;14(12):1564-70. Exclusion Code: X2. [pmid: 21144241].
129 Zhang M, Wang H, Liao M, et al. Diagnosis of latent tuberculosis infection in bacille Calmette-Guerin vaccinated subjects in China by interferon-gamma ELISpot assay. Int J Tuberc Lung Dis. Dec. 2010;14(12):1556-63. Exclusion Code: X2. [pmid: 21144240].
130 Kim BJ, Choi YS, Jang BI, et al. Prospective evaluation of the clinical utility of interferon-gamma assay in the differential diagnosis of intestinal tuberculosis and Crohn's disease. Inflamm Bowel Dis. Jun. 2011;17(6):1308-13. Exclusion Code: X2. [pmid: 21053248].
131 Gandra S, Scott WS, Somaraju V, et al. Questionable effectiveness of the QuantiFERON-TB Gold Test (Cellestis) as a screening tool in healthcare workers. Infect Control Hosp Epidemiol. Dec. 2010;31(12):1279-85. Exclusion Code: X2. [pmid: 20979495].
132 Lee SW, Lee CT, Yim JJ. Serial interferon-gamma release assays during treatment of active tuberculosis in young adults. BMC Infect Dis. 2010;10:300. Exclusion Code: X2. [pmid: 20950477].
133 Connell DW, Singanayagam A, Charif R, et al. A comparison between interferon gamma release assays and the tuberculin skin test in the contact tracing of patients with chronic kidney disease. Thorax. Aug. 2011;66(8):729-30. author reply 30. Exclusion Code: X2. [pmid: 20947898].
134 Ball PM, Pernollet M, Bouillet L, et al. Usefulness of an in-vitro tuberculosis interferon-&#x03B3; release assay (T-SPOT.TB) in the first-line check-up of uveitis patients. Ann Med. Oct. 2010;42(7):546-54. Exclusion Code: X2. [pmid: 20868342].
135 Baboolal S, Ramoutar D, Akpaka PE. Comparison of the QuantiFERON(R)-TB Gold assay and tuberculin skin test to detect latent tuberculosis infection among target groups in Trinidad & Tobago. Rev Panam Salud Publica. Jul. 2010;28(1):36-42. Exclusion Code: X2. [pmid: 20857019].
136 Chigbu LN, Iroegbu CU. Incidence and spread of Mycobacterium tuberculosis-associated infection among Aba Federal prison inmates in Nigeria. J Health Popul Nutr. Aug. 2010;28(4):327-32. Exclusion Code: X2. [pmid: 20824975].
137 Petrescu L, Stancu S, Tardei G, et al. Tuberculin skin test, interferon-gamma assay, and T cells subpopulations in hemodialysis patients. J Ren Nutr. Sep. 2010;20(5 Suppl):S109-17. Exclusion Code: X2. [pmid: 20797557].
138 Harstad I, Winje BA, Heldal E, et al. Predictive values of QuantiFERON-TB Gold testing in screening for tuberculosis disease in asylum seekers. Int J Tuberc Lung Dis. Sep. 2010;14(9):1209-11. Exclusion Code: X2. [pmid: 20819271].
139 Dilektasli AG, Erdem E, Durukan E, et al. Feasibility of the T-SPOT.TB assay for the immunodiagnosis of smear-positive pulmonary tuberculosis using induced sputum. Int J Tuberc Lung Dis. Sep. 2010;14(9):1205-8. Exclusion Code: X2. [pmid: 20819270].
140 Diel R, Loddenkemper R, Niemann S, et al. Negative and positive predictive value of a whole-blood interferon-gamma release assay for developing active tuberculosis: an update. Am J Respir Crit Care Med. Jan. 1. 2011;183(1):88-95. Exclusion Code: X2. [pmid: 20802162].
141 Person AK, Goswami ND, Bissette DJ, et al. Pairing QuantiFERON gold in-tube with opt-out HIV testing in a tuberculosis contact investigation in the Southeastern United States. AIDS Patient Care STDS. Sep. 2010;24(9):539-43. Exclusion Code: X2. [pmid: 20731612].
142 Spence MR, Sibert D, Fleischer L, et al. A field trial evaluating the Quantiferon Gold tuberculosis tube test in an endemic population. Am J Infect Control. Feb. 2011;39(1):79-80. Exclusion Code: X2. [pmid: 20673599].
143 Ringshausen FC, Nienhaus A, Schablon A, et al. Predictors of persistently positive Mycobacterium-tuberculosis-specific interferon-gamma responses in the serial testing of health care workers. BMC Infect Dis. 2010;10:220. Exclusion Code: X2. [pmid: 20653946].
144 Aspler A, Long R, Trajman A, et al. Impact of treatment completion, intolerance and adverse events on health system costs in a randomised trial of 4 months rifampin or 9 months isoniazid for latent TB. Thorax. Jul. 2010;65(7):582-7. Exclusion Code: X5. [pmid: 20627913].
145 Gallant CJ, Cobat A, Simkin L, et al. Impact of age and sex on mycobacterial immunity in an area of high tuberculosis incidence. Int J Tuberc Lung Dis. Aug. 2010;14(8):952-9. Exclusion Code: X2. [pmid: 20626938].
146 Wang SH, Powell DA, Nagaraja HN, et al. Evaluation of a modified interferon-gamma release assay for the diagnosis of latent tuberculosis infection in adult and paediatric populations that enables delayed processing. Scand J Infect Dis. Dec. 2010;42(11-12):845-50. Exclusion Code: X2. [pmid: 20608764].
147 Wu X, Li Q, Liang Y, et al. Clinical evaluation of a homemade enzyme-linked immunospot assay for the diagnosis of active tuberculosis in China. Mol Biotechnol. Jan. 2011;47(1):18-25. Exclusion Code: X3. [pmid: 20596901].
148 Guo N, Marra F, Fitzgerald JM, et al. Impact of adverse drug reaction and predictivity of quality of life status in tuberculosis. Eur Respir J. Jul. 2010;36(1):206-8. Exclusion Code: X3. [pmid: 20595167].
149 Abdalhamid B, Hinrichs SH, Garrett JL, et al. Utilization of the QuantiFERON-TB Gold test in a two-step process with the tuberculin skin test to evaluate health care workers for latent tuberculosis. J Clin Microbiol. Aug. 2010;48(8):2955-6. Exclusion Code: X2. [pmid: 20573876].
150 Yoshiyama T, Harada N, Higuchi K, et al. Use of the QuantiFERON-TB Gold test for screening tuberculosis contacts and predicting active disease. Int J Tuberc Lung Dis. Jul. 2010;14(7):819-27. Exclusion Code: X2. [pmid: 20550763].
151 Lee SS, Chou KJ, Dou HY, et al. High prevalence of latent tuberculosis infection in dialysis patients using the interferon-gamma release assay and tuberculin skin test. Clin J Am Soc Nephrol. Aug. 2010;5(8):1451-7. Exclusion Code: X2. [pmid: 20538837].
152 Jong Lee K, Ae Kang Y, Mi Kim Y, et al. Screening for latent tuberculosis infection in South Korean healthcare workers using a tuberculin skin test and whole blood interferon-gamma assay. Scand J Infect Dis. Sep. 2010;42(9):672-8. Exclusion Code: X2. [pmid: 20482459].
153 Goletti D, Raja A, Ahamed Kabeer BS, et al. IFN-gamma, but not IP-10, MCP-2 or IL-2 response to RD1 selected peptides associates to active tuberculosis. J Infect. Jul. 2010;61(2):133-43. Exclusion Code: X2. [pmid: 20470822].
154 Lienhardt C, Fielding K, Hane AA, et al. Evaluation of the prognostic value of IFN-gamma release assay and tuberculin skin test in household contacts of infectious tuberculosis cases in Senegal. PLoS One. 2010;5(5):e10508. Exclusion Code: X2. [pmid: 20463900].
155 Cashmore TJ, Peter JG, van Zyl-Smit RN, et al. Feasibility and diagnostic utility of antigen-specific interferon-gamma responses for rapid immunodiagnosis of tuberculosis using induced sputum. PLoS One. 2010;5(4):e10389. Exclusion Code: X3. [pmid: 20442850].
156 Patel VB, Singh R, Connolly C, et al. Cerebrospinal T-cell responses aid in the diagnosis of tuberculous meningitis in a human immunodeficiency virus- and tuberculosis-endemic population. Am J Respir Crit Care Med. Aug. 15. 2010;182(4):569-77. Exclusion Code: X2. [pmid: 20442433].
157 Chung WK, Zheng ZL, Kim HS, et al. Serial testing of interferon-gamma-release assays for the diagnosis of latent tuberculosis in hemodialysis patients. J Infect. Jul. 2010;61(2):144-9. Exclusion Code: X2. [pmid: 20435059].
158 Orlando G, Merli S, Cordier L, et al. Interferon-gamma releasing assay versus tuberculin skin testing for latent tuberculosis infection in targeted screening programs for high risk immigrants. Infection. Jun. 2010;38(3):195-204. Exclusion Code: X2. [pmid: 20411295].
159 Simsek H, Alpar S, Ucar N, et al. Comparison of tuberculin skin testing and T-SPOT.TB for diagnosis of latent and active tuberculosis. Jpn J Infect Dis. Mar. 2010;63(2):99-102. Exclusion Code: X2. [pmid: 20332570].
160 Dyrhol-Riise AM, Gran G, Wentzel-Larsen T, et al. Diagnosis and follow-up of treatment of latent tuberculosis; the utility of the QuantiFERON-TB Gold In-tube assay in outpatients from a tuberculosis low-endemic country. BMC Infect Dis. 2010;10:57. Exclusion Code: X2. [pmid: 20210999].
161 Sheriff FG, Manji KP, Manji MP, et al. Latent tuberculosis among pregnant mothers in a resource poor setting in Northern Tanzania: a cross-sectional study. BMC Infect Dis. 2010;10:52. Exclusion Code: X2. [pmid: 20205938].
162 Cordova J, Shiloh R, Gilman RH, et al. Evaluation of molecular tools for detection and drug susceptibility testing of Mycobacterium tuberculosis in stool specimens from patients with pulmonary tuberculosis. J Clin Microbiol. May. 2010;48(5):1820-6. Exclusion Code: X3. [pmid: 20200293].
163 Kleinert S, Kurzai O, Elias J, et al. Comparison of two interferon-gamma release assays and tuberculin skin test for detecting latent tuberculosis in patients with immune-mediated inflammatory diseases. Ann Rheum Dis. Apr. 2010;69(4):782-4. Exclusion Code: X2. [pmid: 20185504].
164 Saracino A, Scotto G, Fornabaio C, et al. QuantiFERON-TB Gold In-Tube test (QFT-GIT) for the screening of latent tuberculosis in recent immigrants to Italy. New Microbiol. Oct. 2009;32(4):369-76. Exclusion Code: X2. [pmid: 20128443].
165 Bua A, Molicotti P, Cannas S, et al. Usefulness of the QuantiFERON-TB-Gold in tube in a population at risk of bovine tubercular infection. Acta Microbiol Immunol Hung. Dec. 2009;56(4):369-73. Exclusion Code: X2. [pmid: 20038488].
166 Nakamura H, Tateyama M, Tasato D, et al. Active tuberculosis in patients undergoing hemodialysis for end-stage renal disease: a 9-year retrospective analysis in a single center. Intern Med. 2009;48(24):2061-7. Exclusion Code: X2. [pmid: 20009393].
167 Kim EY, Lim JE, Jung JY, et al. Performance of the tuberculin skin test and interferon-gamma release assay for detection of tuberculosis infection in immunocompromised patients in a BCG-vaccinated population. BMC Infect Dis. 2009;9:207. Exclusion Code: X2. [pmid: 20003535].
168 Kifai EJ, Bakari M. Mantoux skin test reactivity among household contacts of HIV-infected and HIV un-infected patients with sputum smear positive TB in Dar es Salaam, Tanzania. East Afr J Public Health. Aug. 2009;6(2):211-8. Exclusion Code: X2. [pmid: 20000032].
169 Kang JS, Cherian A, Gan SH, et al. Strong purified protein derivative responses are associated with poor mycobacterium inhibition in latent TB. Eur Respir J. Aug. 2010;36(2):348-54. Exclusion Code: X2. [pmid: 19996195].
170 Gogus F, Gunendi Z, Karakus R, et al. Comparison of tuberculin skin test and QuantiFERON-TB gold in tube test in patients with chronic inflammatory diseases living in a tuberculosis endemic population. Clin Exp Med. Sep. 2010;10(3):173-7. Exclusion Code: X2. [pmid: 19949831].
171 Babu S, Bhat SQ, Kumar NP, et al. Regulatory T cells modulate Th17 responses in patients with positive tuberculin skin test results. J Infect Dis. Jan. 1. 2010;201(1):20-31. Exclusion Code: X2. [pmid: 19929695].
172 Li L, Mahan CS, Palaci M, et al. Sputum Mycobacterium tuberculosis mRNA as a marker of bacteriologic clearance in response to antituberculosis therapy. J Clin Microbiol. Jan. 2010;48(1):46-51. Exclusion Code: X3. [pmid: 19923475].
173 Seyhan EC, Sokucu S, Altin S, et al. Comparison of the QuantiFERON-TB Gold In-Tube test with the tuberculin skin test for detecting latent tuberculosis infection in hemodialysis patients. Transpl Infect Dis. Apr. 2010;12(2):98-105. Exclusion Code: X2. [pmid: 19903322].
174 Lee SW, Jang YS, Park CM, et al. The role of chest CT scanning in TB outbreak investigation. Chest. May. 2010;137(5):1057-64. Exclusion Code: X2. [pmid: 19880906].
175 Babu K, Satish V, Satish S, et al. Utility of QuantiFERON TB gold test in a south Indian patient population of ocular inflammation. Indian J Ophthalmol. Nov-Dec. 2009;57(6):427-30. Exclusion Code: X2. [pmid: 19861743].
176 Shovman O, Anouk M, Vinnitsky N, et al. QuantiFERON-TB Gold in the identification of latent tuberculosis infection in rheumatoid arthritis: a pilot study. Int J Tuberc Lung Dis. Nov. 2009;13(11):1427-32. Exclusion Code: X2. [pmid: 19861018].
177 Kobashi Y, Mouri K, Yagi S, et al. Clinical evaluation of the QuantiFERON-TB Gold test in patients with non-tuberculous mycobacterial disease. Int J Tuberc Lung Dis. Nov. 2009;13(11):1422-6. Exclusion Code: X2. [pmid: 19861017].
178 Zhao X, Mazlagic D, Flynn EA, et al. Is the QuantiFERON-TB blood assay a good replacement for the tuberculin skin test in tuberculosis screening? a pilot study at Berkshire Medical Center. Am J Clin Pathol. Nov. 2009;132(5):678-86. Exclusion Code: X2. [pmid: 19846807].
179 Kik SV, Franken WP, Mensen M, et al. Predictive value for progression to tuberculosis by IGRA and TST in immigrant contacts. Eur Respir J. Jun. 2010;35(6):1346-53. Exclusion Code: X5. [pmid: 19840963].
180 Hussain R, Talat N, Shahid F, et al. Biomarker changes associated with Tuberculin Skin Test (TST) conversion: a two-year longitudinal follow-up study in exposed household contacts. PLoS One. 2009;4(10):e7444. Exclusion Code: X2. [pmid: 19826490].
181 Ferrara G, Losi M, D'Amico R, et al. Interferon-gamma-release assays detect recent tuberculosis re-infection in elderly contacts. Int J Immunopathol Pharmacol. Jul-Sep. 2009;22(3):669-77. Exclusion Code: X2. [pmid: 19822083].
182 Cummings KJ, Smith TS, Shogren ES, et al. Prospective comparison of tuberculin skin test and QuantiFERON-TB Gold In-Tube assay for the detection of latent tuberculosis infection among healthcare workers in a low-incidence setting. Infect Control Hosp Epidemiol. Nov. 2009;30(11):1123-6. Exclusion Code: X9. [pmid: 19803719].
183 Shalabi NM, Houssen ME. Discrepancy between the tuberculin skin test and the levels of serum interferon-gamma in the diagnosis of tubercular infection in contacts. Clin Biochem. Nov. 2009;42(16-17):1596-601. Exclusion Code: X9. [pmid: 19732759].
184 Casas I, Latorre I, Esteve M, et al. Evaluation of interferon-gamma release assays in the diagnosis of recent tuberculosis infection in health care workers. PLoS One. 2009;4(8):e6686. Exclusion Code: X2. [pmid: 19701460].
185 Swindells JE, Aliyu SH, Enoch DA, et al. Role of interferon-gamma release assays in healthcare workers. J Hosp Infect. Oct. 2009;73(2):101-8. Exclusion Code: X2. [pmid: 19699551].
186 Park SH, Yang SK, Yang DH, et al. Prospective randomized trial of six-month versus nine-month therapy for intestinal tuberculosis. Antimicrob Agents Chemother. Oct. 2009;53(10):4167-71. Exclusion Code: X2. [pmid: 19667282].
187 Li J, Munsiff SS, Tarantino T, et al. Adherence to treatment of latent tuberculosis infection in a clinical population in New York City. Int J Infect Dis. Apr. 2010;14(4):e292-7. Exclusion Code: X5. [pmid: 19656705].
188 Chee CB, Lim LK, Barkham TM, et al. Use of a T cell interferon-gamma release assay to evaluate tuberculosis risk in newly qualified physicians in Singapore healthcare institutions. Infect Control Hosp Epidemiol. Sep. 2009;30(9):870-5. Exclusion Code: X2. [pmid: 19637958].
189 Kalantri Y, Hemvani N, Chitnis DS. Evaluation of whole blood IFNgamma test using PPD and recombinant antigen challenge for diagnosis of pulmonary and extra-pulmonary tuberculosis. Indian J Exp Biol. Jun. 2009;47(6):463-8. Exclusion Code: X9. [pmid: 19634712].
190 Kobashi Y, Shimizu H, Ohue Y, et al. False negative results of QuantiFERON TB-2G test in patients with active tuberculosis. Jpn J Infect Dis. Jul. 2009;62(4):300-2. Exclusion Code: X9. [pmid: 19628910].
191 Alvarez-Leon EE, Espinosa-Vega E, Santana-Rodriguez E, et al. Screening for tuberculosis infection in spanish healthcare workers: Comparison of the QuantiFERON-TB gold in-tube test with the tuberculin skin test. Infect Control Hosp Epidemiol. Sep. 2009;30(9):876-83. Exclusion Code: X2. [pmid: 19614541].
192 Dheda K, van Zyl-Smit RN, Meldau R, et al. Quantitative lung T cell responses aid the rapid diagnosis of pulmonary tuberculosis. Thorax. Oct. 2009;64(10):847-53. Exclusion Code: X2. [pmid: 19592392].
193 Ang M, Htoon HM, Chee SP. Diagnosis of tuberculous uveitis: clinical application of an interferon-gamma release assay. Ophthalmology. Jul. 2009;116(7):1391-6. Exclusion Code: X4. [pmid: 19576501].
194 Detjen AK, Loebenberg L, Grewal HM, et al. Short-term reproducibility of a commercial interferon gamma release assay. Clin Vaccine Immunol. Aug. 2009;16(8):1170-5. Exclusion Code: X2. [pmid: 19535542].
195 Tsiouri G, Gaitanis G, Kiorpelidou D, et al. Tuberculin skin test overestimates tuberculosis hypersensitivity in adult patients with psoriasis. Dermatology. 2009;219(2):119-25. Exclusion Code: X2. [pmid: 19478478].
196 Bartacek A, Schutt D, Panosch B, et al. Comparison of a four-drug fixed-dose combination regimen with a single tablet regimen in smear-positive pulmonary tuberculosis. Int J Tuberc Lung Dis. Jun. 2009;13(6):760-6. Exclusion Code: X2. [pmid: 19460254].
197 Khanna P, Nikolayevskyy V, Warburton F, et al. Rate of latent tuberculosis infection detected by occupational health screening of nurses new to a london teaching hospital. Infect Control Hosp Epidemiol. Jun. 2009;30(6):581-4. Exclusion Code: X2. [pmid: 19415970].
198 Dheda K, van Zyl-Smit RN, Sechi LA, et al. Utility of quantitative T-cell responses versus unstimulated interferon-{gamma} for the diagnosis of pleural tuberculosis. Eur Respir J. Nov. 2009;34(5):1118-26. Exclusion Code: X2. [pmid: 19386693].
199 Baker CA, Thomas W, Stauffer WM, et al. Serial testing of refugees for latent tuberculosis using the QuantiFERON-gold in-tube: effects of an antecedent tuberculin skin test. Am J Trop Med Hyg. Apr. 2009;80(4):628-33. Exclusion Code: X5. [pmid: 19346390].
200 Fu R, Wang C, Shi C, et al. An improved whole-blood gamma interferon assay based on the CFP21-MPT64 fusion protein. Clin Vaccine Immunol. May. 2009;16(5):686-91. Exclusion Code: X2. [pmid: 19279170].
201 Hess K, Goad J, Wu J, et al. Isoniazid completion rates for latent tuberculosis infection among college students managed by a community pharmacist. J Am Coll Health. Mar-Apr. 2009;57(5):553-5. Exclusion Code: X7. [pmid: 19254898].
202 Meintjes G, Rangaka MX, Maartens G, et al. Novel relationship between tuberculosis immune reconstitution inflammatory syndrome and antitubercular drug resistance. Clin Infect Dis. Mar. 1. 2009;48(5):667-76. Exclusion Code: X2. [pmid: 19191655].
203 Lee SS, Chou KJ, Su IJ, et al. High prevalence of latent tuberculosis infection in patients in end-stage renal disease on hemodialysis: Comparison of QuantiFERON-TB GOLD, ELISPOT, and tuberculin skin test. Infection. Apr. 2009;37(2):96-102. Exclusion Code: X2. [pmid: 19139810].
204 Kobashi Y, Sugiu T, Mouri K, et al. Indeterminate results of QuantiFERON TB-2G test performed in routine clinical practice. Eur Respir J. Apr. 2009;33(4):812-5. Exclusion Code: X2. [pmid: 19129287].
205 Sahni R, Miranda C, Yen-Lieberman B, et al. Does the implementation of an interferon-gamma release assay in lieu of a tuberculin skin test increase acceptance of preventive therapy for latent tuberculosis among healthcare workers?. Infect Control Hosp Epidemiol. Feb. 2009;30(2):197-9. Exclusion Code: X5. [pmid: 19119939].
206 Sagheb MM, Goodarzi M, Roozbeh J. The booster phenomenon of tuberculin skin testing in patients receiving hemodialysis. Iran J Immunol. Dec. 2008;5(4):212-6. Exclusion Code: X5. [pmid: 19098365].
207 Araujo Z, Giampietro F, Cancado LC, et al. Comparison of serological responses in two different populations with pulmonary tuberculosis. Mem Inst Oswaldo Cruz. Nov. 2008;103(7):661-7. Exclusion Code: X3. [pmid: 19057815].
208 Diel R, Loddenkemper R, Meywald-Walter K, et al. Comparative performance of tuberculin skin test, QuantiFERON-TB-Gold In Tube assay, and T-SPOT.TB test in contact investigations for tuberculosis. Chest. Apr. 2009;135(4):1010-8. Exclusion Code: X2. [pmid: 19017873].
209 Golub JE, Astemborski J, Ahmed M, et al. Long-term effectiveness of diagnosing and treating latent tuberculosis infection in a cohort of HIV-infected and at-risk injection drug users. J Acquir Immune Defic Syndr. Dec. 15. 2008;49(5):532-7. Exclusion Code: X7. [pmid: 18989223].
210 Janssens JP, Roux-Lombard P, Perneger T, et al. Contribution of a IFN-gamma assay in contact tracing for tuberculosis in a low-incidence, high immigration area. Swiss Med Wkly. Oct. 4. 2008;138(39-40):585-93. Exclusion Code: X5. [pmid: 18853288].
211 Anderson BL, Welch RJ, Litwin CM. Assessment of three commercially available serologic assays for detection of antibodies to Mycobacterium tuberculosis and identification of active tuberculosis. Clin Vaccine Immunol. Nov. 2008;15(11):1644-9. Exclusion Code: X3. [pmid: 18827190].
212 Ruhwald M, Bodmer T, Maier C, et al. Evaluating the potential of IP-10 and MCP-2 as biomarkers for the diagnosis of tuberculosis. Eur Respir J. Dec. 2008;32(6):1607-15. Exclusion Code: X2. [pmid: 18684849].
213 Chegou NN, Walzl G, Bolliger CT, et al. Evaluation of adapted whole-blood interferon-gamma release assays for the diagnosis of pleural tuberculosis. Respiration. 2008;76(2):131-8. Exclusion Code: X2. [pmid: 18434705].
214 Chang KC, Leung CC, Yew WW, et al. Hepatotoxicity of pyrazinamide: cohort and case-control analyses. Am J Respir Crit Care Med. Jun. 15. 2008;177(12):1391-6. Exclusion Code: X2. [pmid: 18388355].
215 Carvalho AC, Crotti N, Crippa M, et al. QuantiFERON-TB Gold test for healthcare workers. J Hosp Infect. May. 2008;69(1):91-2. Exclusion Code: X5. [pmid: 18358562].
216 Dosanjh DP, Hinks TS, Innes JA, et al. Improved diagnostic evaluation of suspected tuberculosis. Ann Intern Med. Mar. 4. 2008;148(5):325-36. Exclusion Code: X2. [pmid: 18316751].
217 Eum SY, Lee YJ, Kwak HK, et al. Evaluation of the diagnostic utility of a whole-blood interferon-gamma assay for determining the risk of exposure to Mycobacterium tuberculosis in Bacille Calmette-Guerin (BCG)-vaccinated individuals. Diagn Microbiol Infect Dis. Jun. 2008;61(2):181-6. Exclusion Code: X9. [pmid: 18296002].
218 Diel R, Loddenkemper R, Meywald-Walter K, et al. Predictive value of a whole blood IFN-gamma assay for the development of active tuberculosis disease after recent infection with Mycobacterium tuberculosis. Am J Respir Crit Care Med. May. 15. 2008;177(10):1164-70. Exclusion Code: X2. [pmid: 18276940].
219 Adams LV, Waddell RD, Von Reyn CF. T-SPOT.TB Test(R) results in adults with Mycobacterium avium complex pulmonary disease. Scand J Infect Dis. 2008;40(3):196-203. Exclusion Code: X2. [pmid: 18274952].
220 Haley CA, Stephan S, Vossel LF, et al. Successful use of rifampicin for Hispanic foreign-born patients with latent tuberculosis infection. Int J Tuberc Lung Dis. Feb. 2008;12(2):160-7. Exclusion Code: X4. [pmid: 18230248].
221 Perry S, Sanchez L, Yang S, et al. Reproducibility of QuantiFERON-TB gold in-tube assay. Clin Vaccine Immunol. Mar. 2008;15(3):425-32. Exclusion Code: X2. [pmid: 18199741].
222 Beffa P, Zellweger A, Janssens JP, et al. Indeterminate test results of T-SPOT.TB performed under routine field conditions. Eur Respir J. Apr. 2008;31(4):842-6. Exclusion Code: X2. [pmid: 18057053].
223 Palazzo R, Spensieri F, Massari M, et al. Use of whole-blood samples in in-house bulk and single-cell antigen-specific gamma interferon assays for surveillance of Mycobacterium tuberculosis infections. Clin Vaccine Immunol. Feb. 2008;15(2):327-37. Exclusion Code: X9. [pmid: 18032595].
224 Choi CM, Hwang SS, Lee CH, et al. Latent tuberculosis infection in a military setting diagnosed by whole-blood interferon-gamma assay. Respirology. Nov. 2007;12(6):898-901. Exclusion Code: X2. [pmid: 17986121].
225 Dominguez J, Ruiz-Manzano J, De Souza-Galvao M, et al. Comparison of two commercially available gamma interferon blood tests for immunodiagnosis of tuberculosis. Clin Vaccine Immunol. Jan. 2008;15(1):168-71. Exclusion Code: X2. [pmid: 17978008].
226 Veeser PI, Smith PK, Handy B, et al. Tuberculosis screening on a health science campus: use of QuantiFERON-TB Gold Test for students and employees. J Am Coll Health. Sep-Oct. 2007;56(2):175-80. Exclusion Code: X4. [pmid: 17967764].
227 Smith-Rohrberg D, Sharma SK. Tuberculin skin test among pulmonary sarcoidosis patients with and without tuberculosis: its utility for the screening of the two conditions in tuberculosis-endemic regions. Sarcoidosis Vasc Diffuse Lung Dis. Jun. 2006;23(2):130-4. Exclusion Code: X2. [pmid: 17937109].
228 Falagas ME, Voidonikola PT, Angelousi AG. Tuberculosis in patients with systemic rheumatic or pulmonary diseases treated with glucocorticosteroids and the preventive role of isoniazid: a review of the available evidence. Int J Antimicrob Agents. Dec. 2007;30(6):477-86. Exclusion Code: X2. [pmid: 17913470].
229 Markov M, Patel K, Raeesy A, et al. Liver and pancreatic injury induced by antituberculous therapy. Dig Dis Sci. Nov. 2007;52(11):3275-81. Exclusion Code: X7. [pmid: 17909976].
230 Chan-Yeung M, Dai DL, Cheung AH, et al. Tuberculin skin test reaction and body mass index in old age home residents in Hong Kong. J Am Geriatr Soc. Oct. 2007;55(10):1592-7. Exclusion Code: X4. [pmid: 17908061].
231 Kobashi Y, Obase Y, Fukuda M, et al. Usefulness of QuantiFERON TB-2G, a diagnostic method for latent tuberculosis infection, in a contact investigation of health care workers. Intern Med. 2007;46(18):1543-9. Exclusion Code: X2. [pmid: 17878640].
232 Levy MH, Butler TG, Zhou J. Prevalence of Mantoux positivity and annual risk of infection for tuberculosis in New South Wales prisoners, 1996 and 2001. N S W Public Health Bull. Jul-Aug. 2007;18(7-8):119-24. Exclusion Code: X3. [pmid: 17854540].
233 Mori T, Harada N, Higuchi K, et al. Waning of the specific interferon-gamma response after years of tuberculosis infection. Int J Tuberc Lung Dis. Sep. 2007;11(9):1021-5. Exclusion Code: X2. [pmid: 17705982].
234 Moran-Mendoza O, Marion SA, Elwood K, et al. Tuberculin skin test size and risk of tuberculosis development: a large population-based study in contacts. Int J Tuberc Lung Dis. Sep. 2007;11(9):1014-20. Exclusion Code: X2. [pmid: 17705981].
235 Passalent L, Khan K, Richardson R, et al. Detecting latent tuberculosis infection in hemodialysis patients: a head-to-head comparison of the T-SPOT.TB test, tuberculin skin test, and an expert physician panel. Clin J Am Soc Nephrol. Jan. 2007;2(1):68-73. Exclusion Code: X4. [pmid: 17699389].
236 Kobashi Y, Mouri K, Obase Y, et al. Clinical evaluation of QuantiFERON TB-2G test for immunocompromised patients. Eur Respir J. Nov. 2007;30(5):945-50. Exclusion Code: X2. [pmid: 17652312].
237 Matulis G, Juni P, Villiger PM, et al. Detection of latent tuberculosis in immunosuppressed patients with autoimmune diseases: performance of a Mycobacterium tuberculosis antigen-specific interferon gamma assay. Ann Rheum Dis. Jan. 2008;67(1):84-90. Exclusion Code: X2. [pmid: 17644549].
238 Igari H, Watanabe A, Sato T. Booster phenomenon of QuantiFERON-TB Gold after prior intradermal PPD injection. Int J Tuberc Lung Dis. Jul. 2007;11(7):788-91. Exclusion Code: X2. [pmid: 17609055].
239 Nienhaus A, Schablon A, Bacle CL, et al. Evaluation of the interferon-gamma release assay in healthcare workers. Int Arch Occup Environ Health. Jan. 2008;81(3):295-300. Exclusion Code: X2. [pmid: 17605033].
240 Pai M, O'Brien R. Serial testing for tuberculosis: can we make sense of T cell assay conversions and reversions?. PLoS Med. Jun. 2007;4(6):e208. Exclusion Code: X1. [pmid: 17564491].
241 Hill PC, Brookes RH, Fox A, et al. Longitudinal assessment of an ELISPOT test for Mycobacterium tuberculosis infection. PLoS Med. Jun. 2007;4(6):e192. Exclusion Code: X2. [pmid: 17564487].
242 Gomez LM, Sanchez E, Ruiz-Narvaez EA, et al. Macrophage migration inhibitory factor gene influences the risk of developing tuberculosis in northwestern Colombian population. Tissue Antigens. Jul. 2007;70(1):28-33. Exclusion Code: X5. [pmid: 17559578].
243 Wang JY, Chou CH, Lee LN, et al. Diagnosis of tuberculosis by an enzyme-linked immunospot assay for interferon-gamma. Emerg Infect Dis. Apr. 2007;13(4):553-8. Exclusion Code: X2. [pmid: 17553269].
244 Cho YJ, Lee SM, Yoo CG, et al. Clinical characteristics of tuberculosis in patients with liver cirrhosis. Respirology. May. 2007;12(3):401-5. Exclusion Code: X3. [pmid: 17539845].
245 Ozdemir D, Annakkaya AN, Tarhan G, et al. Comparison of the tuberculin skin test and the quantiferon test for latent Mycobacterium tuberculosis infections in health care workers in Turkey. Jpn J Infect Dis. May. 2007;60(2-3):102-5. Exclusion Code: X2. [pmid: 17515641].
246 Leyten EM, Arend SM, Prins C, et al. Discrepancy between Mycobacterium tuberculosis-specific gamma interferon release assays using short and prolonged in vitro incubation. Clin Vaccine Immunol. Jul. 2007;14(7):880-5. Exclusion Code: X2. [pmid: 17507543].
247 Kang YA, Lee HW, Hwang SS, et al. Usefulness of whole-blood interferon-gamma assay and interferon-gamma enzyme-linked immunospot assay in the diagnosis of active pulmonary tuberculosis. Chest. Sep. 2007;132(3):959-65. Exclusion Code: X9. [pmid: 17505029].
248 Tuuminen T, Sorva S, Liippo K, et al. Feasibility of commercial interferon-gamma-based methods for the diagnosis of latent Mycobacterium tuberculosis infection in Finland, a country of low incidence and high bacille Calmette-Guerin vaccination coverage. Clin Microbiol Infect. Aug. 2007;13(8):836-8. Exclusion Code: X2. [pmid: 17501976].
249 Porsa E, Cheng L, Graviss EA. Comparison of an ESAT-6/CFP-10 peptide-based enzyme-linked immunospot assay to a tuberculin skin test for screening of a population at moderate risk of contracting tuberculosis. Clin Vaccine Immunol. Jun. 2007;14(6):714-9. Exclusion Code: X2. [pmid: 17442844].
250 Gazetta CE, Ruffino-Netto A, Pinto Neto JM, et al. Investigation of tuberculosis contacts in the tuberculosis control program of a medium-sized municipality in the southeast of Brazil in 2002. J Bras Pneumol. Nov-Dec. 2006;32(6):559-65. Exclusion Code: X4. [pmid: 17435907].
251 Gustafson P, Lisse I, Gomes V, et al. Risk factors for positive tuberculin skin test in Guinea-Bissau. Epidemiology. May. 2007;18(3):340-7. Exclusion Code: X2. [pmid: 17435442].
252 Salles CG, Ruffino-Netto A, Lapa-e-Silva JR, et al. The presence of a booster phenomenon among contacts of active pulmonary tuberculosis cases: a retrospective cohort. BMC Public Health. 2007;7:38. Exclusion Code: X2. [pmid: 17371600].
253 Kwon YS, Koh WJ, Suh GY, et al. Hepatitis C virus infection and hepatotoxicity during antituberculosis chemotherapy. Chest. Mar. 2007;131(3):803-8. Exclusion Code: X2. [pmid: 17356096].
254 Franken WP, Timmermans JF, Prins C, et al. Comparison of Mantoux and QuantiFERON TB Gold tests for diagnosis of latent tuberculosis infection in Army personnel. Clin Vaccine Immunol. Apr. 2007;14(4):477-80. Exclusion Code: X9. [pmid: 17301213].
255 Jung SW, Jeon SW, Do BH, et al. Clinical aspects of rifampicin-associated pseudomembranous colitis. J Clin Gastroenterol. Jan. 2007;41(1):38-40. Exclusion Code: X2. [pmid: 17198063].
256 Gooding S, Chowdhury O, Hinks T, et al. Impact of a T cell-based blood test for tuberculosis infection on clinical decision-making in routine practice. J Infect. Mar. 2007;54(3):e169-74. Exclusion Code: X2. [pmid: 17188363].
257 Hill PC, Brookes RH, Fox A, et al. Surprisingly high specificity of the PPD skin test for M. tuberculosis infection from recent exposure in The Gambia. PLoS One. 2006;1:e68. Exclusion Code: X2. [pmid: 17183699].
258 Arend SM, Thijsen SF, Leyten EM, et al. Comparison of two interferon-gamma assays and tuberculin skin test for tracing tuberculosis contacts. Am J Respir Crit Care Med. Mar. 15. 2007;175(6):618-27. Exclusion Code: X2. [pmid: 17170386].
259 Choi CM, Kang CI, Kim DH, et al. The role of TST in the diagnosis of latent tuberculosis infection among military personnel in South Korea. Int J Tuberc Lung Dis. Dec. 2006;10(12):1342-6. Exclusion Code: X2. [pmid: 17167950].
260 Lardizabal A, Passannante M, Kojakali F, et al. Enhancement of treatment completion for latent tuberculosis infection with 4 months of rifampin. Chest. Dec. 2006;130(6):1712-7. Exclusion Code: X7. [pmid: 17166986].
261 Panickar JR, Hoskyns W. Treatment failure in tuberculosis. Eur Respir J. Mar. 2007;29(3):561-4. Exclusion Code: X2. [pmid: 17135229].
262 Page KR, Sifakis F, Montes de Oca R, et al. Improved adherence and less toxicity with rifampin vs isoniazid for treatment of latent tuberculosis: a retrospective study. Arch Intern Med. Sep. 25. 2006;166(17):1863-70. Exclusion Code: X7. [pmid: 17000943].
263 Huizinga TW, Arend SM. Is the tuberculin skin test an accurate method of detecting tuberculosis in patients with rheumatoid arthritis?. Nat Clin Pract Rheumatol. Apr. 2006;2(4):188-9. Exclusion Code: X1. [pmid: 16932683].
264 Tuberculin skin testing of close contacts: recent or long-standing infection?. Can Commun Dis Rep. Jun. 15. 2006;32(12):133-40. Exclusion Code: X2. [pmid: 16805063].
265 Cook PP, Maldonado RA, Yarnell CT, et al. Safety and completion rate of short-course therapy for treatment of latent tuberculosis infection. Clin Infect Dis. Aug. 1. 2006;43(3):271-5. Exclusion Code: X4. [pmid: 16804838].
266 Pai M, Joshi R, Dogra S, et al. Serial testing of health care workers for tuberculosis using interferon-gamma assay. Am J Respir Crit Care Med. Aug. 1. 2006;174(3):349-55. Exclusion Code: X2. [pmid: 16690977].
267 Gomez LM, Anaya JM, Martin J. Genetic influence of PTPN22 R620W polymorphism in tuberculosis. Hum Immunol. Dec. 2005;66(12):1242-7. Exclusion Code: X5. [pmid: 16690411].
268 Frenzel EC, Thomas GA, Hanna HA. The importance of two-step tuberculin skin testing for newly employed healthcare workers. Infect Control Hosp Epidemiol. May. 2006;27(5):512-4. Exclusion Code: X2. [pmid: 16671035].
269 Harada N, Nakajima Y, Higuchi K, et al. Screening for tuberculosis infection using whole-blood interferon-gamma and Mantoux testing among Japanese healthcare workers. Infect Control Hosp Epidemiol. May. 2006;27(5):442-8. Exclusion Code: X2. [pmid: 16671023].
270 Shah SS, McGowan JP, Klein RS, et al. Agreement between Mantoux skin testing and QuantiFERON-TB assay using dual mycobacterial antigens in current and former injection drug users. Med Sci Monit. Apr. 2006;12(4):Mt11-6. Exclusion Code: X2. [pmid: 16572060].
271 Loh LC, Chan SK, Ch'ng KI, et al. Influence of co-morbidity in the interpretation of tuberculin skin reactivity in multi-ethnic adult patients with tuberculosis. Med J Malaysia. Oct. 2005;60(4):426-31. Exclusion Code: X2. [pmid: 16570703].
272 Mahomed H, Hughes EJ, Hawkridge T, et al. Comparison of mantoux skin test with three generations of a whole blood IFN-gamma assay for tuberculosis infection. Int J Tuberc Lung Dis. Mar. 2006;10(3):310-6. Exclusion Code: X2. [pmid: 16562712].
273 Dewan PK, Grinsdale J, Liska S, et al. Feasibility, acceptability, and cost of tuberculosis testing by whole-blood interferon-gamma assay. BMC Infect Dis. 2006;6:47. Exclusion Code: X4. [pmid: 16539718].
274 Abrahao RM, Nogueira PA, Malucelli MI. Tuberculosis in county jail prisoners in the western sector of the city of Sao Paulo, brazil. Int J Tuberc Lung Dis. Feb. 2006;10(2):203-8. Exclusion Code: X5. [pmid: 16499262].
275 Jeffries DJ, Hill PC, Fox A, et al. Identifying ELISPOT and skin test cut-offs for diagnosis of Mycobacterium tuberculosis infection in The Gambia. Int J Tuberc Lung Dis. Feb. 2006;10(2):192-8. Exclusion Code: X2. [pmid: 16499260].
276 Schechter M, Zajdenverg R, Falco G, et al. Weekly rifapentine/isoniazid or daily rifampin/pyrazinamide for latent tuberculosis in household contacts. Am J Respir Crit Care Med. Apr. 15. 2006;173(8):922-6. Exclusion Code: X4. [pmid: 16474028].
277 Anlar FY, Kabasakal E, Karsi R. Tuberculosis and atopy: a study in an endemic area. Respir Med. Sep. 2006;100(9):1647-50. Exclusion Code: X3. [pmid: 16469489].
278 Menzies D, Dion MJ, Francis D, et al. In closely monitored patients, adherence in the first month predicts completion of therapy for latent tuberculosis infection. Int J Tuberc Lung Dis. Dec. 2005;9(12):1343-8. Exclusion Code: X5. [pmid: 16466056].
279 Roth VR, Garrett DO, Laserson KF, et al. A multicenter evaluation of tuberculin skin test positivity and conversion among health care workers in Brazilian hospitals. Int J Tuberc Lung Dis. Dec. 2005;9(12):1335-42. Exclusion Code: X5. [pmid: 16466055].
280 Jacono KM, O'Riordan MA, Furman L. Can we improve the return rate for tuberculin skin test readings?. Arch Pediatr Adolesc Med. Jan. 2006;160(1):106. Exclusion Code: X2. [pmid: 16389222].
281 Wilkinson KA, Kon OM, Newton SM, et al. Effect of treatment of latent tuberculosis infection on the T cell response to Mycobacterium tuberculosis antigens. J Infect Dis. Feb. 1. 2006;193(3):354-9. Exclusion Code: X5. [pmid: 16388482].
282 Schlesinger N, Lardizabal A, Rao J, et al. Tuberculosis of the spine: experience in an inner city hospital. J Clin Rheumatol. Feb. 2005;11(1):17-20. Exclusion Code: X7. [pmid: 16357692].
283 Codecasa LR, Ferrarese M, Penati V, et al. Comparison of tuberculin skin test and Quantiferon immunological assay for latent tuberculosis infection. Monaldi Arch Chest Dis. Sep. 2005;63(3):158-62. Exclusion Code: X2. [pmid: 16312206].
284 Jawahar MS, Rajaram K, Sivasubramanian S, et al. Treatment of lymph node tuberculosis--a randomized clinical trial of two 6-month regimens. Trop Med Int Health. Nov. 2005;10(11):1090-8. Exclusion Code: X2. [pmid: 16262733].
285 Radhakrishna S, Frieden TR, Subramani R, et al. Value of dual testing for identifying tuberculous infection. Tuberculosis (Edinb). Jan. 2006;86(1):47-53. Exclusion Code: X2. [pmid: 16256435].
286 White MC, Tulsky JP, Menendez E, et al. Incidence of TB in inmates with latent TB infection: 5-year follow-up. Am J Prev Med. Nov. 2005;29(4):295-301. Exclusion Code: X3. [pmid: 16242592].
287 Eleftheriadis T, Tsiaga P, Antoniadi G, et al. The value of serum antilipoarabinomannan antibody detection in the diagnosis of latent tuberculosis in hemodialysis patients. Am J Kidney Dis. Oct. 2005;46(4):706-12. Exclusion Code: X2. [pmid: 16183426].
288 Richards B, Kozak R, Brassard P, et al. Tuberculosis surveillance among new immigrants in Montreal. Int J Tuberc Lung Dis. Aug. 2005;9(8):858-64. Exclusion Code: X5. [pmid: 16104631].
289 Kimura M, Comstock GW, Mori T. Comparison of erythema and induration as results of tuberculin tests. Int J Tuberc Lung Dis. Aug. 2005;9(8):853-7. Exclusion Code: X3. [pmid: 16104630].
290 Ponce de Leon D, Acevedo-Vasquez E, Sanchez-Torres A, et al. Attenuated response to purified protein derivative in patients with rheumatoid arthritis: study in a population with a high prevalence of tuberculosis. Ann Rheum Dis. Sep. 2005;64(9):1360-1. Exclusion Code: X6. [pmid: 16100342].
291 Fountain FF, Tolley E, Chrisman CR, et al. Isoniazid hepatotoxicity associated with treatment of latent tuberculosis infection: a 7-year evaluation from a public health tuberculosis clinic. Chest. Jul. 2005;128(1):116-23. Exclusion Code: X4. [pmid: 16002924].
292 Britton WJ, Gilbert GL, Wheatley J, et al. Sensitivity of human gamma interferon assay and tuberculin skin testing for detecting infection with Mycobacterium tuberculosis in patients with culture positive tuberculosis. Tuberculosis (Edinb). May. 2005;85(3):137-45. Exclusion Code: X2. [pmid: 15850752].
293 Lobato MN, Reves RR, Jasmer RM, et al. Adverse events and treatment completion for latent tuberculosis in jail inmates and homeless persons. Chest. Apr. 2005;127(4):1296-303. Exclusion Code: X3. [pmid: 15821208].
294 Dheda K, Udwadia ZF, Huggett JF, et al. Utility of the antigen-specific interferon-gamma assay for the management of tuberculosis. Curr Opin Pulm Med. May. 2005;11(3):195-202. Exclusion Code: X1. [pmid: 15818179].
295 Deniz O, Tozkoparan E, Yonem A, et al. Low parathormone levels and hypercalcaemia in patients with pulmonary tuberculosis: relation to radiological extent of disease and tuberculin skin test. Int J Tuberc Lung Dis. Mar. 2005;9(3):317-21. Exclusion Code: X5. [pmid: 15786897].
296 Tortajada C, Martinez-Lacasa J, Sanchez F, et al. Is the combination of pyrazinamide plus rifampicin safe for treating latent tuberculosis infection in persons not infected by the human immunodeficiency virus?. Int J Tuberc Lung Dis. Mar. 2005;9(3):276-81. Exclusion Code: X4. [pmid: 15786890].
297 Priest DH, Vossel LF Jr., Sherfy EA, et al. Use of intermittent rifampin and pyrazinamide therapy for latent tuberculosis infection in a targeted tuberculin testing program. Clin Infect Dis. Dec. 15. 2004;39(12):1764-71. Exclusion Code: X3. [pmid: 15578397].
298 van Hest R, Baars H, Kik S, et al. Hepatotoxicity of rifampin-pyrazinamide and isoniazid preventive therapy and tuberculosis treatment. Clin Infect Dis. Aug. 15. 2004;39(4):488-96. Exclusion Code: X4. [pmid: 15356811].
299 Wauters A, Peetermans WE, Van den Brande P, et al. The value of tuberculin skin testing in haemodialysis patients. Nephrol Dial Transplant. Feb. 2004;19(2):433-8. Exclusion Code: X5. [pmid: 14736970].
300 Chau CH, Yew WW, Chan CK. Familial clustering of rifampin-induced acute renal failure. Int J Tuberc Lung Dis. Dec. 2003;7(12):1210. Exclusion Code: X5. [pmid: 14677899].
301 Leung CC, Law WS, Chang KC, et al. Initial experience on rifampin and pyrazinamide vs isoniazid in the treatment of latent tuberculosis infection among patients with silicosis in Hong Kong. Chest. Dec. 2003;124(6):2112-8. Exclusion Code: X4. [pmid: 14665488].
302 Al-Moamary MS, Al-Baz S, Alothman A, et al. Does tuberculin skin test predict tuberculosis in patients with end-stage liver disease?. Saudi Med J. Nov. 2003;24(11):1269-70. Exclusion Code: X3. [pmid: 14647571].
303 Mitchison DA. Role of isoniazid in once-weekly rifapentine treatment of pulmonary tuberculosis. Am J Respir Crit Care Med. May. 15. 2003;167(10):1298-9. Exclusion Code: X1. [pmid: 12738593].
304 Bugiani M, Borraccino A, Migliore E, et al. Tuberculin reactivity in adult BCG-vaccinated subjects: a cross-sectional study. Int J Tuberc Lung Dis. Apr. 2003;7(4):320-6. Exclusion Code: X2. [pmid: 12729336].
305 McNeill L, Allen M, Estrada C, et al. Pyrazinamide and rifampin vs isoniazid for the treatment of latent tuberculosis: improved completion rates but more hepatotoxicity. Chest. Jan. 2003;123(1):102-6. Exclusion Code: X4. [pmid: 12527609].
306 Lee AM, Mennone JZ, Jones RC, et al. Risk factors for hepatotoxicity associated with rifampin and pyrazinamide for the treatment of latent tuberculosis infection: experience from three public health tuberculosis clinics. Int J Tuberc Lung Dis. Nov. 2002;6(11):995-1000. Exclusion Code: X4. [pmid: 12475146].
307 Benito N, Sued O, Moreno A, et al. Diagnosis and treatment of latent tuberculosis infection in liver transplant recipients in an endemic area. Transplantation. Nov. 27. 2002;74(10):1381-6. Exclusion Code: X3. [pmid: 12451235].
308 Stout JE, Engemann JJ, Cheng AC, et al. Safety of 2 months of rifampin and pyrazinamide for treatment of latent tuberculosis. Am J Respir Crit Care Med. Mar. 15. 2003;167(6):824-7. Exclusion Code: X3. [pmid: 12446275].
309 Howard AA, Klein RS, Schoenbaum EE, et al. Crack cocaine use and other risk factors for tuberculin positivity in drug users. Clin Infect Dis. Nov. 15. 2002;35(10):1183-90. Exclusion Code: X5. [pmid: 12410478].
310 Quaglio G, Lugoboni F, Talamini G, et al. Prevalence of tuberculosis infection and comparison of multiple-puncture liquid tuberculin test and Mantoux test among drug users. Scand J Infect Dis. 2002;34(8):574-6. Exclusion Code: X2. [pmid: 12238571].
311 Panlilio AL, Burwen DR, Curtis AB, et al. Tuberculin skin testing surveillance of health care personnel. Clin Infect Dis. Aug. 1. 2002;35(3):219-27. Exclusion Code: X2. [pmid: 12115085].
312 Batki SL, Gruber VA, Bradley JM, et al. A controlled trial of methadone treatment combined with directly observed isoniazid for tuberculosis prevention in injection drug users. Drug Alcohol Depend. May. 1. 2002;66(3):283-93. Exclusion Code: X3. [pmid: 12062463].
313 Bock NN, Sterling TR, Hamilton CD, et al. A prospective, randomized, double-blind study of the tolerability of rifapentine 600, 900, and 1,200 mg plus isoniazid in the continuation phase of tuberculosis treatment. Am J Respir Crit Care Med. Jun. 1. 2002;165(11):1526-30. Exclusion Code: X2. [pmid: 12045127].
314 Noertjojo K, Tam CM, Chan SL, et al. Contact examination for tuberculosis in Hong Kong is useful. Int J Tuberc Lung Dis. Jan. 2002;6(1):19-24. Exclusion Code: X5. [pmid: 11931396].
315 Steinmann RA, Rickel MK. A 23-year-old with refractory seizures following an isoniazid overdose. J Emerg Nurs. Feb. 2002;28(1):7-10. Exclusion Code: X7. [pmid: 11830727].
316 Rangel-Frausto MS, Ponce-De-Leon-Rosales S, Martinez-Abaroa C, et al. Tuberculosis and tuberculin quality: best intentions, misleading results. Infect Control Hosp Epidemiol. Aug. 2001;22(8):481-4. Exclusion Code: X3. [pmid: 11700874].
317 Plitt SS, Soskolne CL, Fanning EA, et al. Prevalence and determinants of tuberculin reactivity among physicians in Edmonton, Canada: 1996-1997. Int J Epidemiol. Oct. 2001;30(5):1022-8. Exclusion Code: X2. [pmid: 11689515].
318 Saigal S, Agarwal SR, Nandeesh HP, et al. Safety of an ofloxacin-based antitubercular regimen for the treatment of tuberculosis in patients with underlying chronic liver disease: a preliminary report. J Gastroenterol Hepatol. Sep. 2001;16(9):1028-32. Exclusion Code: X2. [pmid: 11595068].
319 Al Zahrani K, Al Jahdali H, Poirier L, et al. Yield of smear, culture and amplification tests from repeated sputum induction for the diagnosis of pulmonary tuberculosis. Int J Tuberc Lung Dis. Sep. 2001;5(9):855-60. Exclusion Code: X5. [pmid: 11573898].
320 Kanaya AM, Glidden DV, Chambers HF. Identifying pulmonary tuberculosis in patients with negative sputum smear results. Chest. Aug. 2001;120(2):349-55. Exclusion Code: X2. [pmid: 11502628].
321 Klein RS, Gourevitch MN, Teeter R, et al. The incidence of tuberculosis in drug users with small tuberculin reaction sizes. Int J Tuberc Lung Dis. Aug. 2001;5(8):707-11. Exclusion Code: X2. [pmid: 11495260].
322 Moreno S, Blazquez R, Novoa A, et al. The effect of BCG vaccination on tuberculin reactivity and the booster effect among hospital employees. Arch Intern Med. Jul. 23. 2001;161(14):1760-5. Exclusion Code: X4. [pmid: 11485509].
323 Fine PE, Floyd S, Stanford JL, et al. Environmental mycobacteria in northern Malawi: implications for the epidemiology of tuberculosis and leprosy. Epidemiol Infect. Jun. 2001;126(3):379-87. Exclusion Code: X2. [pmid: 11467795].
324 Lalvani A, Pathan AA, Durkan H, et al. Enhanced contact tracing and spatial tracking of Mycobacterium tuberculosis infection by enumeration of antigen-specific T cells. Lancet. Jun. 23. 2001;357(9273):2017-21. Exclusion Code: X3. [pmid: 11438135].
325 Datta M, Radhamani MP, Sadacharam K, et al. Survey for tuberculosis in a tribal population in North Arcot District. Int J Tuberc Lung Dis. Mar. 2001;5(3):240-9. Exclusion Code: X5. [pmid: 11326823].
326 Taskapan H, Oymak O, Utas C. Tuberculin and anergy testing in CAPD patients. Perit Dial Int. Nov-Dec. 2000;20(6):807-9. Exclusion Code: X2. [pmid: 11216589].
327 El-Sadr WM, Perlman DC, Denning E, et al. A review of efficacy studies of 6-month short-course therapy for tuberculosis among patients infected with human immunodeficiency virus: differences in study outcomes. Clin Infect Dis. Feb. 15. 2001;32(4):623-32. Exclusion Code: X2. [pmid: 11181127].
328 Sherman RA, Shimoda KJ. Tuberculosis tracking: determining the frequency of the booster effect in patients and staff. Am J Infect Control. Feb. 2001;29(1):7-12. Exclusion Code: X2. [pmid: 11172312].
329 Memish ZA, Mah MW, Mahmood SA, et al. Clinico-diagnostic experience with tuberculous lymphadenitis in Saudi Arabia. Clin Microbiol Infect. Mar. 2000;6(3):137-41. Exclusion Code: X9. [pmid: 11168089].
330 Raut VS, Mahashur AA, Sheth SS. The Mantoux test in the diagnosis of genital tuberculosis in women. Int J Gynaecol Obstet. Feb. 2001;72(2):165-9. Exclusion Code: X2. [pmid: 11166750].
331 Roselle GA, Danko LH, Kralovic SM, et al. Tuberculosis in the veterans healthcare system: a six-year review and evaluation of programme effectiveness. Epidemiol Infect. Oct. 2000;125(2):315-23. Exclusion Code: X7. [pmid: 11117955].
332 Uyan AP, Baskin E, Buyukbese E, et al. Evaluating Bacillus-Calmette-Guerin vaccination by tuberculin skin test response. Indian Pediatr. Oct. 2000;37(10):1106-10. Exclusion Code: X2. [pmid: 11042711].
333 Boggess KA, Myers ER, Hamilton CD. Antepartum or postpartum isoniazid treatment of latent tuberculosis infection. Obstet Gynecol. Nov. 2000;96(5 Pt 1):757-62. Exclusion Code: X7. [pmid: 11042314].
334 Ramasamy R, Reginald A, Ganesan E. The use of high-dose isomazid in intermittent regime TB treatment--some preliminary findings. Trop Doct. Jan. 2000;30(1):56. Exclusion Code: X3. [pmid: 10842542].
335 Stuart RL, Wilson J, Grayson ML. Isoniazid toxicity in health care workers. Clin Infect Dis. Apr. 1999;28(4):895-7. Exclusion Code: X4. [pmid: 10825056].
336 Tam CM, Chan SL, Kam KM, et al. Rifapentine and isoniazid in the continuation phase of a 6-month regimen. Interim report: no activity of isoniazid in the continuation phase. Int J Tuberc Lung Dis. Mar. 2000;4(3):262-7. Exclusion Code: X4. [pmid: 10751074].
337 Rasolofo V, Rasolonavalona T, Ramarokoto H, et al. Predictive values of the ICT Tuberculosis test for the routine diagnosis of tuberculosis in Madagascar. Int J Tuberc Lung Dis. Feb. 2000;4(2):184-5. Exclusion Code: X3. [pmid: 10694099].
338 Streeton JA, Desem N, Jones SL. Sensitivity and specificity of a gamma interferon blood test for tuberculosis infection. Int J Tuberc Lung Dis. Jun. 1998;2(6):443-50. Exclusion Code: X3. [pmid: 9626600].
339 Kendig EL Jr., Kirkpatrick BV, Carter WH, et al. Underreading of the tuberculin skin test reaction. Chest. May. 1998;113(5):1175-7. Exclusion Code: X5. [pmid: 9596290].
340 Sonmez E, Yakinci C, Aladag M, et al. Diagnosis of tuberculosis: PPD or BCG test. J Trop Pediatr. Feb. 1998;44(1):40-2. Exclusion Code: X3. [pmid: 9538605].
341 McCurdy SA, Arretz DS, Bates RO. Tuberculin reactivity among California Hispanic migrant farm workers. Am J Ind Med. Dec. 1997;32(6):600-5. Exclusion Code: X5. [pmid: 9358916].
342 Duchin JS, Jereb JA, Nolan CM, et al. Comparison of sensitivities to two commercially available tuberculin skin test reagents in persons with recent tuberculosis. Clin Infect Dis. Sep. 1997;25(3):661-3. Exclusion Code: X2. [pmid: 9314456].
343 Wells CD, Zuber PL, Nolan CM, et al. Tuberculosis prevention among foreign-born persons in Seattle--King County, Washington. Am J Respir Crit Care Med. Aug. 1997;156(2 Pt 1):573-7. Exclusion Code: X4. [pmid: 9279242].
344 Woeltje KF, Kilo CM, Johnson K, et al. Tuberculin skin testing of hospitalized patients. Infect Control Hosp Epidemiol. Aug. 1997;18(8):561-5. Exclusion Code: X2. [pmid: 9276237].
345 Thomas RE. Mantoux (tuberculosis) testing. Evaluation of guidelines for testing in Canadian institutions. Can Fam Physician. May. 1997;43:933-8. Exclusion Code: X1. [pmid: 9154365].
346 Lifson AR, Grant SM, Lorvick J, et al. Two-step tuberculin skin testing of injection drug users recruited from community-based settings. Int J Tuberc Lung Dis. Apr. 1997;1(2):128-34. Exclusion Code: X2. [pmid: 9441076].
347 Sorresso DJ, Mehta JB, Harvill LM, et al. Underutilization of isoniazid chemoprophylaxis in tuberculosis contacts 50 years of age and older. A prospective analysis. Chest. Sep. 1995;108(3):706-11. Exclusion Code: X4. [pmid: 7656620].
348 Cieslak TJ, Irwin RG, Dougherty PA, et al. A pseudoepidemic of tuberculin skin test conversions caused by a particular lot of purified protein derivative of tuberculin test solution. Pediatr Infect Dis J. May. 1995;14(5):392-3. Exclusion Code: X2. [pmid: 7638016].
349 John GT, Thomas PP, Thomas M, et al. A double-blind randomized controlled trial of primary isoniazid prophylaxis in dialysis and transplant patients. Transplantation. Jun. 15. 1994;57(11):1683-4. Exclusion Code: X6. [pmid: 8009608].
350 Bellin E, Fletcher D, Safyer S. Abnormal chest x-rays in intravenous drug users: implications for tuberculosis screening programs. Am J Public Health. May. 1993;83(5):698-700. Exclusion Code: X4. [pmid: 8387246].
351 Farmakis M, Travlou O, Aroni S, et al. Fibrinogen and antithrombin III blood levels fluctuations during isoniazid or isoniazid plus rifampicin administration. Arzneimittelforschung. Aug. 1992;42(8):1041-4. Exclusion Code: X5. [pmid: 1418078].
352 Graham NM, Nelson KE, Solomon L, et al. Prevalence of tuberculin positivity and skin test anergy in HIV-1-seropositive and -seronegative intravenous drug users. Jama. Jan. 15. 1992;267(3):369-73. Exclusion Code: X2. [pmid: 1727959].
353 Lee KC, Tami TA, Lalwani AK, et al. Contemporary management of cervical tuberculosis. Laryngoscope. Jan. 1992;102(1):60-4. Exclusion Code: X3. [pmid: 1731159].
354 Martin-Casabona N, Ocana Rivera I, Vidal Pla R, et al. Diagnosis of mycobacterial infection in acquired immunodeficiency syndrome (AIDS) patients and HIV carriers. J Hyg Epidemiol Microbiol Immunol. 1992;36(3):293-302. Exclusion Code: X2. [pmid: 1293212].
355 Gordin FM, Perez-Stable EJ, Reid M, et al. Stability of positive tuberculin tests: are boosted reactions valid?. Am Rev Respir Dis. Sep. 1991;144(3 Pt 1):560-3. Exclusion Code: X5. [pmid: 1892295].
356 Havlir DV, van der Kuyp F, Duffy E, et al. A 19-year follow-up of tuberculin reactors. Assessment of skin test reactivity and in vitro lymphocyte responses. Chest. May. 1991;99(5):1172-6. Exclusion Code: X4. [pmid: 2019174].
357 Lau SK, Wei WI, Kwan S, et al. Combined use of fine-needle aspiration cytologic examination and tuberculin skin test in the diagnosis of cervical tuberculous lymphadenitis. A prospective study. Arch Otolaryngol Head Neck Surg. Jan. 1991;117(1):87-90. Exclusion Code: X3. [pmid: 1986768].
358 Theuer CP, Hopewell PC, Elias D, et al. Human immunodeficiency virus infection in tuberculosis patients. J Infect Dis. Jul. 1990;162(1):8-12. Exclusion Code: X5. [pmid: 1972384].
359 De March-Ayuela P. Choosing an appropriate criterion for true or false conversion in serial tuberculin testing. Am Rev Respir Dis. Apr. 1990;141(4 Pt 1):815-20. Exclusion Code: X5. [pmid: 2327645].
360 Aziz S, Alam SE. Criteria for diagnosis in pulmonary tuberculosis. J Pak Med Assoc. Jan. 1990;40(1):14-6. Exclusion Code: X5. [pmid: 2109125].
361 Dutt AK, Moers D, Stead WW. Smear- and culture-negative pulmonary tuberculosis: four-month short-course chemotherapy. Am Rev Respir Dis. Apr. 1989;139(4):867-70. Exclusion Code: X2. [pmid: 2930066].
362 Franks AL, Binkin NJ, Snider DE Jr., et al. Isoniazid hepatitis among pregnant and postpartum Hispanic patients. Public Health Rep. Mar-Apr. 1989;104(2):151-5. Exclusion Code: X4. [pmid: 2495549].
363 Onwubalili JK, Scott GM. Immune status in tuberculosis and response to treatment. Tubercle. Jun. 1988;69(2):81-94. Exclusion Code: X3. [pmid: 3188236].
364 Biggs B, Connor H, Dwyer BW, et al. Comparison of a multiple puncture tuberculin test, 'Imotest', and the Mantoux test in an Australian population. Tubercle. Dec. 1987;68(4):285-90. Exclusion Code: X3. [pmid: 3455568].
365 Stanford CF, Bell A. Rifampicin does not suppress the tuberculin reaction in man. Eur J Respir Dis. Nov. 1987;71(5):339-40. Exclusion Code: X5. [pmid: 3443155].
366 Aitken ML, Anderson KM, Albert RK. Is the tuberculosis screening program of hospital employees still required?. Am Rev Respir Dis. Oct. 1987;136(4):805-7. Exclusion Code: X4. [pmid: 3116895].
367 Dorken E, Grzybowski S, Allen EA. Significance of the tuberculin test in the elderly. Chest. Aug. 1987;92(2):237-40. Exclusion Code: X5. [pmid: 3111795].
368 Pitchenik AE, Burr J, Suarez M, et al. Human T-cell lymphotropic virus-III (HTLV-III) seropositivity and related disease among 71 consecutive patients in whom tuberculosis was diagnosed. A prospective study. Am Rev Respir Dis. Apr. 1987;135(4):875-9. Exclusion Code: X2. [pmid: 3645999].
369 Cowie RL, Langton ME, Escreet BC. Diagnosis of sputum smear- and sputum culture-negative pulmonary tuberculosis. S Afr Med J. Dec. 7. 1985;68(12):878. Exclusion Code: X6. [pmid: 3934771].
370 van Assendelft AH. Leucopenia in rifampicin chemotherapy. J Antimicrob Chemother. Sep. 1985;16(3):407-8. Exclusion Code: X3. [pmid: 4055546].
371 Welty C, Burstin S, Muspratt S, et al. Epidemiology of tuberculous infection in a chronic care population. Am Rev Respir Dis. Jul. 1985;132(1):133-6. Exclusion Code: X4. [pmid: 4014857].
372 Mukerjee CM, McKenzie DK. Safety of thrice-weekly rifampicin for tuberculosis in South-East Asian refugees. Aust N Z J Med. Apr. 1985;15(2):226-9. Exclusion Code: X3. [pmid: 3861165].
373 Dorken E, Grzybowski S, Enarson DA. Ten year evaluation of a trial of chemoprophylaxis against tuberculosis in Frobisher Bay, Canada. Tubercle. Jun. 1984;65(2):93-9. Exclusion Code: X3. [pmid: 6380067].
374 Isoniazid prevention of tuberculosis. Lancet. Feb. 19. 1983;1(8321):395-6. Exclusion Code: X1. [pmid: 6130384].
375 Rudd RM, Gellert AR, Venning M. Comparison of Mantoux, tine, and 'Imotest' tuberculin tests. Lancet. Sep. 4. 1982;2(8297):515-8. Exclusion Code: X3. [pmid: 6125678].
376 Ellard GA, Girling DJ, Nunn AJ. The hepatotoxicity of isoniazid among the three acetylator phenotypes. Am Rev Respir Dis. May. 1981;123(5):568-70. Exclusion Code: X3. [pmid: 7235381].
377 Dash LA, Comstock GW, Flynn JP. Isoniazid preventive therapy: Retrospect and prospect. Am Rev Respir Dis. Jun. 1980;121(6):1039-44. Exclusion Code: X4. [pmid: 7416591].
378 Costello HD, Snider DE Jr. The incidence of cancer among participants in controlled, randomized isoniazid preventive therapy trial. Am J Epidemiol. Jan. 1980;111(1):67-74. Exclusion Code: X6. [pmid: 6986082].
379 Howe GR, Lindsay J, Coppock E, et al. Isoniazid exposure in relation to cancer incidence and mortality in a cohort of tuberculosis patients. Int J Epidemiol. Dec. 1979;8(4):305-12. Exclusion Code: X3. [pmid: 541154].
380 Falk A, Fuchs GF. Prophylaxis with isoniazid in inactive tuberculosis. A Veterans Administration Cooperative Study XII. Chest. Jan. 1978;73(1):44-8. Exclusion Code: X3. [pmid: 340155].
381 Glassroth JL, White MC, Snider DE Jr. An assessment of the possible association of isoniazid with human cancer deaths. Am Rev Respir Dis. Dec. 1977;116(6):1065-74. Exclusion Code: X2. [pmid: 337865].
382 Controlled trial of intermittent regimens of rifampin plus isoniazid for pulmonary tuberculosis in Singapore. The results up to 30 months. Am Rev Respir Dis. Nov. 1977;116(5):807-20. Exclusion Code: X3. [pmid: 411405].
383 Byrd RB, Horn BR, Griggs GA, et al. Isoniazid chemoprophylaxis. Association with detection and incidence of liver toxicity. Arch Intern Med. Sep. 1977;137(9):1130-3. Exclusion Code: X3. [pmid: 332099].
384 Atuk NO, Hart AD, Hunt EH. Close monitoring is essential during isoniazid prophylaxis. South Med J. Feb. 1977;70(2):156-9. Exclusion Code: X4. [pmid: 841390].
385 Grzybowski S, Ashley MJ, Pinkus G. Chemoprophylaxis in inactive tuberculosis: long-term evaluation of a Canadian trial. Can Med Assoc J. Apr. 3. 1976;114(7):607-11. Exclusion Code: X7. [pmid: 816447].
386 Dubra FA. Short course treatment with two drugs, isoniazid plus rifampicin for six months: a controlled clinical trial with two treatment regimens. Bull Int Union Tuberc. 1976;51(1):61-4. Exclusion Code: X3. [pmid: 1030314].
387 Falk A, Fuchs G. Isoniazid (INH) prophylaxis in inactive pulmonary tuberculosis: report of a Veterans Administration Cooperative Study. Bull Int Union Tuberc. 1976;51(1):219-23. Exclusion Code: X3. [pmid: 1030286].
388 Eule H, Iwainsky H, Kaernbach E, et al. Intermittent treatment using isoniazid and rifampicin once a week: final results of a controlled trial. Bull Int Union Tuberc. 1976;51(1):115-9. Exclusion Code: X3. [pmid: 1030270].
389 Krebs A. The IUAT trial on isoniazid preventive treatment in persons with fibrotic lung lesions. Bull Int Union Tuberc. 1976;51(1):193-201. Exclusion Code: X1. [pmid: 801115].
390 Furcolow ML. Tuberculosis case finding by tuberculin testing a complete population, with follow-up. Chest. Sep. 1975;68(3 Suppl):443-5. Exclusion Code: X3. [pmid: 1157559].
391 Somner AR. Proceedings: Short course chemotherapy in pulmonary tuberculosis: a controlled trial by the British Thoracic and Tuberculosis Association. (A report from one of the three clinical co-ordinators). Tubercle. Jun. 1975;56(2):165. Exclusion Code: X2. [pmid: 1103397].
392 Lewis JE, Mello P, Knauer CM. Isoniazid-associated hepatitis--serum enzyme determinations and histologic features. West J Med. May. 1975;122(5):371-6. Exclusion Code: X4. [pmid: 1130028].
393 A controlled clinical trial of small daily doses of rifampicin in the prevention of adverse reactions to the drug in a once-weekly regimen of chemotherapy in Hong Kong: second report:-the results at 12 months. Tubercle. Sep. 1974;55(3):193-210. Exclusion Code: X2. [pmid: 4620298].
394 Bailey WC, Weill H, DeRouen TA, et al. The effect of isoniazid on transaminase levels. Ann Intern Med. Aug. 1974;81(2):200-2. Exclusion Code: X3. [pmid: 4843577].
395 Comstock GW, Woolpert SF, Baum C. Isoniazid prophylaxis among Alaskan Eskimos: a progress report. Am Rev Respir Dis. Aug. 1974;110(2):195-7. Exclusion Code: X3. [pmid: 4414015].
396 Horwitz O. Long-range evaluation of a mass screening program. Am J Epidemiol. Jul. 1974;100(1):20-8. Exclusion Code: X2. [pmid: 4841817].
397 Horwitz O, Magnus K. Epidemiologic evaluation of chemoprophylaxis against tuberculosis. Am J Epidemiol. May. 1974;99(5):333-42. Exclusion Code: X3. [pmid: 4596645].
398 Erdtmann FJ, Dixon KE, Llewellyn CH. Skin testing for tuberculosis. Antigen and observer variability. Jama. Apr. 22. 1974;228(4):479-81. Exclusion Code: X2. [pmid: 4594690].
399 A Hong Kong Tuberculosis Treatment Services/Brompton Hospital/British Medical Research Council Investigation. Tubercle. Mar. 1974;55(1):1-27. Exclusion Code: X2. [pmid: 4620294].
400 Ludford J, Doster B, Woolpert SF. Effect of isoniazid on reproduction. Am Rev Respir Dis. Nov. 1973;108(5):1170-4. Exclusion Code: X3. [pmid: 4583539].
401 Ville de Goyet C, Kleeberg HH. Tuberculin testing by multiple puncture and by intradermal injection. S Afr Med J. Sep. 15. 1973;47(36):1648-52. Exclusion Code: X2. [pmid: 4795768].
402 Bethlem N, Gerhardt FG, Magarao S. Comparison of two regimens of simplified two-stage chemotherapy in previously untreated pulmonary tuberculosis. Tubercle. Sep. 1973;54(3):180-4. Exclusion Code: X2. [pmid: 4204111].
403 Stead WW, Jurgens GH. Productivity of prolonged follow-up after chemotherapy for tuberculosis. Am Rev Respir Dis. Aug. 1973;108(2):314-20. Exclusion Code: X2. [pmid: 4198349].
404 Cramer PG. Tuberculosis: why our concepts have changed. Mich Med. Jul. 1973;72(21):473-4. Exclusion Code: X7. [pmid: 4732674].
405 Maddrey WC, Boitnott JK. Isoniazid hepatitis. Ann Intern Med. Jul. 1973;79(1):1-12. Exclusion Code: X7. [pmid: 4721174].
406 Horwitz O, Edwards PQ, Lowell AM. National tuberculosis control program in Denmark and the United States. Health Serv Rep. Jun-Jul. 1973;88(6):493-8. Exclusion Code: X1. [pmid: 4715710].
407 B.C.G. tested. Br Med J. Feb. 24. 1973;1(5851):435. Exclusion Code: X1. [pmid: 4734730].
408 Furcolow ML, Deuschle KW. Modern tuberculosis control. A six-year follow-up in an Appalacian community. Am Rev Respir Dis. Feb. 1973;107(2):253-66. Exclusion Code: X2. [pmid: 4539600].
409 Ville de Goyet CD. The intradermal tuberculin test as a research tool. Its planning, execution, analysis and interpretation. S Afr Med J. Jan. 27. 1973;47(4):142-5. Exclusion Code: X1. [pmid: 4595134].
410 Hudson LD, Sbarbaro JA. Twice weekly tuberculosis chemotherapy. Jama. Jan. 8. 1973;223(2):139-43. Exclusion Code: X3. [pmid: 4347487].
411 Nitti V. Controlled clinical evaluation of three intermittent regimens employing low-dosage schedules of rifampicin in original treatment of pulmonary tuberculosis. Preliminary data on effectiveness and side effects. Scand J Respir Dis Suppl. 1973;84:180-5. Exclusion Code: X2. [pmid: 4593266].
412 Eule H, Karnbach E, Kaluza P, et al. Preliminary results of a controlled therapeutic trail administering INH-RMP once-weekly, after--or without--an initial period of continuous treatment. Scand J Respir Dis Suppl. 1973;84:153-9. Exclusion Code: X2. [pmid: 4593264].
413 Gomi J, Aoyagi T. Therapeutic effects and side effects of rifampicin administered daily or twice-weekly. Scand J Respir Dis Suppl. 1973;84:145-52. Exclusion Code: X2. [pmid: 4522070].
414 Mattson K. Side effects of rifampicin. A clinical study. Scand J Respir Dis Suppl. 1973;82:1-52. Exclusion Code: X2. [pmid: 4518740].
415 Debre R, Perdrizet S, Lotte A, et al. Isoniazid chemoprophylaxis of latent primary tuberculosis: in five trial centres in France from 1959 to 1969. Int J Epidemiol. Summer. 1973;2(2):153-60. Exclusion Code: X7. [pmid: 4204799].
416 Proust A, Evans C. The Australian rifampicin trial. Med J Aust. Oct. 14. 1972;2(16):861-7. Exclusion Code: X2. [pmid: 4647286].
417 Schachter EN. Tuberculin negative tuberculosis. Am Rev Respir Dis. Oct. 1972;106(4):587-93. Exclusion Code: X2. [pmid: 4627830].
418 Byrd CB, Nelson R, Elliott RC. Isoniazid toxicity. A prospective study in secondary chemoprophylaxis. Jama. Jun. 12. 1972;220(11):1471-3. Exclusion Code: X3. [pmid: 5067581].
419 Nitti V. Antituberculosis activity of rifampin. Report of studies performed and in progress (1966-1971). Chest. Jun. 1972;61(6):589-98. Exclusion Code: X7. [pmid: 4624281].
420 Verbist L, Mbete S, Van Landuyt H, et al. Intermittent therapy with rifampin once a week in advanced pulmonary tuberculosis. Chest. Jun. 1972;61(6):555-63. Exclusion Code: X2. [pmid: 4624278].
421 Controlled clinical trial of short-course (6-month) regimens of chemotherapy for treatment of pulmonary tuberculosis. Lancet. May. 20. 1972;1(7760):1079-85. Exclusion Code: X2. [pmid: 4112569].
422 Narain R, Naganna K, Lal P. Nonspecific sensitivity and its influence on incidence of pulmonary tuberculosis. Am Rev Respir Dis. Apr. 1972;105(4):578-85. Exclusion Code: X3. [pmid: 5017881].
423 Doto EL, Furcolow ML, MacInnis FE. Size of the tuberculin reaction. Relationship to subsequent development of tuberculosis in Kansas-Missouri area. Arch Environ Health. Nov. 1971;23(5):392-6. Exclusion Code: X4. [pmid: 5133801].
424 Devine CM, Tall R, Nunn AJ, et al. Computer-aided procedures in a multi-centre co-operative controlled clinical trial in pulmonary tuberculosis. Tubercle. Sep. 1971;52(3):199-218. Exclusion Code: X3. [pmid: 4938217].
425 Polascik M, Golden B. Rifampicin. Ann Ophthalmol. Aug. 1971;3(8):877-82. Exclusion Code: X1. [pmid: 5005929].
426 Chusid EL, Shah R, Siltzbach LE. Tuberculin tests during the course of sarcoidosis in 350 patients. Am Rev Respir Dis. Jul. 1971;104(1):13-21. Exclusion Code: X2. [pmid: 5556229].
427 Moulding T. Chemoprophylaxis of tuberculosis: when is the benefit worth the risk and cost?. Ann Intern Med. May. 1971;74(5):761-70. Exclusion Code: X7. [pmid: 5314806].
428 Citron KM, De Silva DJ. The results of tuberculosis chemotherapy in chest clinic practice. Tubercle. Mar. 1971;52(1):31-6. Exclusion Code: X2. [pmid: 5560200].
429 Flemming J, Virchow C. Late results following rifampicin therapy and tolerance of rifampicin given on a long-term basis. Respiration. Suppl. 1971;28:107-15. Exclusion Code: X4. [pmid: 5150790].
430 Trendelenburg F. Controlled clinical research on the therapeutic effect of rifampicin. Respiration. Suppl. 1971;28:123-9. Exclusion Code: X5. [pmid: 4948627].
431 Reid LR. Twenty-seven months of chemoprophylaxis for prevention of tuberculosis in Mississippi. J Miss State Med Assoc. Sep. 1970;11(9):485-92. Exclusion Code: X7. [pmid: 5457043].
432 Comstock GW, Ferebee SH. How much isoniazid is needed for prophylaxis?. Am Rev Respir Dis. May. 1970;101(5):780-2. Exclusion Code: X3. [pmid: 4910642].
433 Narain R, Bagga AS, Naganna K, et al. Influence of isoniazid on naturally acquired tuberculin allergy and on induction of allergy by BCG vaccination. Bull World Health Organ. 1970;43(1):53-64. Exclusion Code: X3. [pmid: 5312322].
434 A controlled comparison of a twice-weekly and three once-weekly regimens in the initial treatment of pulmonary tuberculosis. Bull World Health Organ. 1970;43(1):143-206. Exclusion Code: X2. [pmid: 5312317].
435 Horwitz O. The risk of tuberculosis in different groups of the general population. Scand J Respir Dis Suppl. 1970;72:59-60. Exclusion Code: X1. [pmid: 5273220].
436 Comstock GW, Hammes LM, Pio A. Isoniazid prophylaxis in Alaskan Boarding schools. A comparison of two doses. Am Rev Respir Dis. Dec. 1969;100(6):773-9. Exclusion Code: X2. [pmid: 5353852].
437 Grzybowski S, Ashley MJ, McKinnon NE, et al. In Canada: a trial of chemoprophylaxis in inactive tuberculosis. Can Med Assoc J. Nov. 1. 1969;101(9):81-6. Exclusion Code: X7. [pmid: 5348494].
438 Schlaegel TF Jr., Weber JC. Double-blind therapeutic trial of isoniazid in 344 patients with uveitis. Br J Ophthalmol. Jun. 1969;53(6):425-7. Exclusion Code: X3. [pmid: 4893874].
439 Ramakrishnan CV, Devadatta S, Evans C, et al. A four-year follow-up of patients with quiescent pulmonary tuberculosis at the end of a year of chemotherapy with twice-weekly isoniazid plus streptomycin or daily isoniazid plus pas. Tubercle. Jun. 1969;50(2):115-24. Exclusion Code: X2. [pmid: 4892322].
440 Evans C, Devadatta S, Fox W, et al. A 5-year study of patients with pulmonary tuberculosis treated at home in a controlled comparison of isoniazid plus PAS with 3 regimens of isoniazid alone. Bull World Health Organ. 1969;41(1):1-16. Exclusion Code: X2. [pmid: 5309083].
441 Johnson FK, Thompson R. A 35 year study of tuberculosis detection and treatment. J Sch Health. Jan. 1969;39(1):8-14. Exclusion Code: X2. [pmid: 5189363].
442 Riska N. Hospital-based ambulatory treatment of tuberculosis with capreomycin, ethambutol, and- or rifampicin. Scand J Respir Dis Suppl. 1969;69:75-9. Exclusion Code: X2. [pmid: 4906378].
443 Radenbach KL. Results of clinical studies with capreomycin, ethambutol and rifampicin in the Heckeshorn Hospital, Berlin. Scand J Respir Dis Suppl. 1969;69:43-53. Exclusion Code: X2. [pmid: 4906373].
444 Meissner G. Rifampicin in newly detected, untreated cases of pulmonary tuberculosis. Acta Tuberc Pneumol Belg. 1969;60(3):554-6. Exclusion Code: X2. [pmid: 4906103].
445 Tani P. The requirement of capreomycin, ethambutol and rifampicin in chronic pulmonary tuberculosis in Helsinki on the basis of resistance indications. Scand J Respir Dis Suppl. 1969;69:15-6. Exclusion Code: X7. [pmid: 4313500].
446 Veening GJ. Long term isoniazid prophylaxis. Controlled trial on INH prophylaxis after recent tuberculin conversion in young adults. Bull Int Union Tuberc. Dec. 1968;41:169-71. Exclusion Code: X3. [pmid: 4885378].
447 Horwitz O. Long-term results of the chemoprophylactic trial in Greenland. Bull Int Union Tuberc. Dec. 1968;41:167-8. Exclusion Code: X3. [pmid: 4885377].
448 Ferebee SH. Long-term effects of isoniazid prophylaxis. Bull Int Union Tuberc. Dec. 1968;41:161-6. Exclusion Code: X7. [pmid: 4885376].
449 Corpe RF, Blalock FA. A continuing study of patients with “open negative” status at Battey State Hospital. Am Rev Respir Dis. Dec. 1968;98(6):954-64. Exclusion Code: X3. [pmid: 4301382].
450 Myers JA, Bearman JE, Botkins AC. The natural history of tuberculosis in the human body. X. Prognosis among students with tuberculin reaction conversion before, during and after school of nursing. Dis Chest. Jun. 1968;53(6):687-98. Exclusion Code: X2. [pmid: 5653743].
451 Stradling P. Clinical experience of intermittent treatment in the United Kingdom. Tubercle. Mar. Suppl. 1968;49:83-5. Exclusion Code: X2. [pmid: 4872962].
452 Leskiewicz H. Permanent residual pulmonary lesions following primary tuberculosis in relation to antituberculous chemotherapy. Pol Med J. 1968;7(1):127-38. Exclusion Code: X2. [pmid: 5300914].
453 Thomassen OK. The prognosis of pulmonary tuberculosis under modern treatment. Scand J Respir Dis Suppl. 1968;63:29-32. Exclusion Code: X2. [pmid: 5188461].
454 Olsen PZ, Torning K. Isoniazid and loss of memory. Scand J Respir Dis. 1968;49(1):1-8. Exclusion Code: X2. [pmid: 5187246].
455 Boszormenyi M, Schweiger O. A controlled clinical trial of the drug treatment of new cases of pulmonary tuberculosis. Scand J Respir Dis Suppl. 1968;65:189-93. Exclusion Code: X2. [pmid: 4978460].
456 Bridge EV. Chemoprophylaxis: a major adjunct in the prevention of tuberculosis. Mich Med. Dec. 1967;66(24):1553-5. Exclusion Code: X7. [pmid: 6080307].
457 Bobrowitz ID, Robins DE. Ethambutol-isoniazid versus PAS-isoniazid in original treatment of pulmonary tuberculosis. Am Rev Respir Dis. Sep. 1967;96(3):428-38. Exclusion Code: X3. [pmid: 6039097].
458 Hyde L. Comparison of single and divided daily doses of isoniazid in original treatment of minimal and noncavitary moderately advanced pulmonary tuberculosis. XVIII. A report of the Veterans Administration-Armed Forces Cooperative Study on the chemotherapy of tuberculosis. Am Rev Respir Dis. Aug. 1967;96(2):204-8. Exclusion Code: X3. [pmid: 4951906].
459 Comstock GW, Ferebee SH, Hammes LM. A controlled trial of community-wide isoniazid prophylaxis in Alaska. Am Rev Respir Dis. Jun. 1967;95(6):935-43. Exclusion Code: X4. [pmid: 6026165].
460 Moodie AS. Mass ambulatory chemotherapy in the treatment of tuberculosis in a predominantly urban community. Am Rev Respir Dis. Mar. 1967;95(3):384-97. Exclusion Code: X3. [pmid: 6018699].
461 Lees AW. Ethionamide, 500 mg. daily, plus isoniazid, 500 mg. or 300 mg. daily in previously untreated patients with pulmonary tuberculosis. Am Rev Respir Dis. Jan. 1967;95(1):109-11. Exclusion Code: X3. [pmid: 5333774].
462 Shimamura K. Results of the cooperative study on chemotherapy of tuberculosis in the National Sanatoria. Jpn J Tuberc. Dec. Suppl. 1966;13:105-18. Exclusion Code: X2. [pmid: 5298476].
463 Reisner D. Comparison of single and divided daily dosages of isoniazid and PAS in the treatment of pulmonary tuberculosis. XV. A report of the Veterans Administration-Armed Forces Cooperative. Study on the chemotherapy of tuberculosis. Am Rev Respir Dis. Dec. 1966;94(6):849-57. Exclusion Code: X3. [pmid: 4958797].
464 Myers JA, Bearman JE, Botkins AC. Natural history of tuberculosis in the human body. IX. Prognosis among students with tuberculin reaction conversion before, during and after medical school. Dis Chest. Aug. 1966;50(2):120-32. Exclusion Code: X5. [pmid: 5923663].
465 Nazareth O, Devadatta S, Evans C, et al. A two-year follow-up of patients with quiescent pulmonary tuberculosis following a year of chemotherapy with an intermittent (twice-weekly) regimen of isoniazid plus streptomycin or a daily regimen of isoniazid plus PAS. Tubercle. Jun. 1966;47(2):178-89. Exclusion Code: X2. [pmid: 5963586].
466 Horwitz O, Payne PG, Wilbek E. Epidemiological basis of tuberculosis eradication. 4. The isoniazid trial in Greenland. Bull World Health Organ. 1966;35(4):509-26. Exclusion Code: X3. [pmid: 5335457].
467 Egsmose T, Ang'awa JO, Poti SJ. The use of isoniazid among household contacts of open cases of pulmonary tuberculosis. Bull World Health Organ. 1965;33(3):419-33. Exclusion Code: X3. [pmid: 5321762].
468 Fox Gregory J, Dobler Claudia C, Marks Guy B. Active case finding in contacts of people with tuberculosis. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd. 2011. Exclusion Code: X3.
469 Song GG, Bae SC, Lee YH. Interferon-gamma release assays versus tuberculin skin testing in patients with rheumatoid arthritis. (Provisional abstract). International Journal of Rheumatic Diseases. 2013:279-83. Exclusion Code: X2. [pmid: 23981748].
470 Sester M, Sotgiu G, Lange C, et al. Interferon- release assays for the diagnosis of active tuberculosis: a systematic review and meta-analysis. (Provisional abstract). European Respiratory Journal. 2011:100-11. Exclusion Code: X3. [pmid: 20847080].
471 Han T. Effectiveness of standard short-course chemotherapy for treating tuberculosis and the impact of drug resistance on its outcome. International Journal of Evidence-Based Healthcare. 2006:101-17. Exclusion Code: X5. [pmid: 21631761].
472 Cox HS, Morrow M, Deutschmann PW. Long term efficacy of DOTS regimens for tuberculosis: systematic review. (Structured abstract). Bmj. 2008:484. Exclusion Code: X2. [pmid: 18250104].
473 Huebner RE, Schein MF, Cauthen GM, et al. Evaluation of the clinical usefulness of mycobacterial skin test antigens in adults with pulmonary mycobacterioses. American review of respiratory disease. 1992:1160-6. Exclusion Code: X3. [pmid: 1586061].
474 Prognostic value of interferon gamma release assays in predicting active tuberculosis among individuals with, or at risk of, latent tuberculosis infection (Project record). Health Technology Assessment Database. Health Technology Assessment. 2010. Exclusion Code: X1.
475 Interferon-gamma release assays testing versus tuberculosis skin testing for tuberculosis: a review of the clinical effectiveness and guidelines. (Structured abstract). Health Technology Assessment Database. Canadian Agency for Drugs and Technologies in Health (CADTH). 2011. Exclusion Code: X7.
476 ?IGRA in Diagnostic Evaluation of Active TB (IDEA) (Project record). Health Technology Assessment Database. Health Technology Assessment. 2012. Exclusion Code: X1.
477 Hayes, Inc. Interferon-gamma release assays for tuberculosis. (Structured abstract). Health Technology Assessment Database. HAYES, Inc. 2012. Exclusion Code: X8.
478 Jiménez-Fuentes MA, Souza-Galvao ML, Mila Augé C, et al. Rifampicin plus isoniazid for the prevention of tuberculosis in an immigrant population. International journal of tuberculosis and lung disease. 2013:326-32. Exclusion Code: X4. [pmid: 23407221].
479 Acceptability, compliance, and adverse reactions when isoniazid, rifampin, and pyrazinamide are given as a combined formulation or separately during three-times-weekly antituberculosis chemotherapy. Am Rev Respir Dis. 1989;140(6):1618-22. Exclusion Code: X3. [pmid: 2604291].
480 Donomae I, Fujita S, Gomi J, et al. Clinical evaluation of Rifampicin in pulmonary tuberculosis. 2. A controlled trial on the clinical effects of chemotherapy with Rifampicin-INH-PAS and SM-INH-PAS for treatment of original cases of pulmonary tuberculosis. Kekkaku. Tuberculosis. 1970:257-62. Exclusion Code: X2. [pmid: 4918166].
481 Kalankhodzhaev AA, Gamzaeva NF. Complex treatment of patients with destructive pulmonary tuberculosis including intramuscular administration of isoniazid. Problemy tuberkuleza. 1991:21-2. Exclusion Code: X2. [pmid: 1924235].
482 Michele G, Iodice F, Lappa B. Preliminary observations on the therapeutic effect of rifampycin associated with streptomycin or isoniazid. Archivio di tisiologia e delle malattie dell'apparato respiratorio. 1968:377-86. Exclusion Code: X2.
483 Weill G, Lévy A, Guignon JP, et al. Reduction of fresh forms of pulmonary tuberculosis by the classical treatment and by combined antibiotics including rifampicin (comparative study of a personal survey). Revue de tuberculose et de pneumologie. 1969:1119-25. Exclusion Code: X2. [pmid: 4916253].
484 Kraan JK, Mulder RJ, Dijk B. Controlled study on rifampicin in first treatment of fresh cases of pulmonary tuberculosis. Acta tuberculosea et pneumologica Belgica. 1969:557-62. Exclusion Code: X3. [pmid: 4906104].
485 Adetifa IM, Ota MO, Jeffries DJ, et al. Interferon-? ELISPOT as a biomarker of treatment efficacy in latent tuberculosis infection: a clinical trial. American journal of respiratory and critical care medicine. 2013:439-45. Exclusion Code: X5. [pmid: 23220919].
486 Loos U, Musch E, Mackes KG, et al. Intravenous rifampicin therapy in open tuberculosis. Die Medizinische Welt. 1983:701-3. Exclusion Code: X2. [pmid: 6888237].
487 Kuntz HD, Rausch V. Hepatotoxic side-effects of rifampicin; a comparative clinical study (author's transl). Praxis und Klinik der Pneumologie. 1977:925-32. Exclusion Code: X2. [pmid: 928291].
488 Fraga H, Gomes O, Paz de Almeida A, et al. Comparative study (in a controlled therapeutic trial) of 3 intermittent regimens, after an initial period of daily administration, in the repeated treatment of pulmonary tuberculosis (results). Bulletin of the International Union against Tuberculosis. 1973:125-38. Exclusion Code: X3. [pmid: 4602467].
489 Iodice F. Long-term results of treatment with rifampicin in early pulmonary tuberculosis. Archivio Monaldi per la tisiologia e le malattie dell'apparato respiratorio. 1972:51-6. Exclusion Code: X2.
490 Poppe de Figueiredo F, Brito AA, Laborne Valle JH, et al. Short-term chemotherapy of pulmonary tuberculosis. Pilot study. Bulletin of the International Union against Tuberculosis. 1974:411-7. Exclusion Code: X3. [pmid: 4619561].
491 Tonceanu S, Bazacliu E, Carp G, et al. Quantitative evaluation of the dynamics of tubercular mediastinal adenopathy treated with rifampicin and ethambutol. Revista de igien?, bacteriologie, virusologie, parazitologie, epidemiologie, pneumoftiziologie. Pneumoftiziologia. 1977:143-50. Exclusion Code: X2.
492 González Montaner LJ, Palma Beltran O, Abbate E, et al. A comparison of the therapeutic efficacy of two drug combinations in cases of previously untreated open tuberculosis (author's transl). Praxis und Klinik der Pneumologie. 1978:717-20. Exclusion Code: X2. [pmid: 724638].
493 Schütz I, Bartmann K. Sputum excretion of tubercle bacilli as early criterion in the evaluation of the therapeutic effectiveness of antituberculous drugs, illustrated by its use in a controlled trial of single-drug regimens. Antibiotica et chemotherapia. Fortschritte. Advances. Progrès. 1970:490-500. Exclusion Code: X3. [pmid: 4943581].
494 Bignall JR. Controlled therapeutic study of 5 intermittent chemotherapy regimens for pulmonary tuberculosis. 4th international study of the UICT. Bulletin of the International Union against Tuberculosis. 1974:422-6. Exclusion Code: X3. [pmid: 4143179].
495 Portilla J, Jordá P, Esteban J, et al. Directly observed treatment of latent tuberculosis infection: comparative study of two isoniazid regimens. Enfermedades infecciosas y microbiología clínica. 2003:293-5. Exclusion Code: X3. [pmid: 12809583].
496 Evaluation of high dose INH twice weekly regimen in the original treatment for moderately advanced pulmonary tuberculosis. A report of the 12th series B study of the controlled trials. Kekkaku. Tuberculosis. 1972:159-66. Exclusion Code: X2. [pmid: 4562924].
497 Ohmori M, Wada M, Nishii K, et al. Preventive therapy in middle-aged and elderly persons selected from the population-based screening by mass miniature radiography - Methodological aspect and adverse reactions. [Japanese]. Kekkaku. Tuberculosis. 2002:647-58. Exclusion Code: X2. [pmid: 12440139].
498 Favez G, Maillard JM, Vouilloz M. Comparative results of medium and increased doses of isoniazid in the triple treatment of overt pulmonary tuberculosis. Schweizerische medizinische Wochenschrift. 1968:1392-5. Exclusion Code: X2. [pmid: 5693896].
499 Carratù L, Sonaglioni F, Natali P. Clinical tolerance of rifampycin administered alone or in combination with other antitubercular drugs. Archivio di tisiologia e delle malattie dell'apparato respiratorio. 1968:399-410. Exclusion Code: X3.
500 Nitti V, Delli Veneri F, Marra A. Rifomycin in treatment of chronic tuberculosis with bacilli resistant to standard medications. Acta tuberculosea et pneumologica Belgica. 1969:455-65. Exclusion Code: X2. [pmid: 4906100].
501 Böszörményi M, Fauszt I, Károlyi A, et al. Our initial clinical experience with rifomycin. Acta tuberculosea et pneumologica Belgica. 1969:471-7. Exclusion Code: X7. [pmid: 4906101].
502 Baba H, Shinkai A, Azuma Y. Controlled clinical trial of three 6 month regimens of chemotherapy for pulmonary tuberculosis. (Report 2)--Results at one year after completing chemotherapy--(author's transl). Kekkaku. Tuberculosis. 1979:29-36. Exclusion Code: X2. [pmid: 372663].
503 Yamamoto K. Controlled comparison of daily and intermittent treatment regimens with rifampicin. Bulletin of the International Union against Tuberculosis. 1974:442-6. Exclusion Code: X3. [pmid: 4619565].
504 Nitti V, Delli Veneri F, Ninni A, et al. Behavior of blood levels of rifampicin during the course of treatment. Archivio Monaldi per la tisiologia e le malattie dell'apparato respiratorio. 1970:310-20. Exclusion Code: X5.
505 Eule H, Iwainsky H. The influence of therapeutical and biological parameters on the appearance of side effects and complaints during intermittent chemotherapy of pulmonary tuberculosis (author's transl). Praxis und Klinik der Pneumologie. 1981:347-53. Exclusion Code: X2. [pmid: 7345430].
506 Loos U, Musch E, Mackes KG, et al. Comparison of oral and intravenous rifampicin administration in the treatment of open pulmonary tuberculosis. Praxis und Klinik der Pneumologie. 1983:482-4. Exclusion Code: X2. [pmid: 6647280].
507 Comstock GW. Isoniazid prophylaxis in an undeveloped area. Am Rev Respir Dis. Dec. 1962;86:810-22. Exclusion Code: X3. [pmid: 14022524].
508 Comstock GW, Baum C, Snider DE Jr. Isoniazid prophylaxis among Alaskan Eskimos: a final report of the bethel isoniazid studies. Am Rev Respir Dis. May. 1979;119(5):827-30. Exclusion Code: X2. [pmid: 453704].
509 Bush OB Jr., Sugimoto M, Fujii Y, et al. Isoniazid prophylaxis in contacts of persons with known tuberculosis. Second report. Am Rev Respir Dis. Nov. 1965;92(5):732-40. Exclusion Code: X2. [pmid: 5321147].
510 Del Castillo H, Bautista LD, Jacinto CP, et al. Chemoprophylaxis in the Philippines: a controlled pilot study among household contacts of tuberculosis cases. Bulletin of the Quezon Institute. 1965;7:277-90. Exclusion Code: X2.
511 Ferebee SH, Mount FW. Tuberculosis morbidity in a controlled trial of the prophylactic use of isoniazid among household contacts. Am Rev Respir Dis. Apr. 1962;85:490-510. Exclusion Code: X2. [pmid: 13892318].
512 Ferebee SH, Mount FW, Murray FJ, et al. A controlled trial of isoniazid prophylaxis in mental institutions. Am Rev Respir Dis. Aug. 1963;88:161-75. Exclusion Code: X2. [pmid: 14045220].
513 Mount FW, Ferebee SH. The effect of isoniazid prophylaxis on tuberculosis morbidity among household contacts of previously known cases of tuberculosis. Am Rev Respir Dis. Jun. 1962;85:821-7. Exclusion Code: X2. [pmid: 14476668].
514 Meier T, Eulenbruch HP, Wrighton-Smith P, et al. Sensitivity of a new commercial enzyme-linked immunospot assay (T SPOT-TB) for diagnosis of tuberculosis in clinical practice. Eur J Clin Microbiol Infect Dis. Aug. 2005;24(8):529-36. Exclusion Code: X8. [pmid: 16133410].
515 Mori T, Sakatani M, Yamagishi F, et al. Specific detection of tuberculosis infection: an interferon-gamma-based assay using new antigens. Am J Respir Crit Care Med. Jul. 1. 2004;170(1):59-64. Exclusion Code: X2. [pmid: 15059788].
516 Brock I, Munk ME, Kok-Jensen A, et al. Performance of whole blood IFN-gamma test for tuberculosis diagnosis based on PPD or the specific antigens ESAT-6 and CFP-10. Int J Tuberc Lung Dis. May. 2001;5(5):462-7. Exclusion Code: X3. [pmid: 11336278].
517 Johnson PD, Stuart RL, Grayson ML, et al. Tuberculin-purified protein derivative-, MPT-64-, and ESAT-6-stimulated gamma interferon responses in medical students before and after Mycobacterium bovis BCG vaccination and in patients with tuberculosis. Clin Diagn Lab Immunol. Nov. 1999;6(6):934-7. Exclusion Code: X3. [pmid: 10548589].
518 Lee JY, Choi HJ, Park IN, et al. Comparison of two commercial interferon-gamma assays for diagnosing Mycobacterium tuberculosis infection. Eur Respir J. Jul. 2006;28(1):24-30. Exclusion Code: X2. [pmid: 16611658].
519 Zhang S, Shao L, Mo L, et al. Evaluation of gamma interferon release assays using Mycobacterium tuberculosis antigens for diagnosis of latent and active tuberculosis in Mycobacterium bovis BCG-vaccinated populations. Clin Vaccine Immunol. Dec. 2010;17(12):1985-90. Exclusion Code: X2. [pmid: 20943878].
520 Lee HM, Shin JW, Kim JY, et al. HRCT and whole-blood interferon-gamma assay for the rapid diagnosis of smear-negative pulmonary tuberculosis. Respiration. 2010;79(6):454-60. Exclusion Code: X2. [pmid: 20110640].
521 Winqvist N, Bjorkman P, Noren A, et al. Use of a T cell interferon gamma release assay in the investigation for suspected active tuberculosis in a low prevalence area. BMC Infect Dis. 2009;9:105. Exclusion Code: X2. [pmid: 19575781].
522 Warier A, Gunawathi S, Venkatesh, et al. T-cell assay as a diagnostic tool for tuberculosis. Indian Pediatrics. 2010. 01. 01. 2010;47(1):90-2. Exclusion Code: X2. [pmid: 19430061].
523 Ferrara G, Losi M, Meacci M, et al. Routine hospital use of a new commercial whole blood interferon-gamma assay for the diagnosis of tuberculosis infection. Am J Respir Crit Care Med. Sep. 1. 2005;172(5):631-5. Exclusion Code: X2. [pmid: 15961696].
524 Ferrara G, Losi M, D'Amico R, et al. Use in routine clinical practice of two commercial blood tests for diagnosis of infection with Mycobacterium tuberculosis: a prospective study. Lancet. Apr. 22. 2006;367(9519):1328-34. Exclusion Code: X4. [pmid: 16631911].
525 Nishimura T, Hasegawa N, Mori M, et al. Accuracy of an interferon-gamma release assay to detect active pulmonary and extra-pulmonary tuberculosis. Int J Tuberc Lung Dis. Mar. 2008;12(3):269-74. Exclusion Code: X4. [pmid: 18284831].
526 Ozekinci T, Ozbek E, Celik Y. Comparison of tuberculin skin test and a specific T-cell-based test, T-SPOT.TB, for the diagnosis of latent tuberculosis infection. J Int Med Res. Sep-Oct. 2007;35(5):696-703. Exclusion Code: X9. [pmid: 17944056].
527 Brock I, Weldingh K, Leyten EM, et al. Specific T-cell epitopes for immunoassay-based diagnosis of Mycobacterium tuberculosis infection. J Clin Microbiol. Jun. 2004;42(6):2379-87. Exclusion Code: X2. [pmid: 15184408].
528 Taggart EW, Hill HR, Ruegner RG, et al. Evaluation of an in vitro assay for interferon gamma production in response to the Mycobacterium tuberculosis-synthesized peptide antigens ESAT-6 and CFP-10 and the PPD skin test. Am J Clin Pathol. Mar. 2006;125(3):467-73. Exclusion Code: X5. [pmid: 16613353].
529 Soborg B, Andersen AB, Larsen HK, et al. Detecting a low prevalence of latent tuberculosis among health care workers in Denmark detected by M. tuberculosis specific IFN-gamma whole-blood test. Scand J Infect Dis. 2007;39(6-7):554-9. Exclusion Code: X2. [pmid: 17577817].
530 Lalvani A, Nagvenkar P, Udwadia Z, et al. Enumeration of T cells specific for RD1-encoded antigens suggests a high prevalence of latent Mycobacterium tuberculosis infection in healthy urban Indians. J Infect Dis. Feb. 1. 2001;183(3):469-77. Exclusion Code: X3. [pmid: 11133379].
531 Pathan AA, Wilkinson KA, Klenerman P, et al. Direct ex vivo analysis of antigen-specific IFN-gamma-secreting CD4 T cells in Mycobacterium tuberculosis-infected individuals: associations with clinical disease state and effect of treatment. J Immunol. Nov. 1. 2001;167(9):5217-25. Exclusion Code: X3. [pmid: 11673535].
532 Stennis NL, Trieu L, Ahuja SD, et al. Estimated Prevalence of Tuberculosis Infection Among a New York City Clinic Population Using Interferon-gamma Release Assays. Open Forum Infectious Diseases. September. 1. 2014. 2014;1(2). Exclusion Code: X2.
533 LoBue PA, Moser KS. Use of isoniazid for latent tuberculosis infection in a public health clinic. Am J Respir Crit Care Med. Aug. 15. 2003;168(4):443-7. Exclusion Code: X4. [pmid: 12746255].
534 Tagmouti S, Slater M, Benedetti A, et al. Reproducibility of interferon gamma (IFN-gamma) release Assays. A systematic review. Ann Am Thorac Soc. Oct. 2014;11(8):1267-76. Exclusion Code: X2. [pmid: 25188809].
535 Kruczak K, Duplaga M, Sanak M, et al. Comparison of IGRA tests and TST in the diagnosis of latent tuberculosis infection and predicting tuberculosis in risk groups in Krakow, Poland. Scand J Infect Dis. Sep. 2014;46(9):649-55. Exclusion Code: X2. [pmid: 25073535].
536 Leow MK, Dalan R, Chee CB, et al. Latent tuberculosis in patients with diabetes mellitus: prevalence, progression and public health implications. Exp Clin Endocrinol Diabetes. Oct. 2014;122(9):528-32. Exclusion Code: X5. [pmid: 25003362].
537 Lagrange PH, Thangaraj SK, Dayal R, et al. A toolbox for tuberculosis (TB) diagnosis: an Indian multi-centric study (2006-2008); evaluation of serological assays based on PGL-Tb1 and ESAT-6/CFP10 antigens for TB diagnosis. PLoS One. 2014;9(5):e96367. Exclusion Code: X3. [pmid: 24797271].
538 Park H, Shin JA, Kim HJ, et al. Whole blood interferon-gamma release assay is insufficient for the diagnosis of sputum smear negative pulmonary tuberculosis. Yonsei Med J. May. 2014;55(3):725-31. Exclusion Code: X2. [pmid: 24719140].
539 Erkens CG, Dinmohamed AG, Kamphorst M, et al. Added value of interferon-gamma release assays in screening for tuberculous infection in the Netherlands. Int J Tuberc Lung Dis. Apr. 2014;18(4):413-20. Exclusion Code: X5. [pmid: 24670695].
540 Faurholt-Jepsen D, Aabye MG, Jensen AV, et al. Diabetes is associated with lower tuberculosis antigen-specific interferon gamma release in Tanzanian tuberculosis patients and non-tuberculosis controls. Scand J Infect Dis. May. 2014;46(5):384-91. Exclusion Code: X3. [pmid: 24621055].
541 Ferguson TW, Tangri N, Macdonald K, et al. The diagnostic accuracy of tests for latent tuberculosis infection in hemodialysis patients: a systematic review and meta-analysis. (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014. p. epub. Exclusion Code: X2.