# Methods

## Detailed Methods

### Search Strategies

#### Initial searches

##### PubMed (08/29/14)

Tuberculosis final searches, 8-29-14: 4,288 citations saved in EndNote

PubMed: 3,531 total English language citations saved in EndNote

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Tuberculosis”[Mesh] OR “Latent Tuberculosis”[Mesh]) | 159183 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Interferon-gamma Release Tests”[Mesh] OR IGRA[All Fields] OR “Mantoux tuberculin skin test”[All Fields] OR “Tuberculin Test”[Mesh] OR “tuberculin skin test”[All Fields] OR TST[tiab] OR “T-SPOT”[All Fields] OR “T-SPOT.TB”[All Fields] OR QuantiFERON[All Fields] OR “QFT-GIT”[All Fields]) | 15573 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 9057 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) Filters: Humans | 7781 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) Filters: Systematic Reviews; Humans | 151 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 576514 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 and #6) | 176 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies”) | 1820788 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 and #8) | 1800 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Isoniazid”[Mesh] OR isoniazid[All Fields] OR “rifapentine”[Supplementary Concept] OR rifapentine[All Fields] OR “Rifampin”[Mesh] OR Rifampin[All Fields]) | 32885 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #10) | 12750 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #10) Filters: Humans | 10205 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #10) Filters: Systematic Reviews; Humans | 155 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 and #6) | 684 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies”) | 1820788 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 and #15) | 1811 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 or #13) | 282 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 or #13) Filters: English | 243 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 not #18) | 39 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #9 or #14 or #16) | 4013 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 or #9 or #14 or #16) Filters: English | 3348 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#20 not #21) | 665 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#18 or #21) | 3531 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#19 or #22) | 703 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)

##### Cochrane Library (08/29/14)

For the Cochrane Library search, we did not limit using study design terms, because Cochrane breaks out study results by the categories we seek. We searched the Cochrane Library of Reviews, Trials, Methods, and Technology Assessments. We did not save the Economic Evaluations.

##### Results

Screening:

- All = 250 total results (179 without Economic Evaluations)
- Cochrane Reviews = 12, all imported
- Other reviews = 27, all imported
- Trials = 136
- Technology Assessments = 4
- Economic Evaluations = 71 (not saved)

Drug therapy:

- All = 714 total results (638 without Economic Evaluations)
  - Cochrane Reviews = 22, 11 imported
  - Other reviews = 36, 34 imported
  - Trials = 580, 533 imported
  - Economic Evaluations = 76 (not saved)
- Importing to EndNote = 84 total reviews
  673 Trials and Technology Assessments
- Total in EndNote from the Cochrane Library = 757
  ClinicalTrials.gov search 4-27-15
  291 trials
  Tuberculosis AND (“Interferon-gamma Release Tests” OR IGRA OR “Mantoux tuberculin skin test” OR “Tuberculin Test” OR “tuberculin skin test” OR TST or “T-SPOT” OR “T-SPOT.TB” or QuantiFERON or “QFT-GIT” OR isoniazid OR rifapentine OR Rifampin)

##### WHO ICTRP search and results (05/19/15)

185 records for 173 trials

Searched in Advanced search:

Condition box: Tuberculosis

- Intervention box: Interferon-gamma Release Tests OR IGRA OR Mantoux tuberculin skin test OR Tuberculin Test OR tuberculin skin test OR TST or T-SPOT OR T-SPOT.TB or QuantiFERON or QFT-GIT OR isoniazid OR rifapentine OR Rifampin

(Recruitment status ALL)

185 records for 173 trials found

#### Bridge Searches

Tuberculosis update searches, July 30-31, 2015 and Aug 3, 2015

##### PubMed (07/30/15)

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Tuberculosis”[Mesh] OR “Latent Tuberculosis”[Mesh]) | 162959 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Interferon-gamma Release Tests”[Mesh] OR IGRA[All Fields] OR “Mantoux tuberculin skin test”[All Fields] OR “Tuberculin Test”[Mesh] OR “tuberculin skin test”[All Fields] OR TST[tiab] OR “T-SPOT”[All Fields] OR “T-SPOT.TB”[All Fields] OR QuantiFERON[All Fields] OR “QFT-GIT”[All Fields]) | 16219 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 9413 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) Filters: Humans | 8116 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) Filters: Systematic Reviews; Humans | 163 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 608085 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 and #6) | 184 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies”) | 1946601 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 and #8) | 1945 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Isoniazid”[Mesh] OR isoniazid[All Fields] OR “rifapentine”[Supplementary Concept] OR rifapentine[All Fields] OR “Rifampin”[Mesh] OR Rifampin[All Fields]) | 33825 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #10) | 13136 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #10) Filters: Humans | 10571 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #10) Filters: Systematic Reviews; Humans | 170 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 and #6) | 708 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies”) | 1946601 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 and #15) | 1931 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #13) | 309 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #13) Filters: English | 270 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#17 not #18) | 39 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9 or #14 or #16) | 4285 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9 or #14 or #16) Filters: English | 3604 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#20 not #21) | 681 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 or #21) | 3813 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 or #22) | 719 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (child* OR children OR teen OR teens OR teenage OR teenaged OR adolescen* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 3221593 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #13) Filters: English; Child: birth-18 years | 67 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 and #25) | 84 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#27 or #26) | 84 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 or #13) Filters: English; Adult: 19+ years | 65 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#28 and #29) | 39 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#28 NOT #30) | 45 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 NOT #31) | 225 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#28 NOT #30) Filters: Publication date from 2014/03/29 | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 NOT #31) Filters: Publication date from 2014/03/29 | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 and #25) | 12 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#17 not #18) Filters: Child: birth-18 years | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#35 or #36) | 12 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#38 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#17 not #18) Filters: Adult: 19+ years | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=38)
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#37 and #38) | 8 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#37 NOT #39) | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#37 NOT #40) | 8 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9 or #14 or #16) Filters: Publication date from 2014/03/29; English | 200 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9 or #14 or #16) Filters: Publication date from 2014/03/29; English; Child: birth-18 years | 84 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#42 and #25) | 85 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=44)
#45 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#43 or #44) | 87 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=45)
#46 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9 or #14 or #16) Filters: Publication date from 2014/03/29; English; Adult: 19+ years | 143 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=46)
#47 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#45 and #46) | 58 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=47)
#48 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#45 NOT #47) | 29 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=48)
#49 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#46 NOT #48) | 143 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=49)
#50 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 or #22) Filters: Publication date from 2014/03/29 | 12 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=50)
#51 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 or #22) Filters: Publication date from 2014/03/29; Child: birth-18 years | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=51)
#52 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#50 and #25) | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=52)
#53 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 or #22) Filters: Publication date from 2014/03/29; Adult: 19+ years | 6 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=53)

##### Cochrane Library (08/03/15)

- Adults+ = 10
  - 4 Cochrane Reviews
  - 6 Trials
- Children = 21
  - 8 Reviews
    - 3 Cochrane Reviews
    - 5 Other reviews
  - 8 Trials
  - 1 Technology Assessment
  - 4 Econ Evaluations (not saved)

ID | Search | Hits
#1 | [mh Tuberculosis] or [mh “Latent Tuberculosis”] | 1766
#2 | [mh “Interferon-gamma Release Tests”] or IGRA or “Mantoux tuberculin skin test” or [mh “Tuberculin Test”] or “tuberculin skin test” or TST or “T-SPOT” or “T-SPOT.TB” or QuantiFERON or “QFT-GIT” | 699
#3 | #1 and #2 | 260
#4 | [mh Isoniazid] or isoniazid or rifapentine or [mh Rifampin] or Rifampin | 1918
#5 | #1 and #4 | 740
#6 | #3 or #5 Publication Year from 2014 to 2015 | 31
#7 | (child* or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric* or boys or girls or youth or youths) | 172203
#8 | #6 and #7 | 16
#9 | #6 and (adult* or middle-age* or elderly) | 19
#10 | #9 and #8, Adults+ | 10
#11 | #6 not #10, Children | 21

##### WHO ICTRP search and results

(6/9/15 – 8/3/15)

0 results

Searched in Advanced search:

Condition box: Tuberculosis

Intervention box:

- Interferon-gamma Release Tests OR IGRA OR Mantoux tuberculin skin test OR Tuberculin Test OR tuberculin skin test OR TST or T-SPOT OR T-SPOT.TB or QuantiFERON or QFT-GIT OR isoniazid OR rifapentine OR Rifampin

(Recruitment status ALL)

##### ClinicalTrials.gov search update (08/03/15)

Last Updated Date: 4/27/15-08/03/15

39 trials

11 child

28 adult

- Tuberculosis AND (“Interferon-gamma Release Tests” OR IGRA OR “Mantoux tuberculin skin test” OR “Tuberculin Test” OR “tuberculin skin test” OR TST or “T-SPOT” OR “T-SPOT.TB” or QuantiFERON or “QFT-GIT” OR isoniazid OR rifapentine OR Rifampin)

## Eligibility Criteria for Studies by Key Question

Population | Intervention and Comparator | Setting | Outcomes | Study Design
KQ 1. Effect of screening for LTBI on morbidity, mortality, quality of life, and transmission
Asymptomatic adults belonging to populations at increased risk for LTBI.^a^ The following are excluded: children, symptomatic adults, close contacts of active TB patients, and populations at highest risk for progression from LTBI to active TB disease because of underlying immunosuppression or for whom LTBI screening and treatment would be part of standard disease management by specialty care providers. This includes people with HIV, head and neck cancer, leukemia or lymphoma, silicosis, history of or planned organ transplant, dialysis, planned or active use of TNF-α inhibitors, and planned or active use of chemotherapy. Mixed populations can be included if results are stratified for the included portion of the study population or the excluded portion does not exceed 25% of the study population. | Screening with TST or IGRA as compared with no screening. Studies with no comparator group are excluded. | Primary care settings in countries categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme). Study settings considered to be applicable to primary care will also include homeless shelters, correctional facilities, college health settings, long-term care facilities, public health clinics, and workplaces. HIV and subspecialty care settings and workplace settings that screen for LTBI as part of a formal surveillance program for occupational exposure are excluded. | Active TB disease, TB transmission, quality of life, and mortality (disease-specific and overall). Other outcomes are excluded. | RCTs, prospective cohort studies. Other study designs are excluded.
KQ 2a. Accuracy and reliability of TST and IGRA screening tests KQ 2b. Accuracy and reliability of sequential screening strategies using TST and IGRA screening tests
For sensitivity outcome: patients with bacteriologic- confirmed active TB who have not yet received treatment or who had received no more than a few weeks of treatment. Subjects with TB infection not confirmed by culture, AFB smear, or molecular tests are excluded. For specificity outcome: healthy subjects with no history of TB exposure or risks. Subjects with known history of TB or TB exposure, subjects with HIV, and acutely ill subjects are excluded. Mixed populations of children and adults or studies with both HIV-negative and HIV-positive subjects (sensitivity outcome only) can be included if results are stratified for the includable portion of the study population or the excluded portion does not exceed 25% of the study population. | TST using Mantoux method with intermediate-strength dose of PPD (i.e., 5 TU PPD-S, 2.5 TU RT-23) and standard thresholds for positive test (i.e., 5-mm, 10-mm, 15-mm). Commercially available, FDA-approved IGRA tests. T-SPOT.TB; QuantiFERON- TB Gold (2nd-generation); and QuantiFERON-TB Gold In-Tube (3rd-generation). Other tests, such as nucleic acid amplification, are excluded. | For sensitivity outcome: studies in any country in any setting are included. For specificity outcome: studies in intermediate- or low-TB-burden countries are included. Studies in high-TB-burden countries are excluded.^b^ | Sensitivity, specificity, and reliability (i.e., test-retest). Concordance rates among tests and other outcomes are excluded. Studies assessing 2-step TST testing were excluded. | Systematic reviews, RCTs, cohort studies, cross-sectional studies. Other study designs are excluded.
KQ 3. Effectiveness of treatment for LTBI
Asymptomatic adults with confirmed LTBI; otherwise, same criteria as for KQ 1 except that close contacts of active TB patients were eligible if LTBI was confirmed (e.g., with a positive TST). | Treatment with CDC-recommended regimen (isoniazid daily for 6 or 9 months, isoniazid twice weekly by directly observed therapy for 6 or 9 months, rifampin daily for 4 months, or isoniazid plus rifapentine weekly by directly observed therapy for 3 months) compared with no treatment, delayed treatment, or another eligible treatment. Studies comparing other treatments or combinations are excluded. | Same as KQ 1, except that workplace settings were eligible. | Active TB disease (i.e., progression to active TB disease), TB transmission, quality of life, and mortality (disease-specific and overall). | RCTs
KQ 4. Harms of screening for LTBI
Same as KQ 1 | TST and IGRA tests as described in KQ 1 and KQ 2. | Same as KQ 1 | False-positive results leading to unnecessary testing or treatment, labeling, stigma, anxiety, and cellulitis | Systematic reviews; RCTs and prospective cohort studies.
KQ 5. Harms of treatment for LTBI
Same as KQ 3 | Same as KQ 3 | Same as KQ 1, except that workplace settings were eligible | Hepatotoxicity, mortality from hepatotoxicity, nausea, vomiting, peripheral neuropathy, development of drug-resistant TB, and other specific adverse effects of medications. | RCTs, prospective cohort studies, and case-control studies.

a Adult population subgroups at increased risk for developing active TB include: 1) people who have immigrated from TB-endemic countries; 2) people who work or reside in facilities or institutions with high-risk individuals, such as homeless shelters, correctional facilities, nursing homes or residential facilities; and 3) people with increased risk for progression from LTBI to active TB due to underlying illness or use of medications, injection drug use, or radiographic evidence of prior healed TB.1

b High-TB-burden countries include the following: Afghanistan, Bangladesh, Brazil, Cambodia, China, the Democratic Republic of the Congo, Ethiopia, India, Indonesia, Kenya, Mozambique, Myanmar, Nigeria, Pakistan, the Philippines, the Russian Federation, South Africa, Thailand, Uganda, the United Republic of Tanzania, Vietnam and Zimbabwe. This list is not exhaustive but represents the countries with the highest absolute burden (high rates and high population).30

Abbreviations: AFB=acid fast bacilli; CDC=Centers for Disease Control and Prevention; FDA=U.S. Food and Drug Administration; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; KQ=key question; LTBI=latent tuberculosis infection; PPD=purified protein derivative; RCT=randomized, controlled trial; TB=tuberculosis; TNF-α=tumor necrosis factor-alpha; TST=tuberculin skin test; TU=tuberculin units.

## U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials

Criteria
- Initial assembly of comparable groups: Randomized controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of Ratings Based on Above Criteria

Good: | - Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis.
Fair: | - Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | - Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VII http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual---appendix-vii, Harris et al., 2001^31^

### Studies of Diagnostic Tests

Criteria
- Screening test relevant, available for primary care, adequately described. Although this is one of the USPSTF criteria in its procedures manual, this criterion was not relevant for studies of sensitivity because no reference standard for LTBI exists and the population for sensitivity outcomes are patients with bacteriologic-confirmed active TB.
- Study uses a credible reference standard, performed regardless of test results.
- Reference standard interpreted independently of screening test.
- Handles indeterminate results in a reasonable manner.
- Spectrum of patients included in study. Although a USPSTF criterion, this criterion was also not relevant for this topic, given the very specific nature of the population required to estimate sensitivity and specificity in the absence of a reference standard for LTBI.
- Sample size: Although this is one of the criteria listed in the current procedures manual, we did not consider sample size when assessing study quality, as sample size affects precision of the estimate.
- Administration of reliable screening test: We also did not consider this criterion, as reliability was itself a separate outcome in this review.
- In addition to the criteria listed in the USPSTF procedures manual, we also considered whether patient selection criteria were clearly described, whether withdrawals were explained, and whether the methods for calculating outcomes were valid.

Definition of Ratings Based on Above Criteria

Good: | Relevant and adequately described study populations for the outcome of interest (i.e., Sensitivity, Specificity), screening test well described in terms of test procedures followed and threshold used for a “positive” or “negative” test, credible reference standard used for outcome of interest (i.e., Sensitivity or Specificity), generally interprets reference standard independently of screening test, outcomes clearly reported and valid, handles indeterminate results in a reasonable manner.
Fair: | Mostly includes a relevant and adequately described study population for the outcome of interest (i.e., Sensitivity, Specificity), screening test described although may include some ambiguity about test procedures followed or threshold for a “positive” or “negative” test, credible reference standard mostly used for outcome of interest (i.e., Sensitivity or specificity), interpretation of reference standard may or may not be independent of screening test, outcomes mostly clearly reported although may have some ambiguity regarding how indeterminate results were handled.
Poor: | Has fatal flaw such as study population not appropriate for outcome of interest (i.e., Sensitivity, Specificity), screening test improperly administered or not at all described, use of noncredible reference standard, reference and screening test not independently assessed, outcomes not clearly or accurately reported with no information about how indeterminate tests were handled.

Criteria Adapted from: U.S. Preventive Services Task Force, Procedure Manual Appendix VII http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual---appendix-vii, Harris et al., 2001^31^