# Latent Tuberculosis Infection Prevalence and Treatments

Appendix A Table 1 Prevalence of Latent Tuberculosis Infection by High-Risk Category From Published Studies in English, French, or Spanish, 2009 Through 2014^a^

High-Risk Description | Prevalence Based on TST ≥5 mm Median (Range) | Prevalence Based on T-SPOT.TB Median (Range) | Prevalence Based on QFT-GIT Median (Range) | Incidence of Active TB Median Rate per 1,000 (Range)
High risk because of increased likelihood of TB exposure
Prisoners | 45.5 (23.1–87.6) | NR | NR | 2.6 (0.03–9.8)
Health care workers | 29.5 (1.4–97.6) | 5.2 (3.5–28.7) | 14.1 (0.9–76.7) | 1.3 (0.4–4.1)
Adult contacts of active TB cases | 26.3 (1.8–82.7) | 48.0 (29.6–59.6) | 21.1 (6.6–55.1) | 0.6^b^
Immigrants from high-TB-burden countries | 39.7 (17.8–55.4) | 17.0 (9.0–24.9) | 30.2 (9.8–53.8) | 3.6 (1.3–41.2)
Illicit drug users | 85.0 (0.3–86.7) | 45.8 (34.1–57.5) | 63.0 (1.4–66.4) | 6.0^b^
Homeless persons | 45.6 (20.5–79.8) | NR | 53.8 (18.6–75.9) | 2.2 (0.1–4.3)
High risk because of underlying medical conditions
HIV infection | 19.2 (2.1–54.8) | 11.3 (4.3–67.6) | 14.5 (2.7–21.5) | 16.2 (12.4–28.0)
Use of TNF-alpha blockers | 18.6 (11.3–68.2) | 20.0 (12.9–25.0) | 11.8 (4.0–22.3) | 1.4^b^
Silicosis | NR | 61.0^b^ | 46.6^b^ | 32.1^b^
Organ transplantation | 7.7 (4.4–21.9) | 29.5 (20.5–38.5) | 21.9 (16.4–23.5) | 5.1^b^
Hemodialysis | 21.9 (2.6–42.1) | 43.6 (23.3–58.2) | 33.4 (17.4–44.2) | 26.6 (1.3–52.0)

a Adapted from Getahun et al, 2015.^9^

b Single study.

Abbreviations: HIV=human immunodeficiency virus; NR=not reported; QFT-GIT=QuantiFERON-TB Gold In-Tube (3rd-generation test); TB=tuberculosis; TNF=tumor necrosis factor; TST=tuberculin skin test.

Appendix A Table 2 Recommended Treatment Regimens for Latent Tuberculosis Infection

Drug(s) | Duration | Dose | Frequency | Total Doses
INH | 9 months | 5 mg/kg Maximum dose: 300 mg | Daily | 270
INH | 9 months | 15 mg/kg Maximum dose: 900 mg | Twice weekly^a^ | 76
INH | 6 months | 5 mg/kg Maximum dose: 300 mg | Daily | 180
INH | 6 months | 15 mg/kg Maximum dose: 900 mg | Twice weekly^a^ | 52
INH and RPT | 3 months | INH: 15 mg/kg rounded up to the nearest 50 or 100 mg; 900 mg maximum RPT: 10.0–14.0 kg 300 mg 14.1–25.0 kg 450 mg 25.1–32.0 kg 600 mg 32.1–49.9 kg 750 mg ≥50.0 kg, 900 mg maximum | Once weekly^a^ | 12
RIF | 4 months | 10 mg/kg Maximum dose: 600 mg | Daily | 120

a Intermittent regimens must be provided via directly observed therapy (i.e., health care worker observes the ingestion of medication).

Abbreviations: INH=isoniazid; RIF=rifampin; RPT=rifapentine.