# Discussion

## Summary of Evidence

Table 10 Overall Summary of Evidence by Key Question

Key Question | Studies (k) Participants (n) | Overall quality | Consistency | Applicability | Summary of findings
Screening
KQ1. Health outcomes in adulthood KQ2. Intermediate outcomes | 0 | - | - | - | No evidence on the impact of either selective or universal screening for FH on adult health outcomes or intermediate outcomes in childhood and adolescence.
KQ3. Diagnostic yield of screening for FH | k=2 n=83,241 | Fair | N/A (different screening tests, different populations [U.S. and Denmark]) | School-based setting is relevant to primary care. Limited applicability of findings from non-US population. | Using two different tests, the diagnostic yield of screening for FH ranged from 0.13% to 0.48%.
KQ4. Adverse effects of screening | 0 | - | - | - | No evidence on harms of screening.
Treatment
KQ5. Treatment and adult health outcomes | 0 | - | - | - | No evidence on effect of treatment in childhood or adolescence on adult health outcomes.
KQ6. Effect of treatment on intermediate outcomes | Statins: k=8 n=1,071 Nonstatins: k=5 n=718 | Good/fair: 3 studies had <80% retention. | Consistent treatment effects on LDL-C and TC across 5 different statins. Nonstatins (3 bile-sequestering agents and a cholesterol absorption inhibitor) had more modest effects. | Studies applicable to youth with FH cared for in U.S. primary care settings. Participants were recruited from tertiary clinics and were not screen-identified. | Statins: All trials reported statistically significant LDL-C decreases, with most effect sizes ranging from 20% to 40%, compared to negligible changes with placebo. Dose response was seen in 2 studies. All 8 studies that evaluated effect on TC found decreases that were smaller than for LDL-C and consistent across studies. 1 trial reported decrease in CIMT. Nonstatins: All 5 trials (including bile-sequestering agents and ezetimibe) reported decreases in LDL-C ranging from 10% to 27%.
KQ7. Harms of treatment | k=18 n=2,210^*^ | Fair: Most studies were <2 years duration. | Consistent findings of harms within class: statins and bile-sequestering agents | Good. Most studies were applicable to U.S. primary care setting. | Statins were generally well-tolerated; adverse effects were transient. There was no reported impact on growth or maturation. 1 trial showed lower DHEAS in children with FH treated with pravastatin compared to unaffected siblings. Bile-sequestering agents were commonly associated with gastrointestinal symptoms and poor palatability.
Outcomes
KQ8. Association of intermediate outcomes and adult health outcomes | 0 | - | - | - | No evidence on the association between intermediate outcomes in childhood or adolescence and adult health outcomes in persons with FH.

* Studies included for KQ7 involved 2,210 patients, 2,197 of whom had FH.

Abbreviations: KQ=key question, FH=familial hypercholesterolemia, N/A=not applicable, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, CIMT=carotid intima-media thickness, DHEAS=dehydroepiandrosterone sulfate.

### Screening

Consensus in the current debate regarding screening for dyslipidemia in children and adolescents is that the primary benefit of screening is identifying children with FH.27, 80, 81 Identifying children with mild or moderate elevations in LDL-C is cited as a secondary benefit of such screening, but experts disagree on its relative importance and even whether it represents a net benefit.17, 80-84 Dyslipidemia screening to identify LDL-C elevations not caused by FH is addressed in a separate USPSTF evidence review.

Potential benefits of screening for FH include early identification of children and adolescents with FH; prompt initiation of treatment, including pharmacotherapy and low-fat, low-cholesterol diet; slowing the progression of atherosclerosis; and reducing the incidence or delaying the onset of CHD and stroke. In addition, identifying a child or adolescent with FH could accelerate identification of affected family members. Although most experts agree that the benefits of statin treatment likely outweigh the harms in persons with definite FH, the long-term benefits and harms of lipid-lowering medications in children and adolescents remain poorly understood.

In our review, we sought evidence about both universal and selective screening in studies published both before and since the 2007 USPSTF review. Consistent with that USPSTF review, we found no direct evidence that selective or universal screening programs improves intermediate or health outcomes in children or adolescents with FH. The few studies from which diagnostic yield could be determined for pediatric screening programs addressed only universal screening. The statewide universal screening program in West Virginia schools53 found a diagnostic yield of 0.13 percent, a rate considerably lower than published estimates. The Danish study54 of universal screening in first graders used a lipid screening approach (Apo B:A1 ratio), which to our knowledge is not commonly used. The authors reported a (calculated) diagnostic yield of 0.48 percent.

We found no studies reporting diagnostic yield or effectiveness of selective screening for FH in youth (i.e., screening focused on children with a family history of FH or other targeting factor). The 2007 review found 16 studies on the diagnostic accuracy of using family history to target screening for dyslipidemia in childhood. The quality of the overall body of evidence on this topic was rated as “good.” Studies include a range of family history definitions (e.g., whether grandparents or second-degree relatives were included) and definitions of risk (parental history of heart attack, other parental risk factors for dyslipidemia, and age of onset of early CHD). The evidence suggested that, across different family history definitions, using family history as a tool for targeting screening missed substantial numbers of children with elevated lipid concentrations—as many as 90 percent overall, but ranging from 30 to 60 percent in most studies. The 2007 USPSTF recommendation statement on this topic noted that for children with familial dyslipidemia, the group most likely to benefit from screening, use of family history in screening may be inaccurate because of variability of definitions and unreliability of information.47 It went on to point out that serum lipid levels are accurate screening tests for childhood dyslipidemia, although many children with multifactorial types of dyslipidemia would have normal lipid levels in adulthood.

A 2009 evidence report commissioned by AHRQ on the ability of family history to impact health outcomes (risk of stroke and CVD), although not focused exclusively on children, reached conclusions similar to those mentioned above.85 The review also determined that across disease types, specificity (unaffected family members correctly reported) was consistently high, and sensitivity (affected family members correctly reported) was consistently much lower. No factors were clearly associated with reporting accuracy in relatives and affected individuals, including demographics, race, type of disease, insurance status, type of relative, and time since diagnosis. The studies had high risks for selection, verification, and masking biases that may have overestimated accuracy.85

Two recent reports also support the findings of the 2007 USPSTF report and the 2009 AHRQ report. In the Project Heartbeat! study, a longitudinal study tracking CVD risk factors in children in Texas, the accuracy of family history in predicting TC, LDL-C, and HDL-C concentrations was low. Sensitivity ranged from 38 to 43 percent, and specificity from 64 to 65 percent.86 Similarly, the recent report from the CARDIAC school-based screening program in West Virginia87 found that family history screening did not accurately predict either dyslipidemia warranting pharmacologic treatment (specificity, 63%; sensitivity, 20%) or the presence of any dyslipidemia (specificity, 30%; sensitivity, 63%).87

Thus, studies included in the previous USPSTF review, supplemented by several intervening systematic reviews and studies, consistently suggest that family history alone has low sensitivity for identifying children to be screened for FH. This approach should not be confused with “cascade screening” of all relatives (including children) of index cases with known FH, as has been recommended to improve early detection in several countries.11, 88 The U.S. health system does not have the infrastructure to support cascade screening. Therefore, cascade screening was considered to be out of scope for this review.

We found no studies of the harms of screening children and adolescents for FH. The 2007 USPSTF review found that harms of screening for childhood dyslipidemia in general were poorly reported, but none of the studies in that review met our criteria because they were not focused on screening for FH in particular. There are some potential harms of screening for FH in children and adolescents. Screening asymptomatic populations for FH using TC or LDL-C norms carries the risk of false positives. As covered in the separate review on multifactorial dyslipidemia, at least some of these identified individuals may never experience clinically relevant lipid concentrations. Such “nondisease” can result in subtle harms, such as labeling a child as “sick” or causing parent or child anxiety, or unnecessary or even harmful treatment. In some cases, screening for FH may lead to unnecessary or even harmful treatment.

### Treatment

We found no direct evidence for the effectiveness of treating children and adolescents with FH on health outcomes in adulthood; that is, reducing the incidence or delaying the onset of MI or stroke. However, the evidence is fair- to good-quality for the effectiveness of pharmacologic treatment of children and adolescents with FH on intermediate outcomes. Eight RCTs were of statins and five were of other drug classes. Studies of statins ranged from 8 weeks to 2 years in duration, with most being shorter than 1 year. Statins lowered LDL-C and TC concentrations in the short term, with most studies reporting that statins lowered LDL-C by 20 to 40 percent and as much as 50 percent compared to placebo. The greatest effect on LDL-C was in a trial of rosuvastatin;64 participants who received the highest dose (20 mg/day) experienced a 50 percent decrease (least mean squares) in LDL-C from baseline compared to a 1 percent decrease among controls (p<0.001). The effect on HDL-C was minimal or none.

A single study found that pravastatin reduced CIMT by 2 percent in the treatment group, whereas CIMT increased by 1 percent in the control group. There were no consistent differences in treatment effects among different statins, but the number of studies for any one drug was limited. The two studies that compared different doses of statins reported a dose response with pravastatin52 and rosuvastatin.64 In the 2010 rosuvastatin trial,64, 65 the only statin study in which attainment of LDL-C treatment targets was reported, only 12 to 41 percent of participants reached the target LDL-C concentration of less than 110 mg/dL, with greater effects at higher doses. Our findings are consistent with a recent systematic review48 on the effectiveness of statins in children and adolescents with FH. Evidence is insufficient to allow comparison among different statins.

The three RCTs of bile-sequestering agents lasted from 8 weeks to 1 year. These drugs had more modest effects on LDL-C and TC than did statins. The study of colesevelam65 showed a dose response. In the only nonstatin study reporting attainment of LDL-C treatment targets,65 only 3.2 to 7.9 percent of participants reached a target LDL-C of 110 mg/dL or less, with a greater effect at the higher dose of colesevelam.

One additional drug, ezetimibe—an inhibitor of intestinal cholesterol absorption—was studied in two RCTs. In a trial of combination therapy with simvastatin, ezetimibe reduced LDL-C concentrations by 54 percent, 16 percent more than the 38 percent achieved by simvastatin alone.58 In a 12-week RCT of ezetimibe monotherapy, LDL-C decreased by 28 percent from baseline compared to a negligible change in the placebo group.59

Most participants in whom lipid-lowering medications have been studied are children and adolescents with FH, as opposed to those with other, generally milder dyslipidemias. Most of these trials have been conducted in tertiary clinic populations, not screen-detected individuals. Therefore, subjects in these trials may not accurately represent the spectrum of children and adolescents that would be identified from a screening program.

The earlier USPSTF review found that dietary counseling and exercise (in the absence of medication) had limited effect in reducing LDL-C in children and adolescents with probable or definite FH. We found no new studies of lifestyle (diet or exercise) treatment for FH in youth. Neither did we find new studies of dietary supplements in children or adolescents with FH that met our inclusion and quality criteria. All medication trial protocols included a low-fat, low- cholesterol diet.

When the aim of pharmacologic treatment is reducing disease risk (rather than treating disease), only a low risk of harm is acceptable. The evidence about the short-term harms of pharmacologic treatment of children and adolescents with FH is fair- to good-quality. Most studies were conducted outside the United States but were applicable to U.S. primary care settings. Most studies were short, only 6 weeks to 2 years long. Statins were generally well-tolerated, although reversible elevations of liver enzymes and/or CK concentrations were noted in some studies. Ten-year followup of the Dutch Pravastatin Trial found lower DHEAS concentrations in individuals with FH treated with statins compared to unaffected sibings.77 Clinical significance of this difference is unknown. No severe, permanent harms of statins were reported. Bile-acid binding resins were commonly associated with adverse gastrointestinal symptoms and poor palatability. Long-term harms are unknown. Ezetimibe, represented in only two studies, was well-tolerated in the short term. Reports of a small increase in cancer risk among adults treated with ezetimibe89 emphasizes the importance of long-term followup studies when treatment is being initiated in children and adolescents.

### Outcomes

We found no evidence in individuals with FH to quantify the association between intermediate outcomes (such as lipid concentrations or measures of atherosclerosis) in children or adolescents and MI and stroke in adults. The previous USPSTF review did not examine the evidence related to health outcomes in adulthood.

The Simon Broome Register provides some of the first estimates of the increased mortality risk conferred by FH. This tertiary clinic-based U.K. registry found excess CHD mortality in individuals with FH compared to the general population, with markedly elevated standardized mortality ratios in the 20- to 39-year-old age group.1 These data establish the severe natural history of FH among adults referred to lipid clinics; they do not allow direct estimation of the association between lipid concentrations or atherosclerosis in youth and CHD in adulthood.

Children and adolescents with severely elevated LDL-C have pathologic signs of atherosclerosis at earlier ages than do those with normal LDL-C concentrations of the same age,14, 90 but these signs have not been directly related to the probability of CHD in adulthood. Elevated LDL-C in adults predicts MI and stroke.5, 20 However, no direct evidence supports a link between lipid concentrations or measures of atherosclerosis in children and adolescents with FH and health outcomes in adulthood.

### Optimal Age of Statin Initiation (Contextual Question)

The rationale for screening for FH depends on the availability of safe and effective interventions that alter the course of disease for screen-identified cases compared to other methods of diagnosis.70 One benefit of screening youth for FH would accrue if beginning statin treatment in childhood or adolescence improved health outcomes more than treatment for FH that is begun in young adulthood. Several lines of evidence have promoted interest in treatment at younger ages. An analysis of adults with FH in the Simon Broome Register compared standardized mortality rates in the prestatin and statin eras and found that the advent of statins coincided with a reduction in fatal CHD in young adults, most of it ascribed to primary prevention.91 This finding raises hopes that earlier statin initiation could reduce young adult mortality, although the authors note that addressing this possibility would require expansion of the cohort. The evidence in adults with elevated LDL-C concentrations (not FH) suggests that achieving lower LDL-C concentrations leads to more benefit.92-94 Aggressive treatment in adults with FH suggests that it is possible to slow, and even reverse, the progression of atherosclerosis.95

Motivated by such evidence, experts have raised the question of what age to initiate statin therapy in youth with FH.50 Answering this question would require a randomized trial in which statin treatment in children or adolescents would begin at different ages and that lasted long enough to measure cardiovascular events or intermediate outcomes in adulthood (such as LDL-C, CIMT, or calcium score). Such a trial has not been undertaken, and indeed, available trials of statin treatment in FH still have relatively short followup. Comparing the long-term incidence of MI or stroke in adults identified and successfully treated for FH from an earlier age with those identified in early or middle adulthood might also be informative. In 14 well-known cohort studies in children or adolescents (Appendix E), we found no such evidence.

The best evidence of statin exposure longer than 2 years in childhood comes from one study: the Dutch Pravastatin Trial.66, 72, 76 Although the initial RCT66 was included as primary evidence for efficacy of treatment (KQ6), the followup studies72, 76 were designed as cohort studies and so were included only for harms (KQ7). As described above (see Results), this study began as a 2-year RCT of pravastatin compared to placebo (n=214; mean age, 13 years) and found a beneficial effect of pravastatin on LDL-C and CIMT.66 Subsequently, the trial was converted to a cohort study, with all FH patients treated with pravastatin and a group of nonFH siblings enrolled as controls. Two publications from this later phase of the Dutch Pravastatin Trial72, 76 provide observational data to inform this age of initiation question. The first followup of the Dutch Pravastatin Trial cohort was at a mean of 4.5 years after baseline.76 Younger age at treatment initiation and longer duration of statin exposure independently predicted favorable CIMT values.76 The other publication from the Dutch Pravastatin Trial that sheds light on age of statin initiation reports on CIMT in 91 percent of the original RCT population and 87 percent of the original sibling control group at 10-year followup.72 The progression of CIMT was similar in both FH and sibling groups but began higher in the FH group at baseline and remained higher at followup. As in the other followup study, younger age at statin initiation was associated with thinner CIMT at 10 years.72

These observational findings from the Dutch Pravastatin Trial represent the best evidence to date on the benefits of earlier treatment of FH in youth. Thus, despite considerable trial and observational data in adults, and a biologically plausible pathway through which long-term statin treatment beginning in childhood could reduce or delay the occurrence of cardiovascular events in adulthood through the persistent reduction in atherosclerotic burden, the evidence to assess these benefits is limited. In the absence of RCT data comparing adult CHD outcomes in youth started on statins at different ages, the optimal age of statin initiation in children and adolescents with FH remains unclear.

## Limitations of the Review

One limitation of this review was by design: based on strong advice received during the public comment period, we restricted the KQs to FH alone and addressed other atherogenic dyslipidemias in a separate review. Thus, all findings here are limited to screening for and treatment of FH.

The literature has several limitations. No published studies met our inclusion criteria for several KQs in this review. Direct evidence for the impact of screening on intermediate or health outcomes is lacking. Evidence for the effectiveness of pharmacotherapy lacks data from long-term studies assessing the effect of lipid-lowering medications on intermediate outcomes in childhood and adolescence or on health outcomes in adulthood. Of the eight trials of statins that evaluated effects on lipid concentrations, only one (short-term) study of the effect of pravastatin on atherosclerosis (as measured by CIMT) met our inclusion criteria.66 Participants in the eight statin trials were patients at tertiary care centers; none of the studies were conducted in screen-detected populations. Few studies were conducted in nonwhite populations.

Only two studies reported the percent of participants achieving target LDL-C. Two statin trials included children as young as age 8 years; however, the age distribution of the statin studies as a whole is skewed to early adolescence, with a mean age of 12 to 15 years. Thus, the bodies of evidence on screening (ages 6 to 8 years) and on statin treatment (largely adolescent subjects) are not aligned. We found no updated evidence on lifestyle interventions for FH or any trials comparing initiation of statins at different ages. The body of evidence on harms of pharmacotherapy also lacks long-term studies.

## Future Research Needs

Randomized trials are needed to assess the benefits and harms of FH screening programs in children and adolescents. Future studies should describe the screening programs in detail, including the followup and laboratory testing of children who screen positive and all screening and diagnostic criteria used to establish FH, as well as reporting the number of true positives. Standard genetic mutation testing of FH cases diagnosed by elevated lipid concentrations and family history alone could help confirm the utility of genetic tests in the multiethnic U.S. population. Reports of such studies should also describe efforts to educate parents about interpreting screening tests, because this knowledge is an important component of screening programs that can affect adherence (e.g., participation in screening and parental adherence to recommendations for followup of positive screens). Future studies of screening approaches should also describe any decision support for providers caring for children and adolescents who test positive for FH, because this information may be important for ensuring appropriate care.

Long-term trials of statin treatment are needed to assess harms as well as effectiveness in improving both intermediate outcomes (lipid concentrations and measures of atherosclerosis in youth) and, ideally, health outcomes in adulthood. More pharmacotherapy studies should be conducted in racially/ethnically diverse U.S. populations. Treatment studies in screen-detected FH cases are essential in the absence of RCTs of screening programs. Further consideration of genetic mutation status in treatment response and outcomes for FH patients may provide important data for personalizing treatment. Studies examining benefits and harms of lipid-lowering medication are needed in children with FH younger than age 10 years. Long-term studies to assess harms are needed. Treatment studies should systematically reports AEs of treatment.

Our understanding of outcomes in FH would be furthered by studies examining longitudinal data in persons with FH to better understand the association between intermediate outcomes in childhood and adolescence and MI and stroke in adulthood.

Some experts have advocated for the inclusion of Mendelian randomization studies in systematic evidence reviews of pediatric dyslipidemia. The Mendelian study takes advantage of the random assortment of alleles in reproduction and uses an observational design to infer causality. This study design has been used to examine the association between different loci (LDLR96, 97 and apolipoprotein B mutations98-101) and CHD. Some studies provide evidence of an association between LDL-C concentration over long periods of time and CHD based on Mendelian randomization. However, experts have pointed out a number of limitations of this study design.102 There is a need for a better understanding of the appraisal of Mendelian data and its integration into systematic reviews.

Past pediatric recommendations on screening for FH have generated controversy, much of which has centered on the advisability of accepting indirect evidence from relatively short-term trials that lack outcomes beyond lipid concentrations.80, 82-84, 103, 104 Some experts have expressed skepticism that long-term RCTs of statins in children and adolescents with FH could be feasibly and ethically conducted,105 while others have called for the conduct of RCTs as a public health priority.50, 106 Reaching agreement on any acceptable surrogate endpoints, such as CIMT and other measures of atherosclerosis,106 may increase the feasibility of such a trial, allowing a shorter time frame, provided such endpoints are predictive of CHD.

## Conclusions

We found no direct evidence of the effect of screening on intermediate or health outcomes. Evidence describing the diagnostic yield of screening for FH in children is minimal. Evidence of the effectiveness of statins to reduce LDL-C and TC concentrations is good in studies up to 2 years long. Evidence that statins affect measures of atherosclerosis in youth is limited. Statins were generally well-tolerated in the short term. Some studies reported reversible elevations of liver enzymes or CK concentrations and one study reported lower DHEAS concentrations at 10 years in men treated with statins starting in childhood or adolescence. Bile-acid binding resins were commonly associated with adverse gastrointestinal symptoms and poor palatability. Long-term harms are unknown. Randomized trials of screening for FH in U.S. youth are needed, as are longer-term treatment trials to evaluate benefits and harms of medications in children and adolescents with FH.