# Results

## Literature Search

We reviewed 6,753 unique abstracts and excluded 6,378. We reviewed 375 full-text articles and excluded 333 (Appendix C). An additional 15 articles were reviewed for contextual questions and not included for any KQs. The remaining set of 27 articles is the included body of evidence for this review. We included two screening studies, 13 studies of drug treatment, and 18 studies (24 publications) of treatment harms. We did not find any relevant studies on adult health outcomes, intermediate outcomes, or harms of FH screening.

## Results of Included Studies

### KQ1 Does Screening for FH in Asymptomatic Children and Adolescents Delay or Reduce the Incidence of MI or Stroke in Adulthood?

No studies were identified.

### KQ2 Does Screening for FH in Asymptomatic Children and Adolescents Improve Intermediate Outcomes in Childhood and Adolescence?

No studies were identified.

### KQ3 What Is the Diagnostic Yield of Appropriate Screening Tests for FH in Children and Adolescents?

#### Description of Included Studies

We identified two fair-quality studies of universal screening for FH in school settings (Table 1). The Coronary Artery Risk Detection in Appalachian Communities (CARDIAC) study was a West Virginia screening program aimed at identifying the prevalence of obesity, dyslipidemia, hypertension, glucose intolerance, and other cardiac risk factors. While the program was not aimed at detection of FH, one publication from CARDIAC reports on children who met criteria for FH.53 The second study was a Danish screening study, also based in a school setting, that measured apolipoproteins as a screening test for FH.54 No studies on selective screening for FH were identified.

Table 1 Included Screening Studies

Study, year Quality County | N | N with FH | Age, mean (SD), years | Age range, years | % Female | Race | Population | Years of data collection
Skovby, 1991^54^ Fair Denmark | 2,085 | 10 | NR | 6 to 8 | NR | NR | 3,025 families with children ages 6 to 8 years in Copenhagen schools | 1987
Cottrell, 2013^53^ Fair U.S. | 81,156 | 107 | NR | 10 to 11^*^ | 53.0 | 93.2% White 2.9% African American 2.3% Bi-racial 0.4% Asian 0.7% Hispanic 0.5% Other | 5th grade students in West Virginia at elementary schools screened annually | 1998 to 2012

* Study composed of 5th grade students; age range inferred from description.

Abbreviations: FH = familial hypercholesterolemia, SD=standard deviation, NR = not reported.

#### Included Populations and Interventions

The West Virginia study was a statewide screening program conducted in schools in all 55 counties between 1998 and 2012. All fifth-grade students (ages 10 to 11 years) were eligible for screening. Girls represented 53 percent of the children screened. The majority were white (93.2%), 2.9 percent were African American, and there were less than 1 percent in other race/ethnic categories. Fasting lipid panels were drawn during the school day and sent to local hospitals or commercial laboratories for analysis, along with other serum chemistries. Procedures for obtaining family history are not described. Children with LDL-C concentrations greater than 155 mg/dL or TC concentrations greater than 260 mg/dL plus DNA evidence of an LDLR mutation in a first- or second-degree relative were considered to have “probable FH.” Parents of children with probable FH were asked to take them to a health care provider for additional testing. Results of this testing are not shown; the procedures are not well described. The CARDIAC screening program was embedded in a series of cardiovascular risk reduction activities in the schools and the larger community.

The Danish study took place in a school setting in Copenhagen, targeting children ages 6 to 8 years who were starting first grade. Screening consisted of measuring apolipoproteins in capillary blood, with followup assessment of subjects and family members based on results. The initial questionnaire asked parents about the incidence and age of onset of chest pains or coronary occlusions in themselves or their relatives (parents, siblings, aunts, and uncles). A positive family history was defined as a report of angina pectoris or MI in men younger than age 50 years or in women younger than age 60 years. Questionnaire responses were not used to guide screening. All eligible children were offered screening, regardless of responses. The screening test consisted of a morning nonfasting capillary blood sample. The sample was dried at room temperature for 2 hours and transported to a laboratory within 6 hours.

Children with an Apo B:A-1 ratio greater than 0.83, which was value marking the 97.5th percentile for the sample, had their capillary apolipoprotein ratios rechecked. Children with an Apo B:A-1 ratio greater than 0.83 on repeat testing had their fasting TC, HDL-C, very-low-density lipoprotein cholesterol (VLDL-C), and triglyceride concentrations measured. Fasting lipid panels were obtained from this group of children and from all available first- and second-degree relatives. LDL-C was calculated as TC − (HDL-C + VLDL-C). If LDL-C was greater than the 95th percentile for age, an additional lipid profile analysis was obtained after at least 3 weeks, and physical and laboratory studies were performed to rule out causes of secondary hyperlipidemia.

#### Quality

The quality of the studies was fair. The West Virginia study provided inadequate information about family history screening, failed to report results of confirmatory testing, and lacked a control group. The Danish study gave a scant description of the recruitment and lipid screening of parents and data on nonparticipants, and lacked a control group.

#### Summary of Findings

The statewide universal screening program in West Virginia schools reported a diagnostic yield of about 1.3 cases per 1,000 screened, with a high threshold for FH.53 The Danish study identified 10 subjects with laboratory results and a family history consistent with FH from a sample of 2,085, for a diagnostic yield of 4.8 cases per 1,000 screened.54

#### Detailed Results

Detailed results are available in Table 2. The statewide universal screening program in West Virginia schools used fasting lipid profiles.53 In this fair-quality study, 81,156 (42%) of 192,610 eligible fifth-grade students were screened between 1998 and 2012, and 12,204 (25.7% of the approximately 47,487 students with fasting lipid profiles) had at least one abnormal lipid value. The authors defined “probable FH” as having an LDL-C concentration greater than 155 mg/dL or TC concentration greater than 260 mg/dL plus DNA evidence of an LDLR mutation in a first- or second-degree relative. Results of confirmatory testing (second lipid panel and family history) are not shown. Based on the author's definition of FH, even without confirmatory testing information, we may consider the 107 screen-positive children to be true positives. This results in a diagnostic yield of about 1.3 cases per 1,000 screened. This rate of 0.13 percent is considerably lower than published estimates.

Table 2 Diagnostic Yield of Screening for Familial Hypercholesterolemia

Author | Context | FH diagnosis criteria | Number screened | Number with probable FH (screen-positives), n | True positives, n | False positives, n | Diagnostic yield, %^*^ | PPV, %^†^
Skovby, 1991^54^ Fair Denmark | Copenhagen schools; all families with children starting 1st grade (ages 6 to 8 years) were offered to participate in the pilot screening program | Apolipoprotein B concentration above the 99th centile and Apo B:A-1 ratio >0.83 | 2,085 | 47 | 10 | 37 | 0.48 | 21.3
Cottrell, 2013^53^ Fair U.S. | CARDIAC project, school-based screening in 5th grade students in 53/55 West Virginia counties. All 5th graders eligible | TC >6.7mmol/L or LDL-C >4.0 mmol/L or LDLR gene mutation positive in FDR or SDR | 81,156 | NR | 107^‡^ | NR | 0.13% | NR

* Diagnostic yield is calculated as the number of true postives divided by the number of subjects screened.

† Positive predictive value is calculated as the number of true positives divided by the number of screen-positives.

‡ Article describes 107 with probable FH, number of screen-positives not reported.

Abbreviations: FH=familial hypercholesterolemia, PPV=positive predictive value, Apo B=apolipoprotein B, CARDIAC=Coronary Artery Risk Detection in Appalachian Communities, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, LDLR=low-density lipoprotein receptor, FDR=first-degree relative, SDR=second-degree relative, NR=not reported.

In the Danish study, questionnaires were sent to 3,025 families; 2,675 were returned, and 2,166 parents consented to their children's screening. Of these, successful blood testing and measurement of Apo B:A-1 ratio was obtained for 2,085 children. On initial screen, 47 children (2.2%) had an Apo B:A-1 ratio above 0.83; the ratio remained above 0.83 on repeat screening in 12 children (0.58%). Of the 12 children with a high ratio on the second screening, 11 had fasting lipid concentrations (TC and LDL-C) above the 95th percentile for age based on Danish norms. Almost all (10 of 12) showed biochemical evidence of familial involvement (both the child and one parent) consistent with FH. Diagnostic yield for universal screening was 4.8 cases per 1,000 screened, which was above the expected incidence of 2 to 3 cases per 1,000 screened. This result suggests either a higher proportion of FH in the Danish population or the existence of a broader set of inherited dyslipidemias beyond FH, because genetic mutation testing was not performed.

Lipid measurements in relatives of children with persistent Apo B:A-1 ratios above 0.83 identified 29 close relatives with previously undiagnosed hypercholesterolemia and were sufficient to establish an autosomal-dominant inheritance pattern of FH in 10 families. Physical examination and additional laboratory testing in subjects was unrevealing.

### KQ4 What Are the Harms of Screening for FH in Children and Adolescents?

No studies were identified.

### KQ5 Does Treatment of FH With Lifestyle Modifications and/or Lipid-Lowering Medications in Children and Adolescents Delay or Reduce the Incidence of Adult MI and Stroke Events?

No studies were identified.

### KQ6 Does Treatment of FH With Lifestyle Modifications and/or Lipid-Lowering Medications in Children and Adolescents Improve Intermediate Outcomes in Childhood and Adolescence?

#### Description of Included Studies

Thirteen fair- to good-quality treatment trials in children with FH met our inclusion criteria (Table 3). All 13 trials evaluated lipid-lowering medications. Eight were trials of statins, three were trials of bile-sequestering agents,55-57 and two were trials of ezetimibe, an inhibitor of intestinal cholesterol absorption.58, 59 No studies meeting the inclusion criteria evaluated the effect of lifestyle modifications or dietary supplements on intermediate outcomes in children with FH.

Table 3 Included Treatment and Harms of Treatment Studies (Ordered Chronologically by Statin Type and Nonstatin Type)

Study, year Quality County | Drug name | Trial duration | N | N with FH | Age, mean (SD), years | Age range, years | % Female | Race | Population | Years of data collection
Treatment (KQ 6: 13 studies;12 report on harms and are included for KQ 7)
KQ 6 and KQ 7 statins
Knipscheer, 1996^52^ Good Netherlands | Pravastatin | 12 weeks | 72 | 72 | 12.0 (NR) | 8 to 16 | 65.3 | 91.7% white 6.9% black 1.3% Asian | 72 children with FH | NR
Wiegman, 2004^66^ Good Netherlands Dutch Pravastatin Trial | Pravastatin | 104 weeks | 214 | 214 | 13.0 (3) | 8 to 18 | 53.3 | NR | 214 children with FH ages 8 to 18 years in the Netherlands | 1997–2001
Couture, 1998^67,*^ Good Canada | Simvastatin | 6 weeks | 63 | 63 | 12.6 (2.3) | 8 to 17 | 41.3 | NR | 63 FH patients enrolled at University Lipid Research Clinic with confirmed mutations in the LDLR gene | NR
De Jongh, 2002a62 Good International multicenter | Simvastatin | RCT: 24 weeks Extension: 24 weeks | 173 | 173 | 14.2 (2.1) | 10 to 17 | 43.3 | NR | 173 children with FH | NR
Stein, 1999^61^ Good U.S; Finland | Lovastatin | 48 weeks | 132 | 132 | 13.2 (0.3) | 10 to 17 | 0.0 | NR | Boys ages 10 to 17 years with FH; 14 pediatric outpatient clinics in the U.S. and Finland | 1990–1994
Clauss, 2005^60^ Good USA | Lovastatin | 24 weeks | 54 | 54 | 15.0 (2) | 11 to 18 | 100.0 | 80.0% white 20.0% not white | 54 girls ages 10 to 18 years with FH and at least 1 year postmenarche | 1999–2000
McCrindle, 2003^63^ Good U.S., Canada, Europe, South Africa | Atorvastatin | RCT: 26 weeks Open label: 26 weeks | 187 | 187 | 14.1 (2.1) | 10 to 17 | 31.0 | 92% white 1.6% black 1.6% Asian 4.8% other | 187 children with FH or severe hypercholesterolemia | NR
Avis, 2010^64^ Good Europe and North America | Rosuvastatin | RCT: 12 weeks Open label: 40 weeks | 176 | 176 | 14.5 (1.8) | 10 to 17 | 45.0 | 93.8% Caucasian | Patients ages 10 to 17 years with FH recruited from 20 centers in Europe and North America | 2006–2008
KQ 6 and KQ 7 nonstatins
Tonstad, 1996b56 Good Norway | Colestipol | RCT: 8 weeks Open label: 52 weeks | 66 | 66 | 13.1 (1.7) | 10 to 16 | 43.5 | NR | Adolescents previously referred to pediatric lipid clinic with elevated lipids | NR
Tonstad, 1996a55 Fair Norway | Cholestyramine | 52 weeks | 72 | 72 | 8.4 (1.4)^†^ | 6 to 11 | 38.5 | NR | Boys and girls ages 6 to 11 years with FH | NR
Stein, 2010^65^ Good International multicenter | Colesevelam | RCT: 8 weeks Open label: 18 weeks | 194 | 194 | 14.1 (2.0) | 10 to 17 | 36.6 | 87.1% Caucasian 3.1% black 4.1% Asian 5.2% multiple 0.5% other | Children ages 10 to 17 years with FH | 2005–2007
van der Graaf, 2008^58^ Good Netherlands, U.S., Canada | Ezetimibe and simvastatin | RCT: 33 weeks Open label: 20 weeks | 248 | 248 | 14.2 (1.9) | 10 to 17 | 42.7 | 81.9% Caucasian 3.6% Asian 1.6% black or African American 12.9% multiracial | Male and postmenarchal female adolescents ages 10 to 17 years with FH | 2005–2007
Kusters, 2015^59^ Good 9 countries | Ezetimibe | 12 weeks | 138 | 125 | 8.3 (1.6) | 6 to 10 | 57% | 80% white | 138 children ages 6 to 10 years with diagnosed FH or LDL-C >160 mg/dL | 2009–2012
Harms of Treatment Only (KQ 7: 9 studies)
KQ 7 only: statins
Hedman, 2003^68^ Fair Finland | Pravastatin | 8 weeks | 20 | 20 | 10.3 (2.9) | 4.9 to 15.6 | 65.0 | NR | 20 patients verified by LDLR gene mutation analysis or by lymphocyte test | NR
Rodenburg, 2007^76^ Fair Netherlands Dutch Pravastatin Trial | Pravastatin^‡^ | Mean duration of statin treatment: 4.5 years (range, 2.1 to 7.4 years) | 186 | 186 | 13.7 (3.1) | NR | 51.0 | NR | Children and adolescents with FH in a study at the Academic Medical Center in Amsterdam | 1997–2003
Kusters, 2014^72^ Good Netherlands Dutch Pravastatin Trial | Pravastatin^†^ | 10+ years | 277 | 194 | 24.0 (95% CI, 23.6 to 24.5) | NR | 53.6 | NR | Children enrolled in the Dutch Pravastatin Trial; this followup describes outcomes for 194 members of the original cohort and 83 siblings | 1997–2011
Braamskamp, 2015a78 Good Netherlands Dutch Pravastatin Trial | Pravastatin | 2 year (10-year followup) | Tolerability: 205 Adherence: 188 | Tolerability: 205 Adherence: 188 | At start of RCT: 13.0 (2.9) End of followup: 24.0 (3.2) | At start of RCT: 8 to 18 End of followup: 18 to 30 | Tolerabilty (n=205): 54% Adherence (n=188): NR | NR | Children enrolled in the Dutch Pravastatin Trial between 1997 and 1999 | 1997–2009
Braamskamp, 2015b77 Good Netherlands Dutch Pravastatin Trial | Pravastatin | 2 year (10-year followup) | 150 | 88 | FH at baseline: 12.8 (3.1) FH at 10 years: 23.9 (3.2) Siblings at 10 years (n=62): 24.1 (3.0) | FH at baseline: 8 to 18 FH at 10 years: NR Siblings at 10 years: NR | 24% | NR | Children enrolled in the Dutch Pravastatin Trial between 1997 and 1999 and their siblings | 1997–2009
Carreau, 2011^73^ Fair France | Pravastatin | Mean: 2 years and 2 months Range: 3 months and 7 years | 185 | 185 | 11 (NR) | 4 to 17 | 54.6 | NR | Children identified from medical records at specialized French centers in Paris | 2002–2009
De Jongh, 2002b70 Fair Netherlands | Simvastatin | 28 weeks | 69 | 50 | 14.6 (2.5)^§^ | 9 to 18 | 47.8^§^ | NR | 50 heterozygous FH children plus 19 nonaffected controls. 28 in FH simvastatin group, 22 in FH placebo group, 19 nonFH controls. | NR
Gandelman, 2011^75^ Fair Greece, Norway, and Canada | Atorvastatin | 8 weeks | 39 | 39 | 11.6 (3.0) | 6 to 17 | 48.8 | 100% white | Tanner stage 1 and stage 2 children with genetically verified FH | 2008–2009
Avis, 2011^74^ Good Netherlands | Rosuvastatin | RCT: 12 weeks Open label: 40 weeks | 29 | 29 | 14.4 (1.9) | 10 to 17 | 48.3 | NR | Children ages 10 to 17 years with heterozygous FH participating in Avis 2010 (PLUTO) trial | 2006–2008
Braamskamp, 2015c79 Good Netherlands, U.S., Canada, Belgium, Norway CHARON | Rosuvastatin | 2 years | 198 | 198 | 11.6 (3.3) | 6 to 17 | 56% | NR | 198 children with HeFH | 2010–2013
Sinzinger, 2004^69,*^ Fair Austria | Various statins | 8 years | 22 (all subjects) 6 (in pediatric subgroup) | 22 (all subjects) 6 (in pediatric subgroup) | 16.8 (2.6) (all subjects) | 13–35 (all subjects) 13-20 (pediatric subgroup) | 40.0 (all subjects) | NR | Professional athletes with FH | NR
KQ 7 only: nonstatins
McCrindle, 2002^71^ Good Canada | Colestipol and pravastatin | 18 weeks | 36 | 36 | Median: 14 | 9 to 18 | 30.6 | NR | Children seen at the pediatric lipid disorder clinic at the Hospital for Sick Children (Toronto) and St. Joseph's Hospital (Hamilton) | NR

* Couture 1998 only included for KQ 6.

† Mean age for 96 subjects who entered the yearlong dietary phase.

‡ Pravastatin was original drug prescribed to study cohort.

§ Data represent only those with FH.

** This review focuses on the 6 athletes that met our inclusion criteria (study reported individual-level data).

Abbreviations: KQ=key question, FH=familial hypercholesterolemia, SD=standard deviation, NR=not reported, LDLR=low-density lipoprotein receptor, RCT=randomized, controlled trial, LDL-C=low-density lipoprotein cholesterol, PLUTO=Pediatric Lipid-redUction Trial of rOsuvastatin, HeFH=heterozygous familial hypercholesterolemia.

#### Included Populations

The 13 trials included 54 to 248 participants (Table 3). Trial participants' ages ranged from 6 to 18 years. In 11 of these trials, mean ages of participants ranged from 12 to 15 years; two trials had a mean age of 8 years.55, 59 Both girls and boys were well represented in included trials, 11 of which included both sexes. One study included girls only60 and one included boys only.61 Half (k=7) of included trials were conducted in two or more countries in Europe, North America, or Asia.57-59, 61-65 Four of these multicenter trials had centers in four or more countries and three included at least one country outside our inclusion criteria based on the Human Development Index.62, 63, 65 The remaining trials were conducted in the Netherlands (k=2),52, 66 Norway (k=2),55, 65 Canada (k=1),67 and the United States (k=1).60 Only seven trials reported race, and in these, 80 to 94 percent of subjects were white.52, 57-59, 63, 64 All participants were patients at specialty lipid clinics. None of the studies reported identifying screening-detected participants. Only one study required participants to be treatment-naïve.66

FH was defined by elevated fasting lipid concentrations in combination with family history using various standard criteria. Genetic mutations were among the possible inclusion criteria in five studies;55, 57, 58, 64, 66 some studies specified mutations in LDLR56, 65 and apoB65 genes. In one study, LDLR mutation was a required criterion for the diagnosis of FH.65, 67 One ezetimibe trial59 included youth who did not meet criteria for FH but whose LDL-C concentrations were between 160 and 400 mg/dL; these children accounted for 9 percent of participants in that trial and were analyzed together with children with FH. Eleven trials used fasting LDL-C concentrations,52, 58-67 and the other two used TC cut points.55, 56 Fasting LDL-C or TC concentrations had to be elevated on at least two occasions in five trials.55, 56, 61, 66, 67 Seven studies required that fasting LDL-C be elevated while the child or adolescent was on a low-fat diet, for a duration ranging from 4 weeks to 4 months.52, 58, 59, 61, 65-67 LDL and TC cut points were based on age and were similar across studies.

Mean baseline TC ranged from 260 to 320 mg/dL. Mean baseline LDL-C ranged from 198 to 254 mg/dL. Mean baseline HDL-C ranged from 42 to 50 mg/dL. Mean baseline triglycerides ranged from 62 to 110 mg/dL.

Five studies required participants to be at least at Tanner stage II or greater58, 61-64 or required girls to be postmenarchal.58, 62, 64 Three studies set a minimum weight or body mass index percentile for participation.58, 60, 67

For presumed safety reasons, four studies also excluded participants whose LDL-C was above a maximum cut point60-62, 67 (400 mg/dL in two studies;60, 62 500 mg/dL in one study61). Individuals with elevated triglyceride concentrations were excluded from eight of these trials.56, 59, 60, 63, 65-67 Most trials excluded participants with homozygous FH, secondary dyslipidemias, and use of medications that could affect lipid concentrations.

#### Included Interventions

Of 13 RCTs evaluating the effect of different lipid-lowering medications on dyslipidemia or atherosclerosis in children with FH (Table 3), statin medications were studied in eight trials (N=1,071): pravastatin (N=286),52, 66 simvastatin (N=236),62, 67 and lovastatin (N=186)60, 61 were each evaluated in two studies, and atorvastatin (N=187)63 and rosuvastatin (N=176)64 were each evaluated once. Dose ranges for the different statins were: pravastatin, 5 to 40 mg;52, 66 simvastatin, 20 to 40 mg;62, 67 lovastatin, 40 mg;60, 61 atorvastatin, 10 mg;63 and rosuvastatin, 5 to 20 mg.64 Duration of the blinded, randomized trials ranged from 6^67^ to 104 weeks.66

The three trials of bile-sequestering agents55, 56, 65 evaluated cholestyramine at a dose of 8 g/day for 1 year,55 colestipol at a dose of 10 g/day for 8 weeks,56 and colesevelam at two different doses (1.875 g and 3.75 g/day) for 8 weeks.65 There were two trials of ezetimibe, an inhibitor of intestinal cholesterol absorption. One trial assessed ezetimibe monotherapy (10 mg/day) compared to placebo for 12 weeks.59 Another studied ezetimibe (10 mg/day) in combination with simvastatin (up to 40 mg/day) for 33 weeks.58

Retention was greater than 90 percent in seven studies,52, 58-60, 63, 64, 66 80 to 90 percent in three studies,56, 61, 65 70 to 80 percent in two studies,62, 67 and 67 percent in one study.55

#### Quality

All trials were rated as fair- to good-quality. No trials were excluded for poor quality, although 32 studies were excluded for not being RCTs (Appendix C). We included 12 good-quality trials and one of fair quality.55 The major limitation of the fair-quality study was low patient retention.

#### Overall Results

##### Statins

Eight trials reported on the effects of statins on lipid concentrations. All trials reported decreases in LDL-C from baseline, with mean decreases ranging from 23 to 57 mg/dL. Effect sizes were similar across different statins (Figure 3). Two trials compared a range of doses, and both showed a dose-response effect on lipid concentrations for pravastatin52 and rosuvastatin.64 Of the eight statin RCTs, three were longer than 6 months: two had 48 weeks of followup,61, 62 and one had 104 weeks.66 The greatest effect on LDL-C was in a trial of rosuvastatin.64 Participants who received the highest dose (20 mg/day) experienced a 50 percent decrease (least mean squares) in LDL-C from baseline compared to a 1 percent decrease among controls (p<0.001).

Figure 3 Effect of Statins on Mean Percent Change of Low-Density Lipoprotein Cholesterol

Abbreviations: SD=standard deviation, CI=confidence interval.

Figure 3 is a forest plot depicting the effect of five statins (pravastatin, simvastatin, lovastatin, atorvastatin, and rosuvastatin) on mean percent change of low-density lipoprotein cholesterol (LDL-C). The greatest effect was found in a 2010 rosuvastatin trial, in which participants experienced a 44% mean decrease in LDL-C (standard deviation, 12).

Eight studies reported the effect of statins on TC, all showing decreases of 20 to 30 percent from baseline (compared to no change with placebo). The effects of statins on HDL-C were mixed, with some studies reporting small but equivocal improvement and others reporting no important changes. Six studies could be summarized in a forest plot (Figures 2–4) of mean differences across statins by percent change from baseline of TC, LDL-C, and HDL-C. Significant treatment effects on TC and LDL-C, with overlapping 95% CIs, are seen for all five drugs in these studies: atorvastatin, lovastatin, pravastatin, simvastatin, and rosuvastatin. Mean differences for HDL-C include or come close to zero in all five studies. Because of differences across studies, the forest plots include a range of treatment durations, from 12 to 48 weeks.

Figure 2 Effect of Statins on Mean Percent Change of Total Cholesterol

Abbreviations: SD=standard deviation, CI=confidence interval.

Figure 2 is a forest plot depicting the effect of five statins (pravastatin, simvastatin, lovastatin, atorvastatin, and rosuvastatin) on mean percent change of total cholesterol. The greatest effect was found in a 2010 rosuvastatin trial, in which participants experienced a 34% mean decrease in total cholesterol (standard deviation, 10).

Figure 4 Effect of Statins on Mean Percent Change of High-Density Lipoprotein Cholesterol

Abbreviations: SD=standard deviation, CI=confidence interval.

Figure 4 is a forest plot depicting the effect of five statins (pravastatin, simvastatin, lovastatin, atorvastatin, and rosuvastatin) on mean percent change of high density lipoprotein cholesterol (HDL-C). The greatest effect was found in a 2010 rosuvastatin trial, in which participants experienced a 8% mean increase in HDL-C (standard deviation, 14).

A single trial assessed the effect of pravastatin on measures of atherosclerosis, reporting a 2.01 percent decrease in CIMT after 104 weeks compared with a 1.02 percent increase in the control group.66 Mean change between groups differed significantly (p=0.02). No study assessed the effect of statins on calcium score or pathologic findings.

##### Nonstatin Medications

Five fair- to good-quality RCTs of nonstatins in children and adolescents with FH met our inclusion criteria: three of bile-sequestering agents and two of ezetimibe. All trials reported decreases in LDL-C from baseline. There were three RCTs of bile-sequestering agents. A good-quality trial of colestipol found a mean reduction in LDL-C of 19.5 percent after 8 weeks of treatment compared to a 1 percent decrease in the control group.56 One fair-quality RCT of cholestyramine found an 18.6 percent reduction in LDL-C after 1 year compared to a 1.5 percent increase in the control group.55 One good-quality 8-week RCT of colesevelam65 published after the 2007 USPSTF review found a decrease in mean LDL-C of 10 percent (SE, 2.1%) at the higher of two doses compared to a mean increase of 2.5 percent (SE, 2.0%) in the control group. A lower dose resulted in a smaller nonsignificant reduction. One good-quality RCT,58 also published after the 2007 USPSTF review, reported that LDL-C decreased by a mean of 54.0 percent (SD, 1.4%) in participants who received ezetimibe and simvastatin compared to a decrease of 38.1 percent (SD, 1.4%) in the simvastatin-only group at 33 weeks. A good-quality RCT of ezetimibe monotherapy reported a 28 percent (95% CI, 25 to 31) reduction in LDL-C in the treatment group compared to negligible change in the placebo group.59

#### Detailed Results for Statins

##### Effect on Lipid Concentrations

Eight good-quality RCTs of statins in children and adolescents with FH were included (Table 4). Seven of these were included in the 2007 USPSTF review on this topic; one good-quality RCT64 was published after that report. Details from these studies are discussed below.

Table 4 Randomized, Controlled Trials of Medication in Children and Adolescents With Familial Hypercholesterolemia: Effect of Statins, Bile-Sequestering Agents, and Other Drugs on Lipid Concentrations

Author, Year, Quality | N (IG/CG) % Female | Mean age (SD), years Range, years | Drug RCT duration | Measure of change from baseline | TC | LDL-C | HDL-C | Triglycerides
Statins
Knipscheer,1996^52^ Good Netherlands | 72 (54/18) 65.3% | 12.0 (NR) 8 to 16 | Pravastatin 12 weeks | Mean (95% CI) % change | Mean % change 5 mg: -18.2 (-21.9 to -14.2) 10 mg: -17.2% (-21.1 to -13.1) 20 mg: -24.6% (-28.1 to -21.0) CG: -2.3% (-6.7 to 2.4) | Mean % change 5 mg: -23.3 (-27.9 to -18.4) 10 mg: -23.8 (-28.5 to - 18.8) 20 mg: -32.9 (-37.0 to -28.6) CG: -3.2 (-9.0, to -3.0) | Mean % change 5 mg: +3.8 (-3.1 to 11.2) 10 mg: +5.5 (-1.7 to 13.2) 20 mg: +10.8 (3.4 to 18.8) CG: +4.3 (-2.7 to 11.8) | Mean % change 5 mg: -1.7 (-15.4 to 22.2) 10 mg: +6.6 (-12.0 to 29.0) 20 mg: +3.3 (-14.3 to 24.5) CG: -11.7 (-26.6 to 6.1)
Wiegman, 2004^66^ Good Netherlands | 214 (106/108) 53.0% | 13.0 (3) 8 to 18 | Pravastatin 104 weeks | Mean (SD) difference | IG: -56.0 (43) CG: +2.0 (39) | IG: -57.0 (43) CG: 0.0 (36) | IG: +3.0 (10) CG: +1.0 (9) | IG: +12.0 (-35 to -16) CG: +1.0 (-20 to 22)
Couture,1998^67,*^ Good Canada | 63 (47/16) | 12.5 (2.4) 8 to 17 | Simvastatin 6 weeks | Mean % change | IG: -29.5% CG: -5.8% | IG: -37.5% CG: -5.6% | NR by intervention group | NR by intervention group
De Jongh, 2002a62 Good International multicenter | 173 (106/69) 43.3% | 14.2 (2.1) 10 to 17 | Simvastatin 24 weeks | Mean (SD) % change | IG: -28.3% (13.4) CG: -0.7% (9.5) | IG: -38.4% (16.0) CG: -1.2% (11.0) | IG: +4.9% (13.5) CG: +0.3% (15.5) | IG: -7.9 (-74.1 to 92.5) CG: -3.2% (-56.2 to 179.5)
Stein,1999^61^ Good U.S. and Finland | 132 (67/65) 0.0% | 13.2 (0.3) 10 to 17 | Lovastatin 48 weeks | Mean (SE) % change | IG: -20.0% (2) CG: -3.0% (1) | IG: -25.0% (2) CG: -4.0% (2) | IG: +1.0% (2) CG: -1.0% (2) | IG: +6.0% (6) CG: +8% (7)
Clauss, 2005^60^ Good U.S. | 54 (35/19) 100% | 15.0 (2) 11 to 18 | Lovastatin 24 weeks | LS mean % change (SE) | IG: -21.8% (2.5) CG: +4.5% (2.9) | IG: -26.8% (3.4) CG: +5.2% (3.9) | IG: +2.5% (2.5) CG: +2.7% (2.9) | IG: -22.7% (6.8) CG: -3.0% (9.6)
McCrindle, 2003^63^ Good U.S., Canada, Europe, South Africa | 187 (140/47) 31.0% | 14.1 (2.2) 10 to 17 | Atorvastatin 26 weeks | Mean (SE) % change | Mean % change IG: -31.4% (1.0) CG: -1.5% (1.5) | Mean % change IG: -39.6% (1.1) CG: -0.4% (1.9) | Mean % change IG: +2.8% (1.3) CG: -1.9% (1.9) | Mean % change IG: -12.0% (2.9) CG: +1.0% (6.2)
Avis, 2010^64^ Good Europe and North America | 176 (130/46) 45.0% | 14.5 (1.8) 10 to 17 | Rosuvastatin 12 weeks | LS mean % change | 5 mg: -30.0% 10 mg: -34.0% 20 mg: -39.0% CG: 0% | 5 mg: -38.0% 10 mg: -45.0% 20 mg: -50.0% CG: -1.0% | 5 mg: +4.0% 10 mg: +10.0% 20 mg: +9.0% CG: +7.0% | 5 mg: -13.0% 10 mg: -15.0% 20 mg: -16.0% CG: -7.0%
Bile-sequestering agents
Tonstad, 1996b56 Good Norway | 66 (33/33) 43.5% | 13.1 (1.7) 10 to 16 | Colestipol 8 weeks | Mean % change | IG: -14.0% CG: -1.0 | IG: -19.5% CG: -1.0% | NR | NR
Tonstad, 1996a55 Fair Norway | 72 (36/36) 38.5% | 8.4 (1.4) 6 to 11 | Cholestyramine 52 weeks | Mean % change | IG: -11.5% CG: +3.0% | IG: -18.6% CG: +1.5% | IG: +13.4% CG: +8.8% | NR
Stein, 2010^65^ Good International multicenter | 194 (129/65) 36.6% | 14.1 (2.0) 10 to 17 | Colesevelam 8 weeks | LS mean % change (SE) | 3.75 g/d: -5.1% (1.58) 1.9 g/d: -0.9% (1.6) CG: +2.3% (1.6) | 3.75 g/d: -10.0% (2.1) 1.9 g/d: -3.8% (2.1) CG: +2.5% (2.0) | 3.75 g/d: +8.3 (1.6) 1.9 g/d: +4.5 (1.6) CG: +2.2% (1.6) | 3.75 g/d: +17.4 (42.8) 1.875 g/d: +18.5 (34.9) CG: +12.3 (36.2)
Stein, 2010^65^ Good International multicenter | 194 (129/65) 36.6% | 14.1 (2.0) 10 to 17 | Colesevelam 8 weeks | Treatment difference | 3.75 g/d: -7.4% (2.23) (p<0.01) 1.9 g/d: -3.2% (2.23) | 3.75 g/d: -12.5% (2.92) (p<0.001) 1.9 g/d: -6.3% (2.91) (p=0.031) | 3.75 g/d: +6.1% (2.28) (p<0.01) 1.9 g/d: +2.4 % (2.3) | 3.75 g/d: +5.1% (76.5) 1.875 g/d: +6.4% (70.7) (p=0.47)
Other drugs
van der Graaf, 2008^58^ Good Netherlands, U.S., Canada | 248 (126/122) 42.7% | 14.2 (1.9) 10 to 17 | Ezetimibe (ezetimibe + simvastatin vs. simvastatin) 33 weeks | Mean (SD) % change | IG: -42.5% (1.2) CG: -29.3% (1.2) | IG: -54.0% (1.4) CG: -38.1% (1.4) | IG: +4.67% (1.3) CG: +3.68% (1.3) | IG: -20.0% (23.8) CG: -13.0% (39.0)
Kusters, 2015^59^ Good 9 countries | 138^†^ (93/45) 57% | 8.3 (1.6) 6 to 10 | Ezetimibe 12 weeks | Mean % change at 12 weeks (95% CI) | IG: -21 (-23 to -18) CG: 0.2 (-3 to 3) | IG: -28 (-31 to -25) CG: -0.95 (-4.9 to 3.0) | IG: 2 (-2 to 6) CG: 1 (-4 to 7) | IG: (geometic mean): -6 (-13 to 1) CG (geometic mean): 8 (-2 to 20)

* For Couture 1998, data on TC and LDL-C were extrapolated from a figure.

† 13 nonFH participants (9 in treatment group, 4 in placebo group) were not analyzed separately.

Abbreviations: FH=familial hypercholesterolemia, IG=intervention group, CG=control group, SD=standard deviation, RCT=randomized, controlled trial, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, NR=not reported, CI=confidence interval, LS=least square, SE=standard error, g/d=grams per day.

Pravastatin. Two good-quality RCTs evaluated the effect of pravastatin on lipid concentrations in children with FH. The first52 studied 72 children ages 8 to 16 years randomly assigned to one of four groups: a placebo group and three pravastatin groups receiving doses of 5, 10, or 20 mg/day. The authors do not report whether adherence was assessed. The intervention period lasted 12 weeks, at the end of which all three pravastatin arms had reductions in mean LDL-C relative to the control arm. There were greater reductions in TC and LDL-C concentrations in the group receiving 20 mg pravastatin compared to the groups receiving 5 or 10 mg of pravastatin. Changes in HDL-C and triglycerides were not statistically significant. Detailed results are provided in Table 4a.

Table 4a Data From Knipscheer 1996 (Pravastatin Trial of 72 Children Ages 8 to 16 Years)

Group | Baseline concentration, mean (range), mg/dL | Change from baseline concentration, mean % change (95% CI) | p-value^*^
Placebo
TC | 302 (216.0 to 516.8) | -2.3 (-6.7 to 2.4)
LDL-C | 247 (154.0 to 458.9) | -3.2 (-9.0 to 3.0)
HDL-C | 42 (30.9 to 54.0) | 4.3 (-2.7 to 11.8)
TG | 71 (35.4 to 168.3) | -11.7 (-26.6 to 6.1)
Pravastatin 5 mg
TC | 298 (227.6 to 397.3) | -18.2 (-21.9 to -14.2) | <0.05
LDL-C | 240 (181.2 to 339.4) | -23.3 (-27.9 to -18.4) | <0.05
HDL-C | 46 (34.7 to 65.6) | 3.8 (-3.1 to 11.2)
TG | 62 (26.6 to 194.9) | 1.7 (-15.4 to 22.2)
Pravastatin 10 mg
TC | 294 (200.6 to 374.1) | -17.2 (-21.1 to -13.1) | <0.05
LDL-C | 236 (138.9 to 304.7) | -23.8 (-28.5 to -18.8) | <0.05
HDL-C | 42 (23.1 to 61.7) | 5.5 (-1.7 to 13.2)
TG | 71 (35.4 to 186.0) | 6.6 (-12.0 to 29.0)
Pravastatin 20 mg
TC | 317.1 (216.0 to 513.0) | -24.6 (-28.1 to -21.0) | <0.05
LDL-C | 259.1 (165.9 to 451.3) | -32.9 (-37.0 to -28.6) | <0.05
HDL-C | 46.4 (30.9 to 69.4) | 10.8 (3.4 to 18.8)
TG | 53.14 (26.6 to 115.1) | 3.3 (-14.3 to 24.5)

* p-values apply to the difference in change from baseline between the treatment and control group.

Abbreviations: CI=confidence interval, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

The Dutch Pravastatin Trial, the longest of any statin trial in children,66 followed 214 children ages 8 to 18 years for 2 years. Children younger than age 14 years received pravastatin 20 mg/day; those age 14 years and older received 40 mg/day. The authors do not report whether adherence was assessed. At the end of the intervention period, the pravastatin group had significant reductions in TC and LDL-C relative to the control group. Changes in HDL-C and TG were minimal and not statistically significant. Detailed results are provided in Table 4b.

Table 4b Data From Wiegman 2004 (Pravastatin Trial of 214 Children Ages 8 to 18 Years)

Group | Baseline concentration, mg/dL | Change from baseline concentration, mean (SD) difference, mg/dL | p-value^*^
Placebo
TC | 300 (47) | 2 (39)
LDL-C | 237 (46) | 0 (36)
HDL-C | 48 (11) | 1 (9)
TG | 64 (46 to 90) | 1 (-20 to 22)
Pravastatin^†^
TC | 302 (56) | -56 (43) | <0.001
LDL-C | 239 (53) | -57 (40) | <0.001
HDL-C | 47 (10) | 3 (10) | 0.09
TG | 70 (50 to 112) | -12 (-35 to 16) | 0.21

All values are given as mean (SD) except for TG values, which are given as median (interquartile range).

* p-values apply to the difference in change from baseline between the treatment and control groups.

† Children age <14 years received 20 mg/day; those age ≥14 years received 40 mg/day.

Abbreviations: SD=standard deviation, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

Simvastatin. Two RCTs evaluated the effect of simvastatin on lipid concentration in children with FH. The first was a good-quality trial67 of 63 children ages 8 to 17 years randomly assigned in a 3:1 ratio to receive 20 mg/day of simvastatin or placebo for 6 weeks. Adherence was assessed by pill count but was not reported. At the end of the intervention period, the simvastatin group had significant reductions in TC and LDL-C relative to the control group. Detailed results are provided in Table 4c. Data for this RCT were extrapolated from a figure.

Table 4c Data From Couture 1998 (Simvastatin Trial of 63 Children Ages 8 to 17 Years)

Group | Baseline concentration, mean (SE), mg/dL^*^ | Change from baseline concentration, mean % change^*,†^ | p-value
Placebo
TC | 293 (13) | -5.8%
LDL-C | 228 (10) | -5.6%
HDL-C | NR | NR
TG | NR | NR
Simvastatin 20 mg
TC | 286 (4) | -29.5% | NR
LDL-C | 222 (4) | -37.5% | NR
HDL-C | NR | NR | NR
TG | NR | NR | NR

* Data from baseline and followup (week 6) were extrapolated from a figure.

† Mean percent change from baseline was calculated from the extrapolated data.

Abbreviations: SE=standard error, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides, NR=not reported.

A multicenter, good-quality study62 randomly assigned 173 children in a 3:2 ratio to receive simvastatin or placebo. Simvastatin was started at 10 mg/day for the first 8 weeks, increased to 20 mg/day for the second 8 weeks, and increased to 40 mg/day for the last 8 weeks of the 24-week trial. The authors do not report whether adherence was assessed. At the end of the intervention period, the simvastatin group had significant reductions in TC and LDL-C relative to the control group. HDL-C changes were minimal, and triglyceride changes were not statistically significant. Detailed results are provided in Table 4d.

Table 4d Data From De Jongh 2002a (Simvastatin Trial of 173 Children Ages 10 to 17 Years)

Group | Baseline concentration, mg/dL | Change from baseline concentration, mean or median % change | p-value^*^
Placebo
TC | 279 (52) | -0.7 (9.5)
LDL-C | 212 (49) | -1.2 (11.0)
HDL-C | 47 (12) | 0.3 (15.5)
TG | 90 (39 to 326) | -3.2 (-56.2 to 179.5)
Simvastatin^†^
TC | 271 (44) | -28.3 (13.4) | <0.001
LDL-C | 204 (42) | -38.4 (16.0) | <0.001
HDL-C | 48 (9) | 4.9 (13.5) | <0.05
TG | 78 (42 to 279) | -7.9 (-74.1 to 92.5)

All values are given as mean (SD) except for TG values, which are given as median (range).

* p-values apply to the difference in change from baseline between the treatment and control groups.

† The treatment group received simvastatin at 10 mg/day for the first 8 weeks, 20 mg/day for the second 8 weeks, and 40 mg/day for last 8 weeks.

Abbreviations: SD=standard deviation, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides

Lovastatin. Two RCTs examined lovastatin60, 61 with a combined sample size of 186, and both showed a decrease in LDL-C.

The first trial61 compared lovastatin to placebo in 132 boys ages 10 to 17 years (mean, 13.2 years). This trial was rated good quality. Lovastatin was started at 10 mg/day and doubled every 8 weeks to a maximum dose of 40 mg/day. Adherence was assessed by pill count but was not reported. At the end of the 48-week intervention period, the lovastatin group had significant reductions in TC and LDL-C relative to the control group. Changes in HDL-C and triglycerides were minimal and not statistically significant. The authors report that the U.S. Food and Drug Administration requested that subjects who had not reached Tanner stage II at entry discontinue the trial. This request resulted in the discontinuation of eight subjects, seven in the placebo group and one in the lovastatin group. Detailed results are provided in Table 4e.

Table 4e Data From Stein 1999 (Lovastatin Trial of 132 Male Children Ages 10 to 17 Years)

Group | Baseline concentration, mean (SE), mg/dL | Change from baseline concentration, mean % change (SE) | p-value^*^
Placebo
TC | 315 (7) | -3 (1)
LDL-C | 250 (7) | -4 (2)
HDL-C | 44 (1) | -1 (2)
TG | 110 (6) | 8 (7)
Lovastatin^†^
TC | 318 (6) | -20 (2) | <0.001
LDL-C | 251 (6) | -25 (2) | <0.001
HDL-C | 45 (1) | 1 (2)
TG | 112 (7) | 6 (6)

* p-values apply to the difference in change from baseline between the treatment and control groups.

† The treatment group received lovastatin starting at 10 mg/day, doubling every 8 weeks to a maximum dose of 40 mg/day.

Abbreviations: SE=standard error, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high- density lipoprotein cholesterol, TG=triglycerides.

The second lovastatin trial60 enrolled 54 girls ages 11 to 18 years (mean, 15 years) and randomly assigned them to lovastatin or placebo. In this good-quality trial, lovastatin was administered at 20 mg for the first 4 weeks and then increased to 40 mg for the duration of the 24-week trial. Adherence was assessed by pill count but was not reported. At the end of the intervention period, the lovastatin group had significant reductions in TC and LDL-C relative to the control group. Changes in HDL-C and triglyceride concentrations were not statistically significant. Detailed results are provided in Table 4f.

Table 4f Data From Clauss 2005 (Lovastatin Trial of 54 Female Children Ages 11 to 18 Years)

Group | Baseline concentration, mean (SD), mg/dL | Least mean squares percent change (SE) from baseline concentration | p-value^*^
Placebo
TC | 269 (41) | 4.5 (2.9)
LDL-C | 199 (40) | 5.2 (3.9)
HDL-C | 45 (9) | 2.7 (2.9)
TG | 103 (54)^†^ | -3.0 (9.6)
Lovastatin^‡^
TC | 289 (50) | -21.8 (2.5) | <0.001
LDL-C | 218 (48) | -26.8 (3.4) | <0.001
HDL-C | 49 (12) | 2.5 (2.5)
TG | 106 (54)^†^ | -22.7 (6.8)

* p-values apply to the difference in change from baseline between the treatment and control groups.

† Values are given as median (SE).

‡ The treatment group received lovastatin starting at 20 mg/day for the first 4 weeks, increasing to 40 mg/day for the duration of the trial.

Abbreviations: SD=standard deviation, SE=standard error, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

Atorvastatin. One good-quality trial of atorvastatin randomly assigned 187 children ages 10 to 17 years (mean, 14.1 years) to receive 10 mg/day atorvastatin or placebo over 26 weeks.63 The authors do not report whether adherence was assessed. At the end of the intervention period, the atorvastatin group had significant reductions in TC and LDL-C relative to the control group. There were small increases in HDL-C concentration and small decreases in triglyceride concentration; both were statistically significant. Detailed results are provided in Table 4g.

Table 4g Data From McCrindle 2003 (Atorvastatin Trial of 187 Children Ages 10 to 17 Years)

Group | Baseline concentration, mean (SEM) mg/dL | Change from baseline concentration, mean % change (SEM) | p-value^*^
Placebo
TC | 298 (8) | -1.5 (1.5)
LDL-C | 230 (7) | -0.4 (1.9)
HDL-C | 46 (2) | -1.9 (1.9)
TG | 106 (8) | 1.0 (6.2)
Atorvastatin 10 mg
TC | 285 (4) | -31.4 (1.0) | <0.001
LDL-C | 219 (3.6) | -39.6 (1.1) | <0.001
HDL-C | 46 (1) | 2.8 (1.3) | 0.02
TG | 103 (5) | -12.0 (2.9) | 0.03

* p-values apply to the difference in change from baseline between the treatment and control groups.

Abbreviations: SEM=standard error of the mean, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

Rosuvastatin. The one RCT published after the 2007 USPSTF report, the PLUTO (Pediatric Lipid-redUction Trial of rOsuvastatin) study,64 was a good-quality trial that randomly assigned 176 children and adolescents ages 10 to 17 years (mean, 14.5 years) to 5, 10, or 20 mg/day of rosuvastatin or placebo. Pill counts indicated that 90 percent of participants were at least 80 percent compliant with the protocol. At 12 weeks, all three intervention groups had marked decreases in mean LDL-C and TC. The 20-mg dose group had the greatest reduction in LDL-C among the eight statin trials reviewed here. Fewer than half the participants who received rosuvastatin reached the target LDL-C concentration of less than 110 mg/dL (12%, 41%, and 41% in the 5-mg, 10-mg, and 20-mg groups, respectively). No subject reached this target in the control group. HDL-C and triglyceride changes were neither clinically nor statistically different from the control group. Detailed results are provided in Table 4h.

Table 4h Data From Avis 2010 (Rosuvastatin Trial of 176 Children Ages 10 to 17 Years)

Group | Baseline concentration, mean (SD), mg/dL | Least mean squares percent change from baseline concentration | p-value^*^
Placebo
TC | 293 (50) | 0
LDL-C | 229 (43) | -1
HDL-C | 45 (11) | 7
TG | 82 (57 to 124) | -7
Rosuvastatin 5 mg
TC | 300 (60) | -30 | <0.001
LDL-C | 238 (55) | -38 | <0.001
HDL-C | 46 (12) | 4 | 0.4
TG | 80 (55 to 100) | -13 | 0.8
Rosuvastatin 10 mg
TC | 297 (49) | -34 | <0.001
LDL-C | 229 (45) | -45 | <0.001
HDL-C | 49 (10) | 10 | 0.2
TG | 81 (53 to 105) | -15 | 0.1
Rosuvastatin 20 mg
TC | 302 (49.9) | -39 | <0.001
LDL-C | 237 (47.9) | -50 | <0.001
HDL-C | 47.2 (13) | 9 | 0.5
TG | 81 (59 to 107) | -16 | 0.1

All values are given as mean (SD) except for TG values, which are given as median (interquartile range).

* p-values apply to the difference in change from baseline between the treatment and control groups.

Abbreviations: SD=standard deviation, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

##### Effect on Atherosclerosis Markers

Only the 2-year pravastatin trial66 reported the effect of a statin (pravastatin) on a measure of atherosclerosis (CIMT) (Table 5). Study details are described above, along with the effect on lipid concentrations. One experienced sonographer, blinded to treatment status, measured CIMT on all B-mode ultrasonograms. After 2 years of treatment with 20 mg, then 40 mg of pravastatin daily, mean CIMT declined marginally in the pravastatin group (−0.010 mm [SD, 0.048 mm]; p=0.049) compared to a trend toward progression in the placebo group (+0.005 mm [SD, 0.044 mm]; p=0.28). Expressed as a percent change from baseline, CIMT decreased by 2.01 percent in the pravastatin group and increased by 1.02 percent in the control group (calculated). The mean change in CIMT between the two groups (0.014 mm [SD, 0.046 mm]) was significant (p=0.02).

Table 5 Randomized, Controlled Trials of Medication in Children and Adolescents With Familial Hypercholesterolemia: Effect on Atherosclerosis

Study, year Quality County | N | N with FH | Mean age (SD) | Age range | % Female | Race | Drug | CIMT^*^ measurement at baseline (mm) | Change in CIMT measurement^*^ from baseline (mm)
Wiegman, 2004^66^ Good Netherlands | 214 | 214 | 13.0 (3) | 8 to 18 | 53.3 | NR | Pravastatin 20–40 mg/day^†^ vs. placebo for 104 weeks | IG: 0.497 (0.055) CG: 0.492 (0.045) | IG: -0.010 (0.048) CG: 0.005 (0.044)

* Measures reported are mean (SD).

† 20 mg/day for those younger than age 14 years; 40 mg/day for those age 14 years and older.

Abbreviations: FH=familial hypercholesterolemia, SD=standard deviation, CIMT=carotid intima-media thickness, NR=not reported, IG=intervention group, CG=control group.

#### Detailed Results for Nonstatin Medications

##### Bile-Sequestering Agents

A good-quality RCT evaluated colestipol (10 g/day) in 66 children and adolescents ages 10 to 16 years (mean age, 13.1 years) with FH.56 Adherence was 68 percent in the colestipol group and 76 percent in the placebo group. After 8 weeks, the colestipol group had significant reductions in TC and LDL-C relative to the control group. Changes in HDL-C were not significant. Detailed results are provided in Table 4i.

Table 4i Data From Tonstad 1996b (Colestipol Trial of 66 Children Ages 10 to 16 Years)

Group | Baseline concentration, mean (SD), mg/dL | Change from baseline concentration, mean % change | p-value^*^
Placebo
TC | 297 (49) | -1.0
LDL-C | 237 (46) | -1.0
HDL-C | 43 (8)
TG | 85 (58)
Colestipol 10 g
TC | 316 (57) | -14.0 | p<0.01
LDL-C | 254 (51) | -19.5 | p<0.01
HDL-C | 43 (10)
TG | 88 (54)

* p-values apply to the difference in change from baseline between the treatment and control groups.

Abbreviations: SD=standard deviation, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

One fair-quality study examined the effect of cholestyramine in 72 children ages 6 to 11 years (mean age, 8.4 years) with FH.55 The intervention group received 8 g/day of cholestyramine for 1 year. Adherence was assessed but not reported. At the end of the 12-month intervention period, the cholestyramine group had significant reductions in TC and LDL-C relative to the control group. HDL-C did not change appreciably in either group. Detailed results are provided in Table 4j.

Table 4j Data From Tonstad 1996a (Cholestyramine Trial of 72 Children Ages 6 to 11 Years)

Group | Baseline concentration, mean (SD), mg/dL | Change from baseline concentration, mean % change | p-value^*^
Placebo
TC | 321 (47) | 3.0
LDL-C | NR | 1.5
HDL-C | 44 (10) | 8.8
TG | 84 (45)
Cholestyramine 8 g
TC | 320 (51) | -11.5 | <0.001
LDL-C | NR | -18.6 | 0.0001
HDL-C | 49 (9) | 13.4
TG | 69 (29)

* p-values apply to the difference in change from baseline between the treatment and control groups.

Abbreviations: SD=standard deviation,TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

A single trial of bile-sequestering agents included in this review was published after the 2007 USPSTF review on child lipids. This good-quality, multisite RCT evaluated colesevelam in 194 children and adolescents ages 10 to 17 years (mean, 14.1 years).65 Participants were randomly assigned to three groups: 1.875 g/day (low dose), 3.75 g/day (high dose), or placebo for 8 weeks. Adherence (assessed by pill count) was greater than 85 percent in all groups, and 89.2 percent of participants who were randomized completed the study. At the end of the 8-week intervention period, the colesevelam groups experienced greater reductions in LDL-C and TC than the placebo group, with more pronounced reductions in the high-dose group. The treatment goal of an LDL-C concentration less than 110 mg/dL was achieved by 3.2 percent (n=2) in the low-dose group and by 7.9 percent (n=5) in the high-dose group. Detailed results are provided in Table 4k.

Table 4k Data From Stein 2010 (Colesevelam Trial of 194 Children Ages 10 to 17 Years)

Group | Baseline concentration, mean (SD), mg/dL | Treatment difference, mean % (SE)^*^ | p-value^†^
Placebo
TC | 261 (47)
LDL-C | 197 (44)
HDL-C | 45 (9)
TG | 93 (40)^‡^
Colesevelam 1.875 g
TC | 266 (45) | -3.2 (2.2)
LDL-C | 198 (44) | -6.3 (2.9) | <0.05
HDL-C | 48 (12) | 2.4 (2.3)
TG | 83 (46)^‡^ | 6.4 (70.7)
Colesevelam 3.75 g
TC | 267 (51) | -7.4 (2.2) | <0.01
LDL-C | 202 (50) | -12.5 (2.9) | <0.001
HDL-C | 45 (10) | 6.1 (2.3) | <0.01
TG | 85 (55)^‡^ | 5.1 (76.5)

* Treatment difference is calculated versus placebo.

† p-values apply to the difference in change from baseline between the treatment and control groups.

‡ TG values given as median (± interquartile range).

Abbreviations: SD=standard deviation, SE=standard error, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

##### Ezetimibe

There were two studies of ezetimibe, an intestinal cholesterol absorption inhibitor. One good-quality RCT compared the effectiveness of ezetimibe plus simvastatin to simvastatin alone in 248 children and adolescents ages 10 to 17 years (mean, 14.2 years).58 In this six-group trial, three received ezetimibe (10 mg/day) and three received placebo. All six groups received simvastatin, with three different doses for the first 6 weeks (10, 20, or 40 mg/day) but the same dose (40 mg/day) for the next 27 weeks. The last 20 weeks of the trial were open label (both medications). The six groups were combined into two groups for analysis: ezetimibe plus simvastatin and placebo plus simvastatin. The authors do not report whether adherence was assessed. At the end of the 33-week intervention period, the ezetimibe plus simvastatin group had significant reductions in TC and LDL-C relative to the placebo plus simvastatin group. Detailed results are provided in Table 4l.

Table 4l Data From van der Graaf 2008 (Ezetimibe Trial of 248 Children Ages 10 to 17 Years)

Group^*^ | Baseline concentration, mean (SD), mg/dL | Change from baseline concentration, mean % change (SD) | p-value^†^
Placebo + Simvastatin
TC | 286 (4.1) | -29.3 (1.2)
LDL-C | 219 (3.9) | -38.1 (1.4)
HDL-C | 46 (0.8) | 3.7 (1.3)
TG | 88 (38.8)^‡^ | -13.0 (39.0)^‡^
Ezetimibe + Simvastatin
TC | 292 (4.0) | -42.5 (1.2) | <0.01
LDL-C | 225 (3.8) | -54 (1.4) | <0.01
HDL-C | 46 (0.8) | 4.7 (1.3) | 0.58
TG | 89 (49.3)^‡^ | -20.0 (23.8)^‡^ | <0.01

* In this six-group trial, three received ezetimibe (10 mg/day) and three received placebo. All six groups received simvastatin, with three different doses for the first 6 weeks (10, 20, or 40 mg/day) but the same dose (40 mg/day) for the last 27 weeks of the trial. The six groups were combined into two groups for analysis: ezetimibe plus simvastatin and placebo plus simvastatin.

† p-values apply to the difference in change from baseline between the ezetimibe plus simvastatin group and the placebo plus simvastatin group.

‡ For triglycerides, median and standard deviation derived by (interquartile range)/1.075 are provided.

Abbreviations: SD=standard deviation, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, TG=triglycerides.

One good-quality RCT compared the effectiveness of a 12-week course of ezetimibe to placebo in 138 children ages 6 to 10 years (mean, 8.3 years).59 Children in this trial either met criteria for FH (n=125; 91%) or did not meet criteria but had LCL-C greater than or equal to 160 mg/dL. The study groups were analyzed together regardless of diagnosis status. Participants were randomized to receive ezetimibe (10 mg/day) or placebo in a 2:1 ratio. At the end of the 12-week intervention period, the ezetimibe group had significant reductions in TC and LDL-C relative to the placebo group. Maximum effect was achieved at 2 weeks. HDL-C changes were not significant. Detailed results are provided in Table 4m.

Table 4m Data From Kusters 2015 (Ezetimbe Trial of 138 Children Ages 6 to 10 Years)

Group | Baseline concentration, mean (SD), mg/dL | Change from baseline concentration at 12 weeks, mean % change (95% CI) | p-value^*^
Placebo
TC | 290 (44) | 0.2 (-3, 3)
LDL-C | 222 (45) | -0.95 (-4.9, 3.0)
HDL-C | 50 (12) | 1 (-4, 7)
Non-HDL-C | 240 (48) | 0.3 (-4, 4)
TG | 92 (61) | 8 (-2, 20)^†^
Ezetimibe 10 mg
TC | 295 (48) | -21 (-23,-18) | <0.001
LDL-C | 229 (46) | -28 (-31,-25) | <0.001
HDL-C | 50 (9) | 2 (-2, 6) | 0.807
Non-HDL-C | 245 (47) | -25 (-28, -22) | <0.001
TG | 82 (30) | -6 (-13, 1)^†^ | 0.021

* p-values apply to the difference in change from baseline between the treatment and control groups.

† For triglycerides, change from baseline presented as geometric mean.

Abbreviations: SD=standard deviation, CI=confidence interval, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, non-HDL-C=non–high-density lipoprotein cholesterol, TG=triglycerides.

The number of studies of nonstatin medications was too small to explore heterogeneity or publication bias.

### KQ7 What Are the Harms of Treatment of FH With Medications in Children and Adolescents?

#### Description of Included Studies

We identified 24 publications (18 trials) that met criteria for KQ7. Several of these publications have overlapping study populations (Table 6). Twelve RCTs (seven on statins and five on nonstatins) were included in both KQ6 and KQ7. Twelve articles were published before 2007 that fit our inclusion criteria: nine of statins,52, 60-63, 66, 68-70 two of bile-sequestering agents,55, 56 and one of a bile-sequestering agent coadministered with a statin.71 We identified an additional 12 articles published since 2007 with relevant data on harms: nine of statins,64, 72-79 one of a bile-sequestering agent,65 and two of a selective inhibitor of intestinal cholesterol absorption (ezetimibe).58, 59 Most studies were less than 2 years long. One study reported 10-year followup data of statin use.67

Table 6 Overlapping Study Populations

Study | Author, year Quality County | Drug name | N | N with FH | Mean (SD) age, years range | Female, % | Years of data collection | KQ | Description
PLUTO: Pediatric Lipid-redUction Trial of rOsuvastatin | Avis, 2010^64^ Good Europe and North America | Rosuvastatin | 176 | 176 | 14.5 (1.8) 10 to 17 | 45.0 | 2006 to 2008 | KQ 6, KQ 7 | Parent study
PLUTO: Pediatric Lipid-redUction Trial of rOsuvastatin | Avis, 2011^74^ Fair Netherlands | Rosuvastatin | 29 | 29 | 14.4 (1.9) 10 to 17 | 48.3 | 2006 to 2008 | KQ 7 | Subset of PLUTO analyzing the effect of statin therapy on coenzyme Q10 and mitochondrial adenosine triphosphate synthesis
Dutch Pravastatin Trial | Wiegman, 2004^66^ Good Netherlands | Pravastatin | 214 | 214 | 13.0 (3) 8 to 18 | 53.3 | December 1997 to November 2001 | KQ 6, KQ 7 | Parent study
Dutch Pravastatin Trial | Rodenburg, 2007^76^ Fair Netherlands | Pravastatin | 186 | 186 | 24.0 (23.6 to 24.5)^*^ | 51.0 | 1997 to 2003 | KQ 7 | 4- to 7-year followup of original RCT
Dutch Pravastatin Trial | Kusters, 2014^72^ Good Netherlands | Pravastatin | 277 | 194 | 12.9 (NR) 12.5 to 13.4 | 53.6 | 1997 to 2011 | KQ 7 | 10-year followup of original RCT
Dutch Pravastatin Trial | Braamskamp, 2015a78 Good Netherlands | Pravastatin | Tolerability: 205 Adherence: 188 | Tolerability: 205 Adherence: 188 | Start of RCT: 13.0 (2.9) 8 to 18 End of followup: 24.0 (3.2) 18 to 30 | Tolerability (n=205): 54% Adherence (n=88): NR | 1997 to 2009 | KQ 7 | 10-year followup of tolerability and adherence
Dutch Pravastatin Trial | Braamskamp, 2015b77 Good Netherlands | Pravastatin | 150 (includes 62 siblings) | 88 | FH at baseline: 12.8 (3.1) 8 to 18 FH at 10 years: 23.9 (3.2) NR Siblings at 10 years (n=62): 24.1 (3.0) NR | 24% | 1997 to 2009 | KQ 7 | 10-year followup reporting hormone concentrations
Dutch simvastatin trial^†^ | De Jongh, 2002a62 Good Multicenter (n=9) | Simvastatin | 173 | 173 | 14.2 (2.1) 10 to 17 | 43.3 | NR | KQ 6, KQ 7 | Parent study
Dutch simvastatin trial^†^ | De Jongh, 2002b70 Fair Netherlands | Simvastatin | 69 | 50 | 14.6 (2.5) 9 to 18 | 47.8 | NR | KQ7 | Subset of De Jongh 2002a aiming to determine whether simvastain improves endothelial function in children

* 95% confidence interval.

† De Jongh 2002b is a subset of De Jongh 2002a, and the two populations have different age ranges.

Abbreviations: FH=familial hypercholesterolemia, SD=standard deviation, KQ=key question, RCT=randomized, controlled trial, NR=not reported.

Table 7 Adverse Effects Reported in Studies of Statins, Bile-Sequestering Agents, and Other Drugs

Author, Year Quality Location | Drug | N with FH | Age range (years) | Study duration | Harms Assessed | Clinical Effects | Laboratory Effects
Statins
Knipscheer 1996 Good Netherlands | Pravastatin | 72 | 8 to 16 | 12 weeks | Hematology, ALT, AST, CK, alkaline phosphatase, urinalysis, TSH, cortisol, ACTH | Clinical AEs equally distributed between treatment and placebo groups. Clinical AEs in treatment group included rash (n=1), nose bleeding (n=1), headache (n=3), nausea/vomiting (n=3), and abdominal pain (n=2) | No significant difference between treatment and placebo groups for lab AEs. CK level abnormal in placebo (n=8) and pravastatin 5 mg/d (n=6), 10 mg/d (n=11), and 20 mg/d groups (n=8); cortisol level abnormal in placebo (n=2) and pravastatin 5 mg/d (n=2), 10 mg/d (n=5), and 20 mg/d (n=3) groups. For other lab effects, <5 participants had abnormal values in placebo group, as well as in all pravastatin groups combined.
McCrindle 2002 Good Canada | Pravastatin + Colestipol (PC) vs. Colestipol only (CO) | 36 | 9 to 18 | 18 weeks | Height, weight, blood pressure, serum chemistries, blood counts | Clinical AEs more prevalent in CO group. Clinical AEs included constipation (PC 3%, CO 21%), bloating/gas (PC 3%, CO 15%) stomach ache (PC 0%, CO 21%), headache (PC 3%, CO 14%), and muscle aches (PC 3%, CO 6%) | No effects on CK, AST, other blood chemistries, or hematologic values. Alkaline phosphatase levels decreased significantly from baseline for CO group at 18 weeks. Absolute reduction in ALT level from baseline was significantly greater in CO group than PC group at 8 and 18 weeks.
Hedman 2003 Fair Finland | Pravastatin | 20 | 4 to 15 | 8 weeks | GI symptoms, headache, skin reactions, sleep disturbance, muscle/tendon tenderness, pain, creatinine, CK, ALT | Clinical AEs included abdominal pain (n=1), loose stools (n=1), headache (n=4), sleep disturbance (n=2), muscle tenderness or pain at rest (n=1), and muscle tenderness or pain associated with physical training (n=1) | No effects on serum ALT, CK, or creatinine levels
Wiegman 2004 Good Netherlands Dutch Pravastatin Trial | Pravastatin | 214 | 8 to 18 | 104 weeks | Sex steroids, gonadotropins, pituitary adrenal axis markers, growth, sexual development, academic progress, AST, ALT, CK | No effects on growth, sexual development, or academic progress | No effects on muscle or liver enzyme levels (AST, ALT, CK) or on endocrine function
Rodenburg 2007 Fair Netherlands Dutch Pravastatin Trial | Pravastatin | 186 | 13.7 (mean age) | Mean duration of statin treatment: 4.5 years | Sex steroids, gonadotropins, pituitary adrenal axis markers, muscle and liver enzymes, growth, sexual development | Myalgia without CK elevation (n=4). No effects on growth or sexual development. | No serious lab AEs reported; no subjects discontinued treatment due to lab AEs. Lab AEs included elevated CK likely associated with extreme exercise (n=2), mildly elevated FSH (n=4), decreased DHEAS (n=3), and mildly elevated ACTH (n=2).
Kusters 2014 Good Netherlands Dutch Pravastatin Trial | Pravastatin | 194 | 24.0 (mean age) | 10+ years | Growth, sexual development, AST, ALT, CK, glomerular filtration rate, C-reactive protein, level of education, reported AEs | No effects on growth, sexual development, or education level; no reports of rhabdomyolysis or other serious major AEs. 3 subjects discontinued treatment due to unspecified AEs. | No effects on AST, ALT, CK, glomerular filtration rate, or C-reactive protein. No differences between patients with FH and nonFH siblings for lab AEs.
Braamskamp 2015a Good Netherlands Dutch Pravastatin Trial | Pravastatin | 205^*^ | 8 to 18 (start of RCT) 18 to 30 (end of followup) | 2 years (10 years followup) | AEs and reasons for discontinuation assessed by questionnaire. Physical exam and blood sample taken at 10 year followup | 3 subjects discontinued treatment due to side effects (GI, muscle/joint pain, headache). Over 10 years, 55 side effects reported by 40 subjects (19.5%), including muscle complaints (n=19), GI symptoms (n=14), fatigue (n=9), headache (n=4), skin reaction (n=4), and other (n=5).^§^ No reports of rhabdomyolysis. | No reports of elevated liver enzymes or other major lab Aes.
Braamskamp 2015b Good Netherlands Dutch Pravastatin Trial | Pravastatin | 88 | 8 to 18 | 2 years (10 years followup) | Testosterone, estradiol, LH, FSH, and DHEAS | No reports of irregular menstrual cycle, hyperandrogenism, or involuntary childlessness. | Compared with unaffected siblings, DHEAS was significantly lower in participants with FH (though still within normal range). No effects on testosterone, estradiol, LH, or FSH concentrations.
Carreau 2011 Fair France | Pravastatin | 185 | 4 to 17 | 2 years + 2 months (mean duration) | Growth, sexual development, CK, AST, ALT. AEs assessed by review of medical files | 24 subjects (13%) reported AEs, including muscle pain that resolved after changing statins (n=4), muscle pain not attributed to treatment (n=3), musculoskeletal pain (n=12), and headache that resolved spontaneously (n=1). No reports of alopecia or problems related to growth or sexual development. | Asymptomatic CK elevation (n=8) and pain with moderate CK elevation that resolved without changing treatment (n=2). No effects on AST or ALT.
Stein 1999 Good U.S., Finland | Lovastatin | 132 | 10 to 17 | 48 weeks | Growth, sexual development, ALT, AST, CK, urinalysis, routine hematology, blood coagulation, thyroid function, blood nutrients, cortisol, DHEAS, FSH, LH, testosterone | No effect on growth or sexual development. AEs reported by 70.1% of subjects in treatment group and 73.8% in placebo group. Most common AEs in treatment group included respiratory tract infection (47.8%), abdominal pain (10.4%), ENT infection (10.4%), skin disease (9.0%), and gastroenteritis (7.5%). No significant difference between groups for any clinical AEs. | No effects on AST level; ALT level increased in placebo and treatment groups (no significant difference between groups); transient CK elevations in response to exercise (n=3 in lovastatin group, n=1 in placebo group); DHEAS increased (median increase 18% in treatment group, 5% in placebo group; p=0.03).
Clauss 2005 Good U.S. | Lovastatin | 54 girls | 11 to 18 | 24 weeks | ALT, AST, CK, creatinine, glucose, β-human chorionic gonadotrophin, hematology, urinalysis, sexual development, DHEAS, FSH, LH | No patients discontinued treatment due to AEs. No clinically meaningful differences between treatment groups in incidence of treatment-related AEs. Treatment-related AEs in lovastatin group included abdominal pain (n=2), diarrhea (n=1), nausea (n=1), and headache (n=1). Blood pressure significantly lower in placebo group (p<0.05). No effects on growth or menstrual cycle length. No reports of myopathy or rhabdomyolysis. | Transient decreased hematocrit and hemoglobin (n=1); LH levels slightly decreased in placebo group (p<0.05, difference not clinically meaningful). No effect on ALT, AST, CK, DHEAS, FSH, cortisol, or estradiol.
de Jongh 2002a Good International multicenter | Simvastatin | 173 | 10 to 17 | RCT: 24 weeks Extension: 24 weeks | Growth, sexual development, ALT, AST, CK, cortisol, DHEAS, estradiol, testosterone, LH, FSH, human chorionic gonadatropin | No statistically significant differences between placebo and simvastatin groups in period 1 or 2. Clinical AEs in simvastatin group included: abdominal pain (n=3), chest pain (n=1), flatulence (n=1), myalgia (n=2), headache (n=4), sleep disorder (n=1), weight gain (n=1), and pruritus (n=1). No effect on growth or cortisol levels. No serious clinical AEs reported. | No statistically significant differences between placebo and simvastatin groups in period 1 or 2. Lab AEs in simvastatin group included: increased ALT (n=3), AST (n=3), and CK (n=1) levels. No serious lab AEs reported; no participants discontinued treatment due to AE. DHEAS levels decreased (period 1) or remained stable (period 2) in the simvastatin group compared to slight increases (periods 1 and 2) in placebo group.
de Jongh 2002b Fair Netherlands | Simvastatin | 50 | 9 to 18 | 28 weeks | Growth, blood pressure, ALT, AST, CK | No effects on BMI and blood pressure. No clinical AEs reported. | No significant effects on ALT, AST, and CK levels.
McCrindle 2003 Good U.S., Canada, Europe, South Africa | Atorvastatin | 187 | 10 to 17 | RCT: 26 weeks Open label: 26 weeks | Blood pressure, physical exam, hemoglobin, hematocrit, red blood cell count, white blood cell count, platelet count, AST, ALT, CK, alkaline phosphatase, blood urea nitrogen, creatinine, uric acid, albumin, total protein, glucose | No effect on sexual development. Most AEs were mild or moderate; no statistically significant differences between atorvastatin and placebo group for any clinical AEs. Clinical AEs in atorvastatin group included abdominal pain (n=6), accidental injury (n=13), fever (n=2), flu syndrome (n=9), headache (n=13), infection (n=27), and pharyngitis (n=9). | Increase in AST levels (n=2) and ALT levels (n=1) in atorvastatin group. No participants withdrew or stopped medications as a result of increased transaminase levels.
Gandelman 2011 Fair Greece, Norway, and Canada | Atorvastatin | 39 | 6 to 17 | 8 weeks | Growth, sexual development, hematology, biochemical tests, AST, ALT, CK, urinalysis, ECG, blood pressure, and pulse | No difference in safety or tolerability between younger and older cohorts. No deaths, serious AEs, or premature discontinuations. Clinical AEs in both cohorts combined included nasopharyngitis (n=3), viral upper respiratory tract infection (n=3), headache (n=3), gastroenteritis (n=2), abdominal pain (n=1), nausea (n=1), toothache (n=1), vomiting (n=1), and other^**^ | No difference in safety or tolerability between younger and older cohorts. Increased ALT (n=2), with one of the participants returning to normal ALT during study period. Increased blood creatinine (n=1) attributed to reduced water intake.
Avis 2010 Good Europe and North America | Rosuvastatin | 176 | 10 to 17 | RCT: 12 weeks Open label: 40 weeks | Growth, sexual development, AE reports, blood count, albumin, total protein, liver enzymes, bilirubin, CK, blood urea nitrogen, serum creatinine, calcium, fasting glucose, TSH, urinalysis, phosphorus, potassium sodium, glycosylated hemoglobin | No effect on growth or sexual development. During RCT period, clinical AEs in rosuvastatin groups included headache (n=22), nasopharyngitis (n=17), influenza (n=4), myalgia (n=4), and nausea (n=4). During open-label period, clinical AEs in rosuvastatin groups included vesicular rash that progressed to cellulitis (n=1) and myalgia (n=5). Overall, safety profile of rosuvastatin was similar to that of placebo. | During RCT period, lab AEs in rosuvastatin groups included transaminase (n=3) and CK elevation (n=4). Changes in ALT, AST, and CK were similar among groups. During open-label period, lab AEs in rosuvastatin groups included transaminase (n=1) and CK elevation (n=4). For all patients, transaminase and CK elevations normalized while continuing treatment or remained normal after resuming treatment. No clinically meaningful renal abnormalities observed.
Avis 2011 Good Netherlands | Rosuvastatin | 29 | 10 to 17 | RCT: 12 weeks Open label: 40 weeks | PBMC CoQ10, plasma CoQ10, ATP synthesis | Not reported | Subjects taking rosuvastatin experienced a significant decrease in both PBMC CoQ10 and plasma CoQ10 concentrations; however, the changes are of unclear clinical significance. No change in ATP synthesis.
Braamskamp 2015c Good Netherlands, Canada, Belgium, Norway, U.S. CHARON | Rosuvastatin | 198 | 6 to 17 | 2 years | Growth, sexual development, AE reports, AST, ALT, urine protein: creatine ratio, CK, ECG | No effect on growth or sexual development. Most commonly reported clinical AEs possibly related to treatment included GI disorders (8%), myalgia (2%), and skin disorders (1%). 3 patients experienced treatment-related AEs that led to discontinuation (nausea, migraine, paraesthesia). No cases of myopathy or rhabdomyolysis and no deaths. No abnormal ECG or vital signs. | No clinically important changes in hematology, clinical chemistry, or hepatic, skeletal muscle, and renal biochemistries. Lab AEs included elevated CK levels without associated muscle symptoms (n=3), elevated creatinine (n=1), and elevated urine protein:creatinine ratio (n=7, 5 of whom returned to normal levels by study completion). No patients had abnormal eGFR.
Sinzinger 2004 Fair Austria | Various statins | 6^††^ | 13 to 20^††^ | 8 years | Blood samples for CK and liver enzymes (GGT, AST, ALT) drawn at monitoring intervals | On average, subjects reported muscle pain in 80% of periods of statin therapy (mean time of onset was 6.2 days)^††^ | Elevated CK level in 2 subjects; no increase in liver enzyme levels.^††^
Nonstatins
Tonstad 1996b Good Norway | Colestipol | 66 | 10 to 16 | RCT: 8 weeks Open label: 52 weeks | Physical exam, growth, sexual development, nutrient levels | No effects on growth or sexual development; in colestipol group, subjects reported GI side effects (n=8), including constipation, nausea, dyspepsia, flatulence, decreased appetite, and abdominal pain. | After 8 weeks, colestipol group experienced reduced serum folate, serum vitamin E, and carotenoid levels (significant compared with placebo). After 1 year, vitamin D levels decreased more in subjects who took ≥80% of dose compared with subjects taking <80% of dose.
Tonstad 1996a Fair Norway | Cholestyramine | 72 | 6 to 11 | 52 weeks | Physical exam, growth, sexual development, nutrient levels, hemoglobin, AST, ALT, TSH, free thyroxine, ferritin, erythrocyte | No effects on growth or sexual development; clinical AEs reported in cholestyramine group include intestinal obstruction caused by adhesions (n=1), nausea (n=2), loose stools (n=2), and abdominal pain (n=2). Unpalatability, headaches, and vomiting were reasons for withdrawals. | No effects on hemoglobin or liver enzyme levels. Compared with placebo group, cholestyramine group experienced significant decrease in vitamin D (among subjects not taking multivitamin) and significant increase in total homocysteine (which was negatively correlated with serum folate at baseline and 1 year).
Stein 2010 Good International multicenter | Colesevelam | 194 | 10 to 17 | RCT: 8 weeks Open label: 18 weeks | Vital signs, physical exam, laboratory safety, chemistry, and hematologic studies, urinalysis, LH, TSH, FSH, testosterone, estradiol, fat-soluble vitamins, clotting factors, hsCRP | No effects on growth or sexual development. During RCT period, distribution of AEs was similar in all groups. Most common drug-related AE in colesevelam groups was GI symptoms (n=9) (including diarrhea, nausea, vomiting, and abdominal pain). During open-label period, reported AEs included headaches (n=14), nasopharyngitis (n=10), and upper respiratory infection (n=9). | No clinically meaningful changes in safety lab measurements, hormones, vitamins, or clotting factors.
van der Graaf 2008 Good Netherlands, U.S., Canada | Ezetimibe + simvastatin | 248 | 10 to 17 | RCT: 33 weeks Open label: 20 weeks | Physical exam, ECG, growth, sexual development, menstrual periods, AE reports, hormone assessments, thyroid function tests, blood chemistries, hematology, urinalysis | No effects on growth or sexual development. Clinical AEs in ezetimibe + simvastatin groups include nasopharyngitis (n=27), headaches (n=16), myalgia (n=7), diarrhea (n=9), nausea (n=8), abdominal pain (n=6), and pharyngolaryngeal pain (n=6). AEs leading to discontinuation were myalgia (n=2), nausea (n=1), and muscle spasms (n=1). | CK elevation 10 times or greater than upper limit of normal without associated muscle symptoms (n=2); transaminase elevations at least 3 times upper limit of normal (n=6); no effects on steroid hormones. AEs leading to discontinuation were increased ALT (n=2) and increased CK (n=2).
Kusters 2015 Good 9 countries | Ezetimibe | 138^‡^ | 6 to 10 | 12 weeks | Physical exam, ECG, ALT, AST, CK, nutrient levels, abnormal liver function, rhabdomyolysis or myopathy, hypersensitivity, cholecystitis/cholelithiasis, pancreatitis | No notable differences between ezetimibe and placebo groups for any AEs, drug-related AEs, serious AEs, or AEs leading to discontinuation. No serious drug-related AEs reported. Minor AEs in ezetimibe group include headache (n=1), proteinuria (n=1), prurigo (n=1), and rash (n=1). | No notable differences between ezetimibe and placebo groups for any hematology, blood chemistry, or urinalysis measures assessed. Lab AEs in ezetimibe group included elevated ALT more than 3 times the upper limit of normal (n=1).

* N=205 participants included for tolerability analysis. N=188 included for adherence analysis.

† Age range of participants with FH at baseline. Age ranges for participants with FH and their siblings not reported at 10 years.

‡ 13 nonFH participants (9 in treatment group, 4 in placebo group) were not analyzed separately.

§ Other = frequent urination (×2), weight reduction, hair loss, and forgetfulness.

** Other (n=1 each) includes pain, bronchopneumonia, ear infection, gastritis viral, influenza, lower respiratory tract bacterial infection, tonsillitis, viral rhinitis, hand fracture, arthralgia, musculoskeletal pain, pain in extremity, asthma, rhinitis allergic, and urticarial.

†† Sinzinger 2004 study included 22 participants ages 13 to 35 years. In this table, we report data from a pediatric subgroup of this population (n=6; age range, 13–20).

Abbreviations: FH=familial hypercholesterolemia, TSH= thyroid-stimulating hormone, ACTH=adrenocorticotropic hormone, ALT=alanine transaminase, AST=aspartate transaminase, CK=creatine kinase, PC=pravastatin + colestipol group, CO=colestipol only group, AE=adverse effects, DHEAS=dehydroepiandrosterone sulfate, GI=gastrointestinal, FSH=follicle-stimulating hormone, LH=luteinizing hormone, ENT=ear, nose, and throat, GGT=gamma-glutamyl transpeptidase, hsCRP=high-sensitivity C-reactive protein, ECG=electrocardiography, eGFR=estimated glomerular filtration rate, CoQ10=coenzyme Q10, ATP=adenosine triphosphate.

#### Included Populations

The 18 included trials ranged in size from 6 to 248 children or adolescents with FH. Specific information on recruitment of subjects was not available for many studies; however, in most of those studies for which this was reported, subjects had already been diagnosed with FH and were often drawn from a specialty clinic population. Age at baseline ranged from 6 to 18 years; mean age ranged from 6 to 16 years. All but two studies included between 31 and 65 percent female subjects; the remaining two included exclusively female subjects60 or male subjects.61 Four studies (eight publications) were conducted in the Netherlands,52, 66, 70, 72, 74, 76-78 two studies (two publications) were conducted in Norway,55, 56 and one study each was conducted in the United States,60 Canada,71 Finland,68 Austria,69 and France.73 Nine studies were conducted at multiple sites in two or more countries in North America, Europe, Africa, and/or Australia.58, 59, 61-65, 75, 79 Identified countries involved in these studies include the United States (six studies), Canada (six), the Netherlands (four), Norway (four), Israel (two), South Africa (two), Australia, Austria, Belgium, Colombia, Costa Rica, the Czech Republic, France, Greece, Hungary, Italy, New Zealand, Slovakia, and Spain (one each). In these studies, the percentage of Caucasian subjects ranged from 80 to 100 percent. A case definition of FH was provided for all but one63 study. Specific diagnostic criteria for FH varied from study to study but in all cases included either genetic testing or clinical criteria identical or similar to one of the three most-commonly cited diagnostic criteria (Appendix D).

#### Included Interventions

Among the statin trials, there were five trials of pravastatin: two RCTs52, 66 (six publications), two observational trials of pravastatin,68, 73 and one randomized crossover trial of combination therapy with colestipol and pravastatin.71 There were two RCTs of lovastatin60, 61 and one RCT (two publications) of simvastatin.62, 70 Two statins, atorvastatin63, 75 and rosuvastatin,64, 79 each had two trials, an RCT and an open-label trial. Finally, there was one observational cohort study of various statins.69 The longest followup periods for statin studies were reported in a 48-week lovastatin RCT,61 a 2-year open-label rosuvastatin trial,79 and the Dutch Pravastatin Trial (a 2-year RCT with followup at 10 years).66

Studies evaluating harms of nonstatin medication included three RCTs of bile-sequestering medications: colesevelam,65 cholestyramine,55 and colestipol.56 There were two trials of ezetimibe: one RCT of simvastatin coadministered with ezetimibe58 and one RCT of ezetimibe monotherapy.59 The longest of these nonstatin studies were two year-long RCTs: the cholestyramine trial and the trial of ezetimibe with simvastatin.

Two studies included for assessment of harms involved a statin and a nonstatin. The trial of pravastatin vs. placebo (in youth treated with colestipol)71 is discussed in the section on statins. The trial of ezetimibe vs. placebo (in youth treated with simvastatin)58 is discussed in the section on nonstatin medications.

#### Quality

All included studies were fair- to good-quality. Among studies of statins, eight studies (13 publications) were good-quality and five studies (six publications) were fair-quality. The quality issues most often found in the fair-quality studies were lack of a control group, inadequate description of methods, and a followup of less than 90 percent. Four good-quality and one fair-quality studies assessed harms of nonstatin medication treatment. The primary concern with the fair-quality studies was a low rate of followup. The two studies of combination therapy with a statin and a nonstatin medication were both of good quality.

#### Summary of Findings

The 18 studies included 2,210 children and adolescents, 2,197 of whom had FH.

##### Statins

There were 13 studies (19 publications) on harms of statins, including 1,492 children and adolescents. The shortest intervention durations were 8 to 12 weeks (four studies) and the longest was 2 years (one RCT). Few studies conducted followup assessments beyond the intervention period. One study (the 2-year RCT) provided the longest followup data (10 years) for a group of whom almost all were treated with statins for much of the 10-year period. Dosage varied within and between studies, with some including an open-label phase with all subjects on active medication.

Most studies reported data on clinical adverse events (AEs) and laboratory abnormalities, and several studies of statins monitored growth and pubertal development. In many studies, reporting of harms assessment did not mention which harms were assessed, only those that were noted to have occurred. Statins were generally well-tolerated. There was no evidence of a consistent association between a particular subjective harm and statin use in general (Tables 8 and 9).

Table 8 Laboratory Harms Reported in Studies of Medication in Children and Adolescents With Familial Hypercholesterolemia (Statins, Bile-Sequestering Agents, and Other Drugs)

Author, Year | Exposure | N | Abnormal CK | Transaminase elevation^*^ | Abnormal ALT | Abnormal AST | Liver function labs | Endocrine reproductive labs | Miscellaneous labs
Pravastatin
Knipscheer, 1996^68^ | Pravastatin | 72 | + | + | + | + | + | - | NR
McCrindle, 2002^71^ | Pravastatin + Colestipol | 36 | NR | NR | NR | NR | NR | NR | NR
Hedman, 2003^68^ | Pravastatin | 20 | - | NR | - | - | NR | NR | NR
Wiegman, 2004^66^ | Pravastatin | 214 | - | NR | - | - | NR | - | NR
Rodenburg, 2007^76^ | Pravastatin | 186 | + | NR | NR | NR | NR | + | NR
Kusters, 2014^72^ | Pravastatin | 194 | NR | NR | NR | NR | NR | NR | -
Braamskamp, 2015a78 | Pravastatin | 205^†^ | - | - | - | - | - | NR | NR
Braamskamp, 2015b77 | Pravastatin | 88 | NR | NR | NR | NR | NR | - | NR
Carreau, 2011^73^ | Pravastatin | 185 | + | NR | NR | NR | NR | NR | NR
Lovastatin
Stein, 1999^61^ | Lovastatin | 132 | NR | NR | NR | NR | NR | NR | NR
Clauss, 2005^60^ | Lovastatin | 54 | - | NR | - | - | NR | - | -
Simvastatin
De Jongh, 2002a62 | Simvastatin | 173 | + | + | + | - | + | - | -
De Jongh, 2002b70 | Simvastatin | 50 | - | NR | - | - | NR | NR | NR
Atorvastatin
McCrindle, 2003^63^ | Atorvastatin | 187 | NR | + | NR | + | + | NR | NR
Gandelman, 2011^75^ | Atorvastatin | 39 | NR | + | + | NR | + | NR | NR
Rosuvastatin
Avis, 2010^64^ | Rosuvastatin | 176 | + | + | NR | NR | + | NR | NR
Avis, 2011^74^ | Rosuvastatin | 29 | NR | NR | NR | NR | NR | NR | +
Braamskamp, 2015c79 | Rosuvastatin | 198 | + | - | - | - | - | - | +
Various statins
Sinzinger, 2004^69^ | Various statins | 6^‡^ | + | NR | NR | NR | - | NR | NR
Bile-Sequestering Agents
Tonstad, 1996b56 | Colestipol | 66 | NR | NR | NR | NR | NR | NR | NR
Tonstad, 1996a55 | Cholestyramine | 72 | NR | NR | NR | NR | NR | - | -
Stein, 2010^65^ | Colesevelam | 194 | + | NR | NR | NR | NR | NR | NR
Other
van der Graaf, 2008^58^ | Ezetimibe + simvastatin | 248 | + | + | + | NR | + | NR | NR
Kusters, 2015^59^ | Ezetimibe | 138 | - | NR | + | - | + | NR | -

* Transaminase elevation was considered reported if the author specifically mentioned transaminase elevation.

† N=205 participants included in tolerability analysis. N=188 participants included in adherence analysis.

‡ Sinzinger 2004 study included 22 participants ages 13–35. In this table, we report data from a pediatric subgroup of this population (n=6; age range, 13–20).

Abbreviations: FH=familial hypercholesterolemia, CK=creatine kinase, ALT=alanine transaminase, AST= aspartate transaminase, NR=not reported.

Table 9 Clinical Harms Reported in Studies of Medications in Children and Adolescents With Familial Hypercholesterolemia (Statins, Bile-Sequestering Agents, and Other Drugs)

Author, Year | N | Loose stool/diarrhea | GI | Neuropsychiatric | ENT | Respiratory | Dermatologic | Musculoskeletal | Endocrine | Immunologic | Systemic | Infection NOS | Pain NOS | Misc
Pravastatin
Knipscheer, 1996^52^ | 72 | NR | + | + | + | NR | + | NR | NR | NR | NR | NR | NR | NR
McCrindle, 2002^71,*^ | 36 | NR | + | + | NR | NR | NR | + | - | NR | NR | NR | NR | NR
Hedman, 2003^68^ | 20 | + | NR | + | NR | NR | NR | + | NR | NR | NR | NR | + | NR
Wiegman, 2004^66^ | 214 | NR | NR | - | NR | NR | NR | NR | - | NR | NR | NR | NR | NR
Rodenburg, 2007^76^ | 186 | NR | NR | NR | NR | NR | NR | + | - | NR | NR | NR | NR | NR
Kusters, 2014^72^ | 194 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Braamskamp, 2015a78 | 205^†^ | NR | + | + | NR | NR | + | + | NR | NR | NR | NR | NR | +
Braamskamp, 2015b77 | 88 | NR | NR | NR | NR | NR | NR | NR | - | NR | NR | NR | NR | NR
Carreau, 2011^73^ | 185 | NR | NR | + | NR | NR | NR | + | - | NR | NR | NR | + | NR
Lovastatin
Stein, 1999^61^ | 132 | + | + | NR | + | + | + | + | - | + | NR | NR | NR | NR
Clauss, 2005^60^ | 54 | + | + | + | + | + | NR | NR | - | NR | NR | NR | NR | NR
Simvastatin
De Jongh, 2002a62 | 173 | NR | + | + | NR | NR | + | + | - | NR | + | NR | + | NR
De Jongh, 2002b70 | 50 | NR | NR | NR | NR | NR | NR | NR | - | NR | NR | NR | NR | NR
Atorvastatin
McCrindle, 2003^63^ | 187 | NR | NR | + | + | + | NR | NR | - | NR | + | + | NR | +
Gandelman, 2011^75^ | 39 | NR | + | + | + | + | NR | NR | NR | NR | NR | NR | NR | NR
Rosuvastatin
Avis, 2010^64^ | 176 | NR | + | + | + | + | + | + | - | NR | NR | NR | NR | NR
Avis, 2011^74^ | 29 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Braamskamp, 2015c79 | 198 | NR | + | + | + | + | + | + | - | NR | + | + | NR | NR
Various statins
Sinzinger, 2004^69^ | 6^§^ | NR | NR | NR | NR | NR | NR | + | NR | NR | NR | NR | NR | NR
BSA (colestipol)
Tonstad, 1996b56 | 66 | + | + | NR | NR | NR | NR | NR | - | NR | NR | NR | NR | NR
BSA (cholestyramine)
Tonstad, 1996a55 | 72 | + | + | + | NR | NR | NR | NR | - | NR | NR | NR | + | NR
BSA (colesevelam)
Stein, 2010^65^ | 194 | + | + | + | + | + | NR | NR | - | NR | + | NR | NR | NR
Ezetimibe
van der Graaf, 200858^‡^ | 248 | + | + | + | + | + | + | + | - | NR | NR | NR | NR | -
Kusters, 2015^59^ | 138 | + | + | + | + | + | + | - | NR | + | + | + | NR | NR

* Study assessed pravastatin + colestipol vs. colestipol only.

† N=205 participants included in tolerability analysis. N=188 participants included in adherence analysis.

‡ Study assessed ezetimibe + simvastatin vs. placebo + simvastatin.

§ Sinzinger 2004 study included 22 participants ages 13–35. In this table, we report data from a pediatric subgroup of this population (n=6; age range, 13–20).

Abbreviations: FH=familial hypercholesterolemia, BSAs=bile-sequestering agents, GI=gastrointestinal, ENT=ear, nose, and throat, NOS=not otherwise specified, Misc=miscellaneous.

Serious AEs were rare. In controlled studies with a placebo group, the frequency of reported AEs usually did not differ significantly from those in placebo. The most common AEs were otorhinolaryngologic (mostly nasopharyngitis), gastrointestinal (predominantly abdominal pain, nausea/vomiting, and diarrhea), respiratory (mostly respiratory infection and influenza), and neurological (predominantly headache). Statins were well-tolerated, with 98.5 percent of young adults still taking statin medications 10 years after beginning a clinical trial.78 In this same study, adherence was good, with 78.7 percent reporting taking more than 80 percent of their medications. Most studies did not report on statistical significance of difference in rates for individual AEs between study groups. Those that did generally reported no significant associations. The most frequently reported AEs (Table 9) were generally not believed to be associated with medication use. Systemic, immunologic, and pain-related AEs were reported only sporadically in these studies (<10 reports per study).

In one small, uncontrolled study of statins in six professional athletes with FH (mean age, 16.8 years [SD, 2.6 years]), three subjects reported muscle pain on all five statins tried, and three reported muscle pain on three of the five statins tried.69 However, musculoskeletal pain was infrequently reported in other studies, occurring in only 4.8 percent (56 of 1,018) of subjects taking statins in studies that reported these data. Musculoskeletal pain, myalgia, and muscle pain were reported as AEs in 10 statin studies. The incidence ranged between 0 and 10 percent for those on statins (and between 0% and 6.2% for those in the placebo groups). The incidence of musculoskeletal pain, myalgia, and muscle pain was not reported as being significantly different from control subjects in any studies for which this information was available.

All but two of the 13 statin studies assessed liver transaminase and creatine kinase (CK) concentrations as part of their safety assessment. Concentrations were checked at baseline and conclusion; many studies also included checks at scheduled intervals during treatment. Five of the 13 studies reported no abnormalities of either CK or transaminases. In the eight studies that did, the abnormalities were usually transient, with concentrations usually resolving either spontaneously or after temporary withdrawal of the medication (Table 8).

Ten statin studies also assessed the impact of treatment on growth and pubertal development in children or adolescents, either through physical examination and measurement, laboratory screening, or both.52, 60-64, 66, 72, 73, 76 No studies suggested an important association between statin use and abnormalities in any of these outcomes.

Ten-year followup of the Dutch Pravastatin Trial measured sex hormones in young men and women (mean age, 24 years) with FH who had participated in the initial 2-year pravastatin trial, followed by continued use of pravastatin and other statins over the intervening years. Compared to their brothers without FH, the young men with FH in this study treated with statins had lower mean dehydroepiandrosterone sulfate (DHEAS) concentrations, although values were still within the normal range. These elevations are of unclear clinical significance.

##### Bile-Sequestering Agents

Three RCTs evaluated the harms of monotherapy with three different bile-sequestering agents (colesevelam,65 cholestyramine,55 and colestipol56) in a total of 332 children and adolescents with FH. Two were 8-week trials and one lasted 1 year. The most common drug-related AEs were gastrointestinal. Abdominal pain, diarrhea, nausea, or vomiting were reported by 7 to 10 percent (calculated from reported data) of subjects in the two studies that reported data from the placebo-controlled period. However, these rates were similar to those reported in the placebo groups (4.6% to 5%, calculated).55, 65 The studies on colestipol and cholestyramine both note that unpalatability was a marked problem and caused 14 subjects to withdraw from the cholestyramine study. However, unpalatability was also often reported in the placebo group in the same study, in which 10 subjects withdrew.

The most notable laboratory abnormalities were decreased vitamin D concentrations in treated subjects (compared to placebo) in the cholestyramine study and, to a lesser extent, in the colestipol study. Folate concentrations were lower in subjects treated with colestipol than in those on placebo, and homocysteine was increased in subjects treated with cholestyramine, concentrations of which were negatively correlated with folate concentrations at baseline and at 1 year.55, 56 No marked laboratory abnormalities were reported in the colesevelam trial, although it is not clear which safety factors were measured.

##### Ezetimibe

Two RCTs evaluated harms of ezetimibe in 373 children and adolescents with FH. One was a 12-week trial of monotherapy and the other a 52-week trial of ezetimibe coadministered with simvastatin.58 In the year-long study,58 alanine aminotransferase (ALT) elevations occurred in 5 percent of participants in the simvastatin plus ezetimibe group and 2 percent of those in the simvastatin-only group. Laboratory values normalize with discontinuation of treatment. Most AEs and their rates were similar between groups: gastrointestinal symptoms, elevated transaminase concentrations (that resolved following interruption of therapy), and myalgia without associated CK elevation. The 12-week ezetimibe monotherapy trial59 found no significant difference in AE distribution between study groups and no serious AEs in either group.

#### Detailed Results

Studies are listed here by class and drug, then chronologically by date of the publication of the original study. All publications for a given study are considered together.

##### Statins

Pravastatin. Four trials evaluated harms of pravastatin use in children with FH, including the Dutch Pravastatin Trial that produced five publications that addressed harms with up to 10 years followup. A fifth trial used a randomized crossover design to evaluate pravastatin in children treated with colestipol.71

In a 12-week good-quality RCT, 72 children ages 8 to 16 years with FH in the Netherlands were randomly assigned to placebo or to one of three pravastatin doses (5 mg, 10 mg, or 20 mg daily).52 Physical examinations were performed at the beginning and end of the study, and fasting blood samples (hematology, ALT, aspartate aminotransferase [AST], CK, alkaline phosphatase, urinalysis, thyroid-stimulating hormone, cortisol, and adrenocorticotropic hormone) were measured monthly. The incidence of laboratory abnormalities did not differ significantly between groups. The most common AEs were gastrointestinal symptoms and headache; both these and other sporadic complaints (rash, fatigue, epistaxis, and myalgia) were equally distributed between the placebo and treatment groups. None were believed to be medication-related. (Note: This trial was conducted in the Netherlands; however, we use the shorthand term “Dutch Pravastatin Trial” to refer to a separate study by Wiegman and colleagues—described below—which was a larger trial with longer followup.)

In a good-quality randomized crossover trial of colestipol combined with pravastatin,71 36 youth ages 9 to 18 years received either colestipol alone (10 g/day) or low-dose colestipol (5 g/day) in combination with pravastatin (10 mg/day). This Canadian study consisted of an 8-week period without lipid-lowering medication followed by two 18-week treatment periods. Subjects crossed over to the alternate regimen after the first treatment period. Serum chemistries and blood counts were assessed at baseline and 2 weeks, 8 weeks, and 18 weeks into each treatment period. Alkaline phosphatase concentrations were significantly decreased in both treatment regimens at 2 and 8 weeks, but the decrease was significant only in the colestipol-only group at 18 weeks. The absolute reduction in ALT concentrations from baseline was significantly greater in the colestipol-only group than in the combination group at 8 and 18 weeks. No significant changes or differences between regimens were reported for CK, AST, other blood chemistries, or hematologic values. Increases in weight, height, and body mass index did not differ significantly between groups. Subject-reported AEs were more common in the higher-dose colestipol-only group than in the combination group: constipation occurred in 21 percent of subjects on colestipol only versus 3 percent of subjects on the combination regimen, bloating/gas in 15 versus 3 percent, stomach ache in 21 versus 0 percent, headache in 14 versus 3 percent, and muscle ache in 6 versus 3 percent, respectively.

One fair-quality, prospective observational study examined the pharmacokinetics and pharmacodynamics of pravastatin in Finnish children with FH.68 Twenty children with FH ages 4 to 15 years received 10 mg pravastatin daily for 8 weeks. Subjects indicated AEs (gastrointestinal symptoms, headache, skin reactions, sleep disturbance, muscle/tendon tenderness, and pain) each day on a home questionnaire, and laboratory values (creatinine, ALT, and CK) were measured at baseline, 4 weeks, and 8 weeks. Laboratory values did not increase during the study. Other AEs were rare: four reports of headache, two reports of sleep disturbance, and one report each of abdominal pain, loose stool, muscle tenderness at rest, and muscle tenderness with activity.

The Dutch Pravastatin Trial was the largest RCT of a statin in youth with FH and also the single trial in this review with the longest followup (10 years). In this RCT, 214 children with FH ages 8 to 18 years were randomly assigned to receive either placebo or pravastatin (20 mg daily for children age <14 years, 40 mg daily for those age ≥14 years) for 2 years.66 Subjects were evaluated by a physician every 6 months. Sex steroids, gonadotropins, and pituitary-adrenal axis markers were measured at baseline and at 1 and 2 years into the study; developmental and maturation indices were measured at the same times: growth (height, weight, body mass index, and body surface area), pubertal development (Tanner stage, menarche, and testicular volume), and academic progress (school records). Muscle and liver enzymes (ALT, AST, and CK) were measured at baseline, at 3 month intervals in year 1, and at 6 month intervals in year 2. CK concentrations were increased by more than a factor of 4 in four subjects in the intervention group and in three subjects in the placebo group; however, at the end of the trial, the groups had no relevant differences in CK or transaminase concentrations. Groups also did not differ in measures of endocrine function or in the aforementioned growth and maturation markers, and academic performance was not affected.

At the end of 2 years, all participants in the Dutch Pravastatin Trial intervention and control groups were combined and all participants were treated with pravastatin (20 to 40 mg daily) and followed for varying periods (duration of statin therapy ranged from 2.1 to 7.4 years). Of the 186 subjects included in this fair-quality study,76 83 percent were still using pravastatin at the time of followup. No serious laboratory abnormalities were noted on followup. Two subjects had CK concentrations greater than 10 times normal. However, these elevations were considered to be associated with extreme fitness regimens, and they resolved without discontinuing treatment. Myalgia without CK elevation occurred in four subjects. Four subjects (three male, one female) had mildly elevated follicle-stimulating hormone concentrations, three had decreased DHEAS concentrations, and two had mildly elevated adrenocorticotropic hormone concentrations. None of these changes were thought to be related to statin use.

The authors assessed Dutch Pravastatin Trial participants for harms at 10 years postrandomization and published findings in three articles.72, 77, 78 In the main 10-year adherence and tolerability analysis, 205 patients were available for followup (mean age, 24 years).78 Tolerability was 98.5 percent over the 10 years; three out of 205 subjects had discontinued medications due to side effects (gastrointestinal, muscle and joint pain, or headache). There were 55 side effects reported over 10 years by 40 subjects (19.5%), mainly consisting of muscle complaints and gastrointestinal symptoms. There were no reports of rhabdomyolysis or elevation of liver enzymes. By 10 years, 17 participants had had discontinued lipid-lowering medications due to pregnancy, lactation, and/or the advice of a physician, and 19 participants had chosen to discontinue the medication on their own. Among the 169 participants still taking lipid-lowering medications, 99 percent were on various statins and 36 percent were on ezetimibe. Most (78.7%) subjects reported adherence of greater than 80 percent in the previous month.

The last two articles from the Dutch Pravastatin Trial included the 214 patients with FH and 95 unaffected siblings who had been recruited at the conclusion of the 2-year RCT. One72 of these two sibling comparison studies evaluated 194 participants (91% followup) and 83 siblings (87% followup) 10 years after randomization. All participants were ages 18 to 30 years at that time. In this study, 163 subjects were still using lipid-lowering medications at 10 years (31% pravastatin; 15% simvastatin; 27% rosuvastatin; 27% atorvastatin). Growth, maturation, level of education, history of AEs, liver transaminases, CK, glomerular filtration rate, and C-reactive protein were assessed. Subjects and unaffected siblings did not differ remarkably on any outcomes (except for extremely elevated CK concentrations in two unaffected siblings). Three subjects discontinued statin therapy because of unspecified AEs. No serious major AEs were reported.

Comparison with these siblings also formed the basis of a study77 examining the possible effects of statins on sex hormones, including testosterone, estradiol, luteinizing hormone, follicle-stimulating hormone, and DHEAS concentrations after 10 years. There were 88 participants with FH and 62 siblings available for this analysis. The only significant difference between siblings and those with FH was for DHEAS, which was significantly lower in the males with FH (8.4 μmol/L [SD, 3.0 μmol]) than in their brothers without FH (12.9 μmol/L [SD, 4.9 μmol]; p<0.001). The authors note that despite this difference, the mean DHEAS concentration in the FH group was still within the normal range.

The final pravastatin study was an observational analysis of the medical records of 185 French children age 18 years and younger with FH (mean age, 11 years) who were being treated with pravastatin at varying doses.73 Subjects were followed for 3 months to 7 years. Of the 185 patients, 24 (13%) experienced AEs: four reported muscular pain that resolved after changing to a new statin; three others had muscle pain not apparently associated with treatment; and 12 had musculoskeletal pain (two with associated moderate CK elevation) that resolved spontaneously. Other AEs included asymptomatic CK elevation (eight subjects), transient headache (one), and gynecomastia with normal hormone concentrations (one). No subjects had elevated transaminase concentrations and no instances of growth problems, early maturation, or delayed puberty were observed.

Lovastatin. Two good-quality RCTs evaluated harms of lovastatin in children with FH. One trial, conducted in the United States and Finland, randomly assigned 132 boys ages 10 to 17 years with FH to either placebo or daily lovastatin (initially at a dose of 10 mg, titrated after 8 and 16 weeks to 20 mg and 40 mg, respectively, then maintained at 40 mg for the remaining 32 weeks of the study).61 AEs were reported by 70.1 percent of subjects in the lovastatin group and by 73.8 percent in the placebo group. AEs reported in the lovastatin group included gynecomastia (1.5%); respiratory tract infection (47.8%); abdominal pain (10.4%); ear, nose, and throat infection (10.4%); skin disease (9.0%); gastroenteritis (7.5%); lymphadenopathy (3.0%); myalgia (4.5%); diarrhea (1.5%); and arthropathy (1.5%). The frequencies of these AEs did not differ significantly from those in the placebo group. Both the lovastatin and placebo groups had a statistically significant increase in ALT at 48 weeks; however, ALT concentrations did not differ significantly between the two groups. No sustained changes in AST or CK were noted in either group, although nonsustained CK elevations (>5 times the upper limit of normal) were noted in three subjects in the lovastatin group and in one subject in the placebo group. These elevations were reported to be associated with vigorous or unusual exercise. Participants reported no associated muscle pain. Indices of growth and development did not differ between groups.

In the other, a U.S. study, 54 postmenarchal girls (ages 11 to 18 years) were randomly assigned to receive placebo or lovastatin 20 mg or 40 mg daily for 24 weeks.60 Just over two-thirds of the girls in both the lovastatin and placebo groups reported AEs; among these, the most common were upper respiratory infection (29% of girls on lovastatin, 47% of girls on placebo), headache (20% and 21%, respectively), and pharyngitis (17% and 11%, respectively); 11 percent of lovastatin subjects also reported an influenza-like disease. Three girls (9%) in the lovastatin group had AEs believed to be treatment-related: two girls (6%) with abdominal pain, one with diarrhea, one with nausea, and one with headache. All treatment-related AEs resolved spontaneously while patients continued on study medication. The only laboratory AE reported was a decrease in hemoglobin and hematocrit in one subject taking 40 mg of lovastatin. This AE was believed to be unrelated to treatment. Luteinizing hormone concentrations decreased in subjects on placebo but were unchanged in those on lovastatin. No significant between-group differences or changes from baseline were noted for other hormones (follicle-stimulating hormone, cortisol, estradiol, or DHEAS), AST, ALT, CK, height, weight, body mass index, or vital signs (except a small decrease in systolic blood pressure in the placebo group).

Simvastatin. One good-quality RCT (two publications) evaluated the safety of simvastatin for treating children with FH in the Netherlands. This trial randomly assigned 173 children ages 10 to 17 years with FH to receive simvastatin or placebo.62 Simvastatin dose in the first phase was 10 mg/day for 8 weeks, with subsequent increase to 20 mg for 8 weeks and then to 40 mg for 8 weeks. Subjects then continued at a dose of 40 mg/day for an additional 24 weeks. Drug-related laboratory AEs occurred in two subjects on simvastatin and in one subject on placebo during the first phase of the trial, and in two simvastatin and one placebo subjects during the second phase. These AEs included two cases of transaminase elevations greater than 3 times the upper limit of normal (one of which improved after a 10-day interruption in therapy, the other of which occurred in a child with infectious mononucleosis) and three cases of elevated CK concentrations. One of these three children was on concurrent erythromycin therapy and had CK levels greater than 10 times the upper limit of normal, which resolved after completing antibiotic therapy. The other two children had CK levels greater than 5 times the upper limit of normal, which returned to normal on repeat testing. Clinical AEs reported during the study included headache (in four subjects on simvastatin), abdominal pain (three subjects on simvastatin), and myalgia (two subjects on simvastatin). Other AEs (one subject on simvastatin each) included chest pain, flatulence, weight gain, sleep disorder, and pruritus. Fewer subjects on placebo reported clinical AEs (five subjects) than did those on simvastatin (10 subjects); however, none of the differences between the placebo and simvastatin groups in either phase of the study was statistically significant. There were small but statistically significant between-group differences in the absolute change of DHEA concentrations in both boys and girls at 24 and 48 weeks, but no associated growth or pubertal development abnormalities (no significant differences between groups on growth, body mass index, cortisol and hormone concentrations, or pubertal development).

A fair-quality subanalysis of this simvastatin RCT assessed harms in 50 children with FH ages 9 to 18 years who received either placebo or simvastatin 10 mg/day for 8 weeks, then 20 mg/day for 8 weeks, and then 40 mg for 8 weeks.70 Safety assessment included measuring AST, ALT, and CK and a physical examination. Laboratory values did not differ substantially between the simvastatin and placebo groups. The authors stated that no AEs were reported; no data were shown.

A different RCT58 evaluated ezetimibe in children with FH being treated with simvastatin and is discussed in the section on ezetimibe below.

Atorvastatin. Two studies evaluated harms of atorvastatin used to treat FH in children. One good-quality RCT conducted in the United States, Canada, Europe, and South Africa randomly assigned 187 youth (ages 10 to 17 years with FH or severe hypercholesterolemia) to receive atorvastatin 10 mg/day or placebo daily for 26 weeks, followed by an additional 26 weeks during which all subjects received 10 mg atorvastatin daily.63 During the RCT phase, the dose of atorvastatin could be titrated to 20 mg/day at week 4 for subjects not achieving target LDL-C levels. AEs occurred in 63 percent of the treatment group during the blinded phase and in 62 percent of the placebo group. Among subjects in the treatment group, AEs included infection (19%), accidental injury and headache (9% each), pharyngitis and flu syndrome (6% each), abdominal pain (4%), and fever (1%). All of these AEs occurred in the placebo group as well; the incidence did not differ significantly between groups. During the RCT phase, 7 percent of AEs in the atorvastatin group were judged to be treatment-related compared to 4 percent in the placebo group. AEs were mostly mild or moderate; one subject in the atorvastatin group experienced increased depression that was thought to be possibly treatment-related, and this subject discontinued treatment. Marked laboratory abnormalities were noted in 29 percent of atorvastatin subjects and in 34 percent of placebo subjects during the RCT phase. Two subjects on atorvastatin had AST elevations (3 times the upper limit of normal), and one had an ALT elevation, none of which required treatment modifications. No such abnormalities occurred in the placebo group. Indices of growth and sexual development did not differ significantly between groups, nor did the incidence or severity of treatment-related AEs increase in the second phase of the study.

One fair-quality, open-label, 8-week study assessed the tolerability of atorvastatin in 15 children ages 6 to 10 years (Tanner stage 1) and in 24 children ages 10 to 17 years (Tanner stage ≥2) with FH in Greece, Norway, and Canada.75 Initial doses were 5 mg/day for younger children and 10 mg/day for older children. Doses were doubled after 4 weeks if the target LDL-C concentration was not achieved. Indices of safety and tolerability did not differ between the younger and older groups, and no serious AEs were observed. At least one AE was reported by nine of 15 subjects in the younger group and by 13 of 24 subjects in the older group. The only AEs reported by more than one subject were viral upper respiratory infection (three subjects in Tanner stage 1 group), nasopharyngitis (one subject in Tanner stage 1 group; two subjects in Tanner stage ≥2 group), headache (two subjects in Tanner stage 1 group, one in Tanner stage ≥2 group), and increased ALT (two subjects, both in Tanner stage ≥2 group). Only four subjects (two from each group) reported AEs that were believed to be treatment-related. These AEs included one instance each of headache, abdominal pain, nausea, and vomiting in the younger group, and the two aforementioned subjects with ALT elevations in the older group (at the end of the study, ALT concentrations returned to normal in one subject and were only slightly elevated in the other.) Data on vital signs, electrocardiography, urinalysis, hematology, and biochemistry tests (including CK) were obtained at baseline and 8 weeks. The only abnormality was a moderate but transient increase in CK that was not believed to be related to treatment in one 9-year-old child.

Rosuvastatin. Two good-quality trials (three publications) evaluated the safety of rosuvastatin for treating FH in children. Authors of the first of these also published a separate analysis of a subset of trial participants.74 The PLUTO trial conducted in 20 centers in North America and Europe was a good-quality RCT that randomly assigned 176 participants with FH (ages 10 to 17 years) to receive placebo or rosuvastatin at a dose of 5 mg, 10 mg, or 20 mg daily for 12 weeks. This period was followed by a 40-week open-label phase in which dosing for all subjects was titrated to achieve target LDL-C concentrations (maximum dose, 20 mg/day).64 Safety assessment included monitoring of growth, pubertal development, solicitation of AEs, and laboratory screening (consisting of complete blood count, albumin, total protein, liver enzymes, bilirubin, CK, blood urea nitrogen, creatinine, calcium, glucose, electrolytes, thyroid-stimulating hormone, HbA1c, and urinalysis). During the first phase of the study, AEs occurred in between 50 and 64 percent of subjects on rosuvastatin (varying by dose) and in 54 percent of subjects on placebo. The most common were headache (in six to nine subjects in rosuvastatin groups and in nine subjects on placebo), nasopharyngitis (three to seven in rosuvastatin groups, five on placebo), influenza (zero to two in rosuvastatin groups, four on placebo), myalgia (one to two in rosuvastatin groups, zero on placebo), and nausea (zero to two in rosuvastatin groups, two on placebo). Blurred vision occurred in one subject on placebo, and vesicular rash occurred in one subject on rosuvastatin during the open-label period. Overall changes in AST and ALT were similar between groups, although transaminase concentrations were elevated (>3 times the upper limit of normal) in three rosuvastatin subjects on doses of 10 mg or 20 mg during the first phase and in one rosuvastatin subject in the second phase. Overall changes in CK were also similar between groups, although CK was elevated (>10 times upper limit of normal) in four rosuvastatin subjects on doses of 10 mg or 20 mg during the first phase and in four during the open-label phase. Myalgia was reported by four rosuvastatin subjects during the first phase and five during the second phase. In all subjects, transaminase concentrations, CK, and myalgia returned to normal during treatment or remained normal after treatment was restarted.

Another publication from the PLUTO trial addressed a potential harm of statins, hypothesized based on the role of HMG-CoA reductase in the synthesis of coenzyme Q10 (CoQ10). CoQ10 serves both as an electron carrier in adenosine triphosphate (ATP) synthesis and as an important cellular antioxidant. For this reason, inhibition of HMG-CoA reductase activity in the course of statin treatment could reduce endogenous CoQ10 synthesis, thus impairing mitochondrial energy metabolism and cellular antioxidant capacity. A substudy of PLUTO (conducted in the Netherlands) reports on CoQ10 concentrations in peripheral blood mononuclear cells (PBMCs) and plasma (at baseline and end of study) in 29 PLUTO participants and mitochondrial respiratory chain–driven ATP in PBMCs in 17 of these 29 subjects.74 During rosuvastatin treatment, mean PBMC CoQ10 concentrations dropped, from 89 pmol/mg (SD, 59 pmol/mg) to 63 pmol/mg (21 pmol/mg). At the end of the study, CoQ10 concentrations (corrected for baseline concentrations) differed significantly between the 5-mg and 10-mg groups but not between other treatment groups, and no dose-related effect of rosuvastatin on PBMC CoQ10 concentration was found. Although the differences were statistically significant, they were of unclear clinical significance. Proportion of participants with CoQ10 concentrations below the reference range did not change with rosuvastatin treatment. PBMC ATP synthesis did not change. Mean plasma CoQ10 concentration also decreased significantly; however, although concentrations differed between the 10-mg and 20-mg groups, they did not differ between other treatment groups, and the rosuvastatin dose at the end of the study was not associated with plasma CoQ10 concentration. Ratios of plasma CoQ10/TC and CoQ10/LDL-C remained equal during treatment. The authors concluded that the observed 32% decrease in PBMC CoQ10 level did not perturb mitochondrial respiratory chain–driven ATP synthesis in these participants.

The second rosuvastatin trial was CHARON (hyperCholesterolaemia in cHildren and Adolescents taking Rosuvastatin OpeN label), a 2-year, single-arm, open-label trial conducted in several sites in Europe and North America. 198 children and adolescents ages 6 to 17 years (mean, 11.6 years [SD, 3.3 years]) received 10 or 20 mg daily of rosuvastatin (depending on age). Incidence and severity of AEs and serious AEs, rates of discontinuation due to AEs, and abnormal serum laboratory values were recorded. Laboratory assessments included AST, ALT, urine protein:creatinine ratio, and CK. Most participants (86% to 89% across age groups) reported at least one treatment-emergent AE during the study period. The most common AEs were nasopharyngitis, headache, influenza, and vomiting. There were 29 AEs that were considered to be possibly related to the study medication, including gastrointestinal disorders, myalgia, increased serum CK, and skin disorders. Myalgia was reported in none of the 6- to 9-year olds, 7 percent of the 10- to 13-year-olds, and 10 percent of the 14- to 17-year-olds. Arthralgias were reported in 3 percent of the 6- to 9-year-olds, 10 percent of the 10- to 13-year-olds, and 5 percent of the 14- to 17-year-olds. No serious treatment-related AEs were reported. Three of 198 participants discontinued rosuvastatin due to AEs (nausea, migraine, and paresthesias).

Various statins. One Austrian study included youth treated with different statins. This fair-quality prospective clinical followup study of 22 professional adolescent and young adult athletes with FH investigated the possibility that the frequency of harms associated with statin use in athletes (muscle pain in particular) may be greater than in nonathletes with FH. Six of these subjects were age 20 years or younger, and FH had been diagnosed between 4 and 10 years earlier.69 Safety outcomes included muscle pain, CK concentrations, and liver enzymes. The six subjects were started on the lowest available dose of either pravastatin or lovastatin and subsequently switched to an alternate statin if AEs developed or target values were not met. Three of the six subjects did not tolerate any of the five statins tried (pravastatin, lovastatin, simvastatin, fluvastatin, and atorvastatin), and muscle pain developed in all six subjects 2 to 18 days after the start of treatment with at least one of the medications. Two of the six subjects experienced CK elevations while on certain statins (one subject while on pravastatin and lovastatin, one while on pravastatin, simvastatin, and atorvastatin). Muscle pain developed in all six subjects while on pravastatin and simvastatin, in five while on lovastatin, in four while on atorvastatin, and in three while on fluvastatin. Concentrations of liver enzymes did not change in any patient. Symptoms disappeared in less than a week after drug withdrawal in most patients, and within 3 weeks in all patients.

##### Nonstatin Medications

Bile-sequestering agents. Three RCTs evaluated harms of bile-sequestering medications in children and adolescents with FH. A different study (a randomized crossover trial of combination pharmacologic therapy with colestipol and pravastatin) is described above in the section on statins.71

One good-quality RCT with a followup open-label period randomly assigned 66 adolescents with FH ages 10 to 16 years to receive colestipol 10 mg daily (10 mg once a day or 5 mg twice a day) or placebo for 8 weeks. Those in the placebo group then received colestipol 10 mg daily for 1 year, and the other groups continued at their originally assigned doses for 1 year total treatment.56 Of the 42 subjects completing 1 year of colestipol treatment, eight reported AEs, including constipation (two subjects), intermittent nausea (two subjects), and one subject each for dyspepsia, flatulence, temporary reduction in appetite, and abdominal pain. Both constipation and abdominal pain improved with dose reduction. One subject lost 1 kg or more during the study, a boy with initial body mass index of 24.5 kg/m^2^. Folate concentrations decreased in the colestipol group (compared to the placebo group) during the initial 8-week phase and remained decreased after 1 year (although they were still above the laboratory's lower reference point in all but three subjects). The authors note that this decrease might be attributable to sexual maturation because the 1-year findings were not controlled. Vitamin E and carotenoid concentrations also decreased in the colestipol group during the initial 8-week phase; however, this decrease was proportionate to the decrease in cholesterol. Vitamin D concentrations did not change significantly during the initial 8 weeks, but after 1 year, vitamin D concentrations tended to be lower in the subset of subjects who took more than 80 percent of the prescribed colestipol dose than in others (p=0.07). Vitamin D, vitamin A, and vitamin-E-to-cholesterol ratio all remained above the laboratory's lower reference point in all subjects after 1 year. As with cholestyramine, poor palatability was a frequent complaint for colestipol; only 21 percent “liked the taste” of the medication.

One fair-quality, double-blind RCT evaluated harms of cholestyramine treatment in children ages 6 to 11 years with FH.55 The 96 children enrolled were instructed to follow a low-fat, low-cholesterol diet for 1 year. At that point, 72 subjects with elevated LDL-C concentrations and a family history of premature CVD who agreed to continue were randomly assigned to receive cholestyramine 8 g or placebo daily for 1 year. Of the 48 subjects completing the study, 22 were in the cholestyramine group and 26 were in the placebo group. Vitamin D concentration decreased from baseline by 30.9 percent (calculated) in the cholestyramine group and decreased by 20 percent (calculated) in the placebo group (p<0.04). None of the subjects whose vitamin D concentrations decreased below the reference range were taking daily multivitamins. Total homocysteine was increased in the cholestyramine group and was negatively correlated with folate concentrations at baseline and 1 year. One subject with an increased homocysteine concentration became folate-deficient. No differences in liver enzymes or hemoglobin were noted between groups. Height velocity and weight were not adversely affected, and no other nutritional deficiencies were observed. Carotenoid concentrations did decrease significantly (as expected with a decrease in cholesterol). Other AEs were enumerated but not statistically compared between groups. Those who completed the study reported sporadic gastrointestinal symptoms. Nausea, loose stool, or abdominal pain were reported by one to two subjects each on cholestyramine; one subject withdrew because of vomiting after taking two packets; one subject withdrew after 2 months because of headaches; and one subject who had undergone appendectomy 3 months before had an intestinal obstruction after two doses of cholestyramine. However, the frequency of AEs was similar to that in the placebo group. Three subjects on placebo reported intermittent abdominal pain. One withdrew due to vomiting for 3 weeks, and one developed appendicitis. Unpalatability (unpleasant enough to cause withdrawal from the study) was the most common report in the 14 cholestyramine subjects; however, 10 subjects in the placebo group also reported unpalatability.

One good-quality RCT evaluated harms of colesevelam treatment in children and adolescents with FH (including both statin-naïve subjects and those on a statin regimen).65 This study measured changes in vital signs, physical examination findings, and laboratory values (blood chemistry, including lipids, hematology, selected hormone concentrations, vitamins A and E, clotting factors, and high sensitivity C-reactive protein and urine analysis) in 194 subjects (ages 10 to 17 years) who were randomly assigned to placebo, low-dose, or high-dose colesevelam treatment for 8 weeks, followed by open-label use for 18 weeks. AEs were reported by 34.5 percent of subjects during the initial 4-week period, during which all subjects received only placebo (plus their usual statin, if any). This increased to 42.8 percent during the blinded period (with a similar distribution in all three groups) and to 50.5 percent during the open-label period, when all subjects received colesevelam (again with their usual statin, if any). Drug-related AEs were reported by 9.3 percent of subjects in the blinded period (by 6.3% of those on high-dose colesevelam, 10.8% of those on low-dose colesevelam, and 10.8% of those on placebo), and medication was stopped in one subject on high-dose and in three subjects on low-dose therapy. The most common drug-related AEs were gastrointestinal (diarrhea, nausea, vomiting, and abdominal pain) and occurred in 7 percent of those on colesevelam and in 4.6 percent of those on placebo. During the open-label period, 6.0 percent of subjects reported drug-related AEs; the most common again being gastrointestinal symptoms (occurring in 4.3%). The AEs most commonly reported during the open-label period were headache (7.6%), nasopharyngitis (5.4%), and upper respiratory infection (4.9%). Five patients reported serious treatment-emergent AEs, but none were believed to be drug-related. Clinically meaningful changes were not found in safety laboratory measurements, vital signs, or physical findings, and changes in heart rate, blood pressure, body weight, and height velocity were similar for both groups.

Ezetimibe. Two good-quality RCTs evaluated ezetimibe, one coadministered with simvastatin58 and the other as monotherapy.59 One good-quality RCT evaluated coadministration of ezetimibe with simvastatin in 248 subjects ages 10 to 17 years with FH.58 Subjects were randomly assigned to receive varying doses of simvastatin plus either 10 mg/day ezetimibe or placebo for 6 weeks, followed by higher-dose (40 mg) simvastatin plus either 10 mg/day ezetimibe or placebo for 27 weeks, followed by an open-label regimen of lower-dose simvastatin (10 or 20 mg) plus 10 mg/day ezetimibe for 20 weeks. The study was not powered to detect differences between groups on safety endpoints. However, at the end of the second phase of the trial, 83 percent of the simvastatin-plus-ezetimibe group and 84 percent of the simvastatin-plus-placebo group reported AEs. The most frequent AEs were reported at the same rates (nasopharyngitis in 27 subjects in each group and headache in 16 subjects in each group). The only AEs that were noted in at least twice as many subjects in the ezetimibe group as in the placebo group occurred rarely: myalgia (7 vs. 1 subject), diarrhea (9 vs. 3 subjects), nausea (8 vs. 4 subjects), abdominal pain (6 vs. 3 subjects), pharyngolaryngeal pain (6 vs. 3 subjects), and ALT concentrations increased to 3 times the upper limit of normal on consecutive checks (6 vs. 3 subjects). Among the eight subjects with myalgia, CK concentrations were unremarkable. Persistently elevated transaminase concentrations returned to normal in all affected subjects after interrupting or discontinuing therapy. Three percent of participants discontinued treatment due to AEs. No clinically important AEs on growth, sexual maturation, or steroid hormones were reported.

The ezetimibe monotherapy RCT was conducted in 29 international sites and randomized 138 youth ages 6 to 10 years (mean, 8.3 years [SD, 1.6 years]) to 10 mg ezetimibe or placebo for 12 weeks. Clinical harms assessed included rhabdomyolysis, myopathy, hypersensitivity, cholecystitis, cholelithiasis, and pancreatitis. Laboratory harms assessed included consecutive increases in ALT or AST greater than 3 times the upper limit of normal, consecutive increases in creatine phosphokinase greater than 5 times the upper limit of normal with clinical muscle symptoms, or creatine phosphokinase greater than 10 times the upper limit of normal. There were no significant differences in AE distribution across the treatment groups. There were no serious drug-related AEs in either group. Three members of the ezetimibe group (3.3%) and none in the placebo group discontinued treatment because of AEs (two drug related, one serious): one elevated ACT, one prurigo, and one epileptic event.

### KQ8 What Is the Association Between Intermediate Outcomes in Childhood and Adolescence and the Future Incidence or Timing of Adult MI and Stroke Events?

No studies were identified.