# Methods

## Overview

This systematic review was designed to complement the systematic review that supported the recommendation on screening for multifactorial dyslipidemia in children and adolescents. For this review, we adapted the analytic framework for lipid screening from the 2007 USPSTF review to address the benefits and harms of primary care–relevant screening and treatment of children and adolescents with FH.

## Key Questions and Analytic Framework

Using the USPSTF's methods (detailed in Appendix A), we developed an analytic framework (Figure 1) and eight key questions (KQs).

Figure 1 Analytic Framework

* Intermediate outcomes include lipid concentrations (total and low-density lipoprotein cholesterol) and atherosclerosis markers (carotid intima–media thickness, calcium score, and pathological findings)

Figure 1 is an analytic framework that depicts the eight Key Questions (KQs) described in the Methods section. Specifically, it illustrates the following questions: whether screening for familial hypercholesterolemia (FH) in asymptomatic children and adolescents delays or reduces the incidence of myocardial infarction (MI) or stroke in adulthood (KQ1), whether screening for FH in asymptomatic children and adolescents improves intermediate outcomes in childhood and adolescence (KQ2), the diagnostic yield of appropriate screening tests for FH in children and adolescents (KQ3), the harms of screening for FH in children and adolescents (KQ4), whether treatment for FH delays or reduces the incidence of MI and stroke in adulthood (KQ5) or improves intermediate health outcomes in childhood and adolescence (KQ6), the harms of treatment of FH with medications in children and adolescents (KQ7), and the association between intermediate outcomes in childhood and adolescence and the future incidence or timing of adult MI and stroke (KQ8).

### Screening KQs

1. Does screening for FH in asymptomatic children and adolescents delay or reduce the incidence of MI or stroke in adulthood?
  a. Selective screening based on family history
  b. Universal screening
2. Does screening for FH in asymptomatic children and adolescents improve intermediate outcomes (i.e., reduce lipid concentrations or reverse or slow the progression of atherosclerosis) in childhood and adolescence?
  a. Selective screening based on family history
  b. Universal screening
3. What is the diagnostic yield of appropriate screening tests for FH in children and adolescents?
  a. Selective screening based on family history
  b. Universal screening
4. What are the harms of screening for FH in children and adolescents?

### Treatment KQs

5 Does treatment of FH with lifestyle modifications and/or lipid-lowering medications in children and adolescents delay or reduce the incidence of adult MI and stroke events?
6 Does treatment of FH with lifestyle modifications and/or lipid-lowering medications in children and adolescents improve intermediate outcomes (i.e., reduce lipid concentrations or reverse or slow the progression of atherosclerosis) in childhood and adolescence?
7 What are the harms of treatment of FH with medications in children and adolescents?

### Outcomes KQ

8 What is the association between intermediate outcomes in childhood and adolescence and future incidence or timing of adult MI and stroke events?

In these KQs, intermediate outcomes include lipid concentrations (TC and LDL-C) and atherosclerosis markers (CIMT, calcium score, and pathological findings).

## Data Sources and Searches

We designed this review to extend the 2007 systematic review on screening in childhood lipids. In October 2013, we searched the following databases to identify systematic reviews on child lipid screening published since September 2005 (the date of the literature search for the previous USPSTF review on this topic): AHRQ, BMJ Clinical Evidence, Canadian Agency for Drugs and Technologies in Health, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, Health Technology Assessment (Centre for Reviews and Dissemination), Institute for Clinical Systems Improvement, Institute of Medicine, MEDLINE and PubMed, and National Institute for Health and Care Excellence. We worked with a trained medical librarian to develop the appropriate search strategy for screening for childhood lipids (Appendix A). On February 12, 2014, we conducted our original search for this review, and the search was updated on June 13, 2014 and again on June 2, 2015.

For the published literature prior to September 2005, we searched all publications cited in the 2007 USPSTF review. Although that review did not specifically address diagnostic yield (KQ3 in this review), several of their KQs addressed various aspects of screening. We conducted a focused search of the studies cited in the 2007 USPSTF review to identify any that met our criteria for KQ3. Also, because the 2007 USPSTF review did not have a KQ on the association between screening and intermediate outcomes (KQ2 in this review) or on the association between intermediate outcomes in children and adolescents with FH and adult health outcomes (KQ8 in this review), we supplemented our search of the 2007 USPSTF citations with a search of the 2011 NHLBI expert panel report27 and publications from large published cohort studies with longitudinal data (Appendix E). To ensure the comprehensiveness of our search strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were not identified in our literature searches. We also supplemented our database searches with suggestions from experts and searched Clinicaltrials.gov to identify relevant ongoing trials (Appendix B).

## Study Selection

Two investigators independently reviewed the title and abstracts of all identified articles to determine whether the study met the inclusion and exclusion criteria for design, population, screening, intervention, and outcomes (Appendix A Table 2). Two reviewers then independently evaluated 375 full-text articles against the complete inclusion and exclusion criteria (Appendix A Table 1). We resolved discrepancies through discussion and consultation with a third reviewer. Excluded studies and their reason for exclusion are listed in Appendix C.

For screening studies (KQs 1–4), we included studies of asymptomatic children and adolescents ages 0 to 20 years at the time of screening. Acceptable screening interventions were defined as a lipid panel (fasting or nonfasting lipid measurement, TC or LDL-C alone or in combination with HDL-C) delivered in a universal or selective screening strategy. We excluded screening studies that focused on genetic screening alone or cascade screening because those screening approaches are not relevant to screening for FH in primary care. We excluded screening studies of populations with known dyslipidemia, a diagnosis associated with secondary dyslipidemia, or a documented family history of FH because these populations were not asymptomatic. Only screening studies that reported the number of children with probable or definite FH were included.

For treatment studies (KQs 5–7), we included interventions using lipid-lowering drugs or lifestyle interventions (including diet or exercise). We focused on interventions targeting persons ages 0 to 20 years who had a diagnosis of FH at the beginning of the intervention. We accepted any class of lipid-lowering drug, including, but not limited to, statins and bile-acid sequestrants. We excluded studies that focused on treating those with secondary dyslipidemia or monogenic dyslipidemia other than FH. We excluded treatment studies focusing on apheresis and revascularization, as those treatments are reserved for persons with homozygous FH. We included all reported clinical and laboratory harms associated with lipid-lowing drugs.

We included studies with mixed dyslipidemic populations when the outcome data for subjects with FH were presented separately. We included studies where the author specifically identified subjects with FH using any specified and accepted criteria (Appendix D). We limited studies of efficacy or effectiveness to fair- to good-quality randomized trials that were conducted in countries with a high Human Development Index (>0.9). Included intervention trials had to compare an intervention against a usual care or control group.

Consistent with current USPSTF methods, health outcomes (KQ1, KQ5, and KQ8) were defined as those experienced by the patient. We considered atherosclerosis or elevated lipid concentrations to be intermediate outcomes (KQ2 and KQ6). We included trials, cohort studies, and observational studies that reported clinical or laboratory harms but did not include case series or case reports.

## Quality Assessment and Data Extraction

Two reviewers independently appraised all articles that met the inclusion criteria for this review. The appraisal criteria were adapted from the USPSTF's design-specific quality criteria51 (Appendix A Table 2). Topic-specific quality criteria were designed with the assistance of clinical experts. The final quality rating recorded in the evidence tables was based on quality guidelines from the procedure manual for USPSTF reviews. We rated studies as good, fair, or poor quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet, or it was unclear whether it met, at least one criterion but also had no known issue that would invalidate its results. A poor-quality study had important limitations that made inference about a population difficult or unwarranted. We excluded poor-quality studies from this review. Poor-quality studies had severe limitations, including one or more of the following risk of biases: lack of randomization, possibly biased assignment, unclear diagnostic criteria, unclear classification procedures, or no reporting of baseline characteristics. Excluded articles are listed in a table with reasons for exclusion (Appendix C). One reviewer extracted data from all included fair- or good-quality studies into a standard evidence table. A second reviewer checked the data for accuracy. The reviewers abstracted study characteristics (e.g., population, purpose, exposure, and outcomes of the study), study design elements (e.g., recruitment procedures, eligibility criteria, duration of followup, and attrition), randomized trial characteristics (e.g., setting, blinding, methods of measurement for outcome and exposure, duration, and lipid concentrations), outcomes for screening studies (e.g., true positives, diagnostic yield, and positive predictive value), intermediate outcomes (e.g., lipid concentrations and CIMT) and health outcomes (e.g., MI and stroke), and harms.

## Data Synthesis and Analysis

The data are summarized in tables. Lipids and measures of atherosclerosis were expressed as the percent change from baseline or as the difference from baseline. One KQ, KQ6, had sufficient included studies to permit meta-analysis. The results of RCTs of statins that reported means and standard deviations (SDs) for percent change (k=6) were summarized in forest plots. Intervention effects for each study are presented as the mean difference between groups with 95% confidence intervals (CIs). When trials reported standard errors (SEs) or CIs for the primary outcome, we used the reported results to compute SDs. For one trial with three groups randomly assigned to different doses of a statin,52 we used weighted means and SDs to combine reported results into a single intervention effect for the study. Results are displayed in a forest plot. We did not combine data across studies, given the variability in drug, dosage, and intended duration of treatment.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and eligibility criteria was available for public comment from January 23 to February 19, 2014. This draft research plan was broadly focused on dyslipidemia in childhood and adolescence, not specifically FH. Because of public comment, we decided to conduct two complementary reviews: screening for FH and screening for multifactorial dyslipidemia in children and adolescents. A draft version of the current report was reviewed by three invited content experts, as well as by federal partners from the Centers for Disease Control and Prevention, the Centers for Medicare & Medicaid Services, the National Institutes of Health, the Veteran's Health Administration, and the Military Health Service. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and subsequently addressed, as appropriate, in the final version of this report. Additionally, a draft of the full report was posted on the USPSTF's Web site from December 22, 2015 to January 25, 2016. A few comments were received during this public comment period; there were no changes made to the report based on these comments.

## USPSTF Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to refine the inclusion criteria, to address methodological decisions on applicable evidence, and to resolve issues around the scope of the final evidence review. AHRQ funded this research under a contract to support the work of the USPSTF. AHRQ staff oversaw the project and assisted in the external review of drafts of the evidence report. AHRQ was not involved in study selection, quality assessment, or synthesis.