# Introduction

## Scope and Purpose

The Agency for Healthcare Research and Quality (AHRQ) commissioned a systematic evidence review to support the U.S. Preventive Services Task Force (USPSTF) in updating its 2007 recommendation statement on screening for lipid disorders in children.

As noted in the 2007 review, pediatric dyslipidemias are a heterogeneous set of conditions that include several monogenic disorders as well as dyslipidemias caused by a variety of factors, both genetic and environmental. Based on public comments on the draft research plan, the USPSTF decided to conduct separate systematic reviews on screening for familial hypercholesterolemia (FH) and screening for multifactorial dyslipidemia. This review focuses on FH. This review assesses the benefits and harms of screening for and treatment of FH in children and youth ages 0 to 20 years. The separate systematic review to update the 2007 USPSTF recommendation on multifactorial dyslipidemia will address screening children and adolescents for other dyslipidemias involving elevated low-density lipoprotein cholesterol (LDL-C) or total cholesterol (TC) that are not FH. These two concurrent systematic reviews will allow the USPSTF to simultaneously consider both bodies of evidence to evaluate the preventive health benefits of screening children and adolescents for dyslipidemias involving elevated LDL-C.

## Clinical Presentation and Diagnosis

FH is an inherited disorder of lipoprotein metabolism characterized by highly elevated TC concentrations early in life, independent of environmental influences. Tendon xanthomas (cutaneous deposits of cholesteryl ester-enriched foam cells in ligaments and tendons) may also be present, most commonly in the Achilles tendon.

Currently, no criteria for the diagnosis of FH are universally accepted. Studies of children with FH use several different diagnostic criteria, some of which are drawn from published definitions. The three most commonly cited diagnostic criteria are the Simon Broome criteria1 from the United Kingdom, the Dutch Lipid Clinic Network criteria2 from the Netherlands, and the MEDPED criteria3 from the United States. All use a combination of elevated lipid concentrations, physical findings, family history, or genetic tests to establish the diagnosis. Further, combinations of diagnostic criteria are used to stratify diagnosis according to the probability of disease (i.e., definite, probable, or possible FH) (Appendix D). The use of genetic diagnosis alone is complicated by incomplete penetrance of the genes that cause FH and by varying expressivity of clinical symptoms, especially in childhood and adolescence.4, 5

## Etiology and Prevalence

FH is an autosomal-dominant disorder caused primarily by mutations in the low-density lipoprotein receptor (LDLR) gene.6, 7 More than 80 percent of cases are attributed to 1 of 1,500 known deleterious mutations8 in the LDLR gene.9 The remainder of cases reflect mutations in other genes (ApoB, PCKS9) or unknown mutations.

The prevalence of heterozygous FH is estimated to be 1 in 200 to 1 in 500 persons in North America and Europe. It is higher (up to 1 in 100) for populations with known founder effects, including the Netherlands, South Africa's Afrikaner population, Quebec, and Lebanon.9 Given population prevalence estimates, FH may be underdiagnosed, especially in children.10, 11 Homozygous FH, a more severe condition than heterozygous FH, is far less common, with a prevalence of about 1 in 1,000,000 births.5 This evidence review focuses exclusively on the heterozygous form of the disorder. In the remainder of this report, we refer to heterozygous FH simply as FH.

## Natural History

FH is normally asymptomatic in childhood and is rarely associated with cardiovascular illness in the first two decades of life. The burden of FH is caused largely by premature cardiovascular events in adulthood that are associated with long-term exposure to elevated, and in some cases severely elevated, serum cholesterol concentrations and the associated atherosclerotic burden. Lifelong elevation of plasma concentrations of LDL-C leads to cholesterol deposition in the arteries, where it forms an atherosclerotic plaque that can begin early in life. Early atherosclerotic lesions in children, adolescents, and young adults have been related to higher antecedent concentrations of TC and LDL-C12-15 and mean carotid intima-media thickness (CIMT) values in young children (age <8 years) with FH, which may be greater than those of their unaffected siblings.16

Untreated, FH is associated with a high incidence of premature clinical atherosclerotic cardiovascular disease (CVD). Before statins were in common use, FH was associated with a 1-in-6 cumulative incidence of ischemic heart disease events in men and a 1-in-10 incidence in women by age 40 years.17 By age 50 years, 25 percent of women and 50 percent of men with untreated FH will experience clinical CVD.18 In adults with untreated FH, coronary artery disease (CAD) occurs in 50 percent of men by age 50 years and in 30 percent of women by age 60 years.19, 20 CAD-associated mortality is increased in persons with FH younger than age 60 years. Among persons surviving to age 60 years, the risk of CAD approaches that in the general population.21 Deposition of LDL-C in other body tissues can manifest as clinical findings, mainly tendon xanthomas and corneal arcus.

## Lipid Concentrations in Children and Adolescents

Lipid concentrations in healthy children vary with age, starting very low at birth, increasing slowly in the first 2 years of life, and then stabilizing until adolescence. TC and LDL-C concentrations subsequently decrease by 10 to 20 percent or more during adolescence, before rising again during late adolescence and young adulthood.22-25 In children with FH, concentrations of TC and LDL-C in early childhood will be 2 to 3 times higher as those in unaffected children.

## Screening for FH

### Rationale for Screening

The rationale for screening for FH in childhood or adolescence is to identify presymptomatic children and to intervene with lipid-lowering agents before clinically significant atherosclerosis develops. Given the earlier onset and more severe clinical implications of FH compared to other dyslipidemias, the long preclinical disease course of atherosclerosis, and the availability of intervention for detected cases, FH may be a candidate for screening in primary care.

### Laboratory Studies

Because elevated LDL-C concentrations are the primary abnormality associated with FH, all FH diagnostic criteria are based in part on serum concentrations of TC, LDL-C, or both. LDL-C may be calculated with the Friedewald formula26: LDL-C = TC – (triglycerides/5) – high-density lipoprotein cholesterol (HDL-C). Because the calculation depends on triglycerides, calculating LDL-C concentrations accurately requires blood to be drawn when the person is fasting. Direct LDL-C measurement does not require fasting.15 Recent screening recommendations for childhood dyslipidemia have included guidelines for use of either LDL-C or non–high-density lipoprotein cholesterol (non–HDL-C).18, 27

### Screening Strategies

- Screening by clinical examination. Because only a few children have clinically detectable atherosclerotic deposits, such as xanthomas, by adolescence, detecting these deposits can aid in diagnosis but is not a useful screening marker for FH in children and adolescents.
- Selective screening based on family history. Targeted lipid screening of high-risk individuals ages 2 to 8 years has also been recommended, as well as screening in late adolescence and young adulthood (after lipid concentrations have once again risen).18 Screening based on a family history of early CVD or hypercholesterolemia will identify only 30 to 60 percent of children with FH. The previous USPSTF review determined that having a parent or grandparent with CHD diagnosed before age 50 or 60 years or a cholesterol concentration greater than 240 mg/dL was only 46 to 74 percent sensitive for identifying TC concentrations greater than 170 mg/dL or LDL-C concentrations greater than 130 mg/dL. A family history of a parent or grandparent having early CHD alone was only 46 percent sensitive for LDL-C concentrations above the 95th percentile.15, 28-30
- Universal screening. In universal screening, all children in a population undergo blood lipid screening based on age alone, regardless of other risk factors. Recent recommendations from the National Heart, Lung, and Blood Institute (NHLBI) have suggested universal screening at ages 9 to 11 years and again at ages 17 to 21 years.18 The National Lipid Association also recommends screening for FH at ages 9 to 11 years.27
- Genetic screening. Only one FH diagnostic guideline (the Dutch criteria) currently recommends assigning a diagnosis of FH based on mutation status alone (Appendix D). Other schemes require other clinical or laboratory characteristics in addition to mutation status. In genetically homogeneous populations, population-based screening for genetic variants known to exist in the population may be a useful strategy. However, given the genetic heterogeneity of the U.S. population and the lack of validated genetic screening tests for this population, genetic screening is beyond the scope of this review.
- Cascade screening. Cascade screening involves case-finding among relatives with confirmed FH and often involves testing for genetic variants identified in the proband. Because implementing this approach in the United States would require new infrastructure, cascade screening is outside of the purview of U.S. primary care and beyond the scope of this review.

## Current Clinical Practice in the United States

Beginning in the 1990s, organizations have recommended selective screening for childhood dyslipidemia based on the presence of risk factors, such as a family history suggesting inherited dyslipidemia (e.g., early CVD, early myocardial infarction [MI] or sudden death, or early cerebrovascular disease) or a personal history of risk factors for CVD.6, 31 A recent report from the NHLBI Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents recommended universal screening for children ages 9 to 11 years and 17 to 21 years, as well as targeted screening of high-risk younger children and adolescents.18 These recommendations are controversial, in part because of concerns about the lack of data on long-term efficacy and the safety of lipid-lowering medications in children and adolescents.

### FH Screening in the United States

In the United States, there are no national screening programs, and FH identification falls to individual clinicians as a matter of differential diagnosis. At least one FH patient registry exists in the United States.32

### FH Screening in Other Countries

Cascade screening is the most common screening strategy in other countries. The Netherlands has a known founder population with a high rate of FH, a subsidized health care system, and an infrastructure that supports a disease registry, and so it has a successful cascade screening program. In this program, relatives of FH patients are identified and screened with clinical examinations, fasting lipid panels, and molecular testing for LDLR mutations. With a participation rate of more than 90 percent, it has been successful in detecting new cases, increasing coverage of lipid-lowering therapies, and is cost-effective in case-finding, although following up with children remains challenging.33-36 These screening algorithms led to the Dutch Criteria described in this review. Norway and Wales have also implemented national cascade screening programs.37 Several other countries have explored cascade screening programs or have begun implementation.21, 38-41 U.K. public health authorities recommend cascade screening with identified FH patients using the clinically-focused Simon Broome criteria.42 Regional implementation suggests that cascade screening is feasible but has mixed results in identifying persons with FH.43-45 Currently, the United States does not have the necessary health infrastructure to support cascade screening.

Italy promotes a selective screening strategy based on family history to guide lipid testing.36, 46 We are aware of at least one universal screening program, in Slovenia, but its impact is not yet known.

## Treatment of FH in Children

Interventions for correcting lipid aberrations in children and adolescents include lifestyle modification and pharmacotherapy.

### Lifestyle

Current guidelines27 recommend a low-fat, low-cholesterol diet and regular physical activity for children and adolescents with FH, although evidence for the effect of nonpharmacologic interventions in children with FH is limited. Some evidence indicates that low-fat, low-cholesterol diets are marginally effective in lowering lipid concentrations in children (age >2 years) with certain conditions (including FH). The 2007 USPSTF review noted some uncertainty about whether these improvements would be sustained.47 Exercise is associated with minimal, if any, improvement in lipids in children with any sort of dyslipidemia. The 2007 USPSTF review found no studies that assessed the effect of physical activity interventions in children with FH.47

### Pharmacotherapy

Several lipid-lowering medications are used in children and adolescents with FH. Bile acid-binding resins have been available for decades. Several HMG-CoA reductase inhibitors (statins)48, 49 are approved by the U.S. Food and Drug Administration for children with FH who are age 10 years and older and (if female) are postmenarchal; one statin is approved for children as young as age 8 years. A third class of lipid-lowering agents used in youth inhibits intestinal cholesterol absorption (e.g., ezetimibe).

Following the widespread adoption of statins to reduce LDL-C concentrations in adults with hypercholesterolemia (most of whom do not have FH), pediatric specialists have actively debated the appropriate age of statin initiation in youth with FH. Some experts in the field recommend waiting until after puberty—some suggesting as late as age 20 years50—to minimize potential adverse effects on growth and development. Others advocate starting statins in children with FH as young as age 8 or 10 years.27

## Previous USPSTF Recommendation

In 2007, the USPSTF found insufficient evidence to recommend for or against routine screening for lipid disorders in infants, children, or adolescents up to age 20 years (I statement).15, 47 The 2007 recommendation referred to screening for all forms of childhood and adolescent dyslipidemia, and no separate recommendation was made specifically regarding screening for FH. The 2007 evidence review found these evidence gaps relevant to screening children and adolescents for FH:

- Direct evidence on the impact of FH screening on intermediate and adult health outcomes
- The diagnostic yield of screening for FH
- The harms of screening
- The benefits and harms of long-term treatment of FH identified in childhood (noting that the long-term effectiveness of statins is a critical evidence gap)