# Cohort Studies

National Health and Nutritional Examination Survey (NHANES)
Bogalusa Heart Study
Pathobiological Determinants of Atherosclerosis in Youth (PDAY)
Muscatine Study
Princeton Lipid Research Clinics Follow-up Study
Cardiovascular Risk in Young Finns Study (Young Finns)
National Heart, Lung, and Blood Institute Growth and Health Study (NGHS)
Special Turku Coronary Risk Factor Intervention Project (STRIP)
Coronary Artery Risk Development in Young Adults Study (CARDIA)
Minnesota Children's Blood Pressure Study
Beaver County Lipid Study
Fels Longitudinal Study
National Children's Study (NIH)
Four Provinces Study (4P)