# Diagnostic Criteria for Familial Hypercholesterolemia

Table 1 MEDPED Criteria (United States)^*,1^

Age | Total Cholesterol (LDL-C) concentrations, mg/dL
Age | First-degree relative | Second-degree relative | Third-degree relative | General population
<18 | 220 (155) | 230 (165) | 240 (170) | 270 (200)
20 | 240 (170) | 250 (180) | 260 (185) | 290 (220)
30 | 270 (190) | 280 (200) | 290 (210) | 340 (240)
40 + | 290 (205) | 300 (215) | 310 (225) | 360 (260)

* Cutoffs for 98% specificity and 54% to 88% sensitivity.

Abbreviation: LDL-C=low-density lipoprotein cholesterol.

Table 2 Simon Broome Criteria (United Kingdom)2

Total cholesterol (LDL-C) of 290 mg/dL (190 mg/dL) in adults or 260 mg/dL (155 mg/dL) in pediatrics (age <16 years) AND
1. DNA mutation | Definite FH
2 Tendon xanthomas in the patient or in a first- or second-degree relative | Probable FH
3 Family history of MI at age <50 years in second-degree relative or at age <60 years in first-degree relative; OR; Family history of total cholesterol >290 mg/dL in first- or second-degree relative | Possible FH

Abbreviations: LDL-C=low-density lipoprotein cholesterol, MI=myocardial infarction, FH=familial hypercholesterolemia.

Table 3 Dutch Criteria (The Netherlands)3

1 point | First- degree relative with premature cardiovascular disease or LDL-C >95^th^ percentile, or personal history of premature peripheral or cerebrovascular disease, or LDL-C between 155 and 189 mg/dL
2 points | First-degree relative with tendinous xanthoma or corneal arcus, or first- degree relative child (<18 years) with LDL-C >95^th^ percentile, or personal history of coronary artery disease
3 points | LDL-C between 190 and 249 mg/dL
4 points | Presence of corneal arcus in patient age <45 years
5 points | LDL-C between 250 and 329 mg/dL
6 points | Presence of a tendon xanthoma
8 points | LDL-C >330 mg/dL or functional mutation in the LDLR gene

Abbreviations: LDL-C=low-density lipoprotein cholesterol, LDLR=low-density lipoprotein receptor, FH=familial hypercholesterolemia.

Definite FH (≥8 points); probable FH (6–7 points); possible FH (3–5 points).

## References

1 Williams RR, Hunt SC, Schumacher MC, et al. Diagnosing heterozygous familial hypercholesterolemia using new practical criteria validated by molecular genetics. Am J Cardiol. 1993;72(2):171-6. [pmid: 8328379].
2 Risk of fatal coronary heart disease in familial hypercholesterolaemia. Scientific Steering Committee on behalf of the Simon Broome Register Group. BMJ. 1991;303(6807):893-6. [pmid: 1933004].
3 World Health Organization. Familial hypercholesterolemia—report of a second WHO Consultation. Geneva, Switzerland. World Health Organization. 1999.