# Excluded Studies

Code^*^ | Reason for Exclusion
E1 | Not English
E2 | Not original research in a peer-reviewed journal
E4 | Ineligible SETTING (a) non-generalizable to primary care; (b) low HDI country
E5 | Ineligible POPULATION
E6 | Ineligible OUTCOMES
E7 | Ineligible screening strategy
E8 | Ineligible treatment
E9 | Ineligible study design
E10 | Study rated as poor quality
E11 | Overlapping study population
E12 | N/A

* The exclusion code E3 was not used.

Abbreviations: HDI=Human Development Index, N/A=not applicable.

1 Two controversial recommendations: screening (and treating) children for cholesterol. Child Health Alert. 2008;26:1-2. KQ1E2. [pmid: 18953695].
2 American Academy of Pediatrics. National Cholesterol Education Program: Report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents. Pediatrics. 1992;89(3 Pt 2):525-84. KQ4E6. [pmid: 1538956].
3 American Academy of Pediatrics Committee on Nutrition American Academy of Pediatrics, Committee on Nutrition. Cholesterol in childhood. Pediatrics. 1998;101(1 Pt 1):141-7. KQ4E6. [pmid: 11345978].
4 Andersen GE, Brokhattingen K, Lous P. Familial hypobetalipoproteinaemia in 9 children diagnosed as the result of cord blood screening for hypolipoproteinaemia in 10,000 Danish newborns. Arch Dis Child. 1979;54(9):691-4. KQ4E6. [pmid: 229774].
5 Andersen GE, Lous P, Friis-Hansen B. Screening for hyperlipoproteinemia in 10,000 Danish newborns. Follow-up studies in 522 children with elevated cord serum VLDL-LDL-cholesterol. Acta Paediatr Scand. 1979;68(4):541-5. KQ4E6. [pmid: 223372].
6 Andersen GE, Nielsen HG. Neonatal screening for hyperlipoproteinemia. Methods for direct estimation of cord serum VLDL + LDL. Clin Chim Acta. 1976;66(1):29-41. KQ4E6. [pmid: 177231].
7 Arambepola C, Farmer AJ, Perera R, et al. Statin treatment for children and adolescents with heterozygous familial hypercholesterolaemia: a systematic review and meta-analysis. Atherosclerosis. 2007;195(2):339-47. KQ6E13, KQ7E13. [pmid: 17097660].
8 Asgary S, Kelishadi R, Rafieian-Kopaei M, et al. Investigation of the lipid-modifying and antiinflammatory effects of Cornus mas L. supplementation on dyslipidemic children and adolescents. Pediatr Cardiol. 2013;34(7):1729-35. KQ6E5, KQ7E5. [pmid: 23625305].
9 AstraZeneca. A phase IIIb, efficacy, and safety study of rosuvastatin in children and adolescents 10 to 17 years of age with heterozygous familial hypercholesterolemia (HeFH): a 12-week, double-blind, randomized, multicenter, placebo-controlled study with a 40-week, open-label, followup. 2011. NCT00355615. KQ6E2, KQ7E2.
10 Averna M, Zaninelli A, Le Grazie C, et al. Ezetimibe/simvastatin 10/20 mg versus simvastatin 40 mg in coronary heart disease patients. J Clin Lipidol. 2010;4(4):272-8. KQ6E5, KQ7E5. [pmid: 21122660].
11 Avis HJ, Hargreaves IP, Ruiter JP, et al. Rosuvastatin lowers coenzyme Q10 levels, but not mitochondrial adenosine triphosphate synthesis, in children with familial hypercholesterolemia. J Pediatr. 2011;158(3):458-62. KQ5E13, KQ6E9, KQ7E6. [pmid: 20884007].
12 Avis HJ, Vissers MN, Stein EA, et al. A systematic review and meta-analysis of statin therapy in children with familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 2007;27(8):1803-10. KQ6E13, KQ7E13. [pmid: 17569881].
13 Bachman RP, Schoen EJ, Stembridge A, et al. Compliance with childhood cholesterol screening among members of a prepaid health plan. Am J Dis Child. 1993;147(4):382-5. KQ4E6. [pmid: 8456792].
14 Backes JM, Gibson CA, Ruisinger JF, et al. The high-dose rosuvastatin once weekly study (the HD-ROWS). J Clin Lipidol. 2012;6(4):362-7. KQ6E5, KQ7E5. [pmid: 22836073].
15 Baker SG, Joffe BI, Mendelsohn D, et al. Treatment of homozygous familial hypercholesterolaemia with probucol. S Afr Med J. 1982;62(1):7-11. KQ7E13, KQ8E13. [pmid: 7089781].
16 Ballantyne C, Gleim G, Liu N, et al. Effects of coadministered extended-release niacin/laropiprant and simvastatin on lipoprotein subclasses in patients with dyslipidemia. J Clin Lipidol. 2012;6(3):235-43. KQ6E5, KQ7E5. [pmid: 22658147].
17 Bang OY, Saver JL, Liebeskind DS, et al. Association of serum lipid indices with large artery atherosclerotic stroke. Neurology. 2008;70(11):841-7. KQ8E5. [pmid: 18160673].
18 Bangert SK, Eldridge PH, Peters TJ. Neonatal screening for familial hypercholesterolaemia by immunoturbidimetric assay of apolipoprotein B in dried blood spots. Clin Chim Acta. 1992;213(1-3):95-101. KQ4E6. [pmid: 1477991].
19 Barra S, Cuomo V, Silvestri N, et al. Lipoprotein(a) concentration does not differ between sexes in healthy offspring of patients with premature myocardial infarction. J Cardiovasc Med (Hagerstown). 2011;12(7):482-6. KQ2E7. [pmid: 21519277].
20 Barter PJ, Ballantyne CM, Carmena R, et al. Apo B versus cholesterol in estimating cardiovascular risk and in guiding therapy: report of the thirty-person/ten-country panel. J Intern Med. 2006;259(3):247-58. KQ4E6. [pmid: 16476102].
21 Bastida S, Sanchez-Muniz FJ, Cuena R, et al. High density lipoprotein-cholesterol changes in children with high cholesterol levels at birth. Eur J Pediatr. 2002;161(2):94-8. KQ4E6. [pmid: 11954759].
22 Baumer JH, Shield JP. Hypercholesterolaemia in children guidelines review. Arch Dis Child Educ Pract Ed. 2009;94(3):84-6. KQ8E2. [pmid: 19460897].
23 Bazzano LA, Thompson AM, Tees MT, et al. Non-soy legume consumption lowers cholesterol levels: a meta-analysis of randomized controlled trials. Nutr Metab Cardiovasc Dis. 2011;21(2):94-103. KQ6E5, KQ7E5. [pmid: 19939654].
24 Becker DJ, French B, Morris PB, et al. Phytosterols, red yeast rice, and lifestyle changes instead of statins: a randomized, double-blinded, placebo-controlled trial. Am Heart J. 2013;166(1):187-96. KQ6E5, KQ7E5. [pmid: 23816039].
25 Becker DJ, Gordon RY, Morris PB, et al. Simvastatin vs therapeutic lifestyle changes and supplements: randomized primary prevention trial. Mayo Clin Proc. 2008;83(7):758-64. KQ6E5, KQ7E5. [pmid: 18613992].
26 Becker M, Staab D, Von Bergman K. Long-term treatment of severe familial hypercholesterolemia in children: effect of sitosterol and bezafibrate. Pediatrics. 1992;89(1):138-142. KQ7E13, KQ8E13. [pmid: 1727999].
27 Beeso J, Wong N, Ayling R, et al. Screening for hypercholesterolaemia in 10,000 neonates in a multi-ethnic population. Eur J Pediatr. 1999;158(10):833-7. KQ4E6. [pmid: 10486088].
28 Bell DA, Hooper AJ, Edwards G, et al. Detecting familial hypercholesterolaemia in the community: impact of a telephone call from a chemical pathologist to the requesting general practitioner. Atherosclerosis. 2014;234(2):469-72. KQ1E5, KQ3E5. [pmid: 24814411].
29 Bell MM, Joseph S. Screening 1140 fifth graders for hypercholesterolemia: family history inadequate to predict results. J Am Board Fam Pract. 1990;3(4):259-63. KQ4E6. [pmid: 2248092].
30 Benlian P, Turquet A, Carrat F, et al. Diagnosis scoring for clinical identification of children with heterozygous familial hypercholesterolemia. J Pediatr Gastroenterol Nutr. 2009;48(4):456-63. KQ3E7, KQ4E7. [pmid: 19330934].
31 Bergmann ML, Bergmann GG, Halpern R, et al. Associated factors to total cholesterol: school based study in southern Brazil. Arq Bras Cardiol. 2011;97(1):17-25. KQ3E4. [pmid: 21625818].
32 Bistritzer T, Rosenzweig L, Barr J, et al. Lipid profile with paternal history of coronary heart disease before age 40. Arch Dis Child. 1995;73(1):62-5. KQ4E6. [pmid: 7639553].
33 Blades BL, Dudman NP, Wilcken DE. Screening for familial hypercholesterolemia in 5000 neonates: a recall study. Pediatr Res. 1988;23(5):500-4. KQ4E6. [pmid: 3387172].
34 Blazek M, Blaha M, Pecka M, et al. Primary hemostasis in patients treated with LDL-apheresis for severe familiar hypercholesterolemia: A prospective pilot trial using PFA-100 analysis to rationalize therapeutic LDL-apheresis procedure. Hematology. 2007;12(6):571-6. KQ6E8, KQ7E8. [pmid: 17852459].
35 Boulton TJ. The validity of screening for hypercholesterolaemia at different ages from 2 to 17 years. Aust N Z J Med. 1979;9(5):542-6. KQ4E6. [pmid: 231425].
36 Braamskamp MJ, Hutten BA, Wiegman A. Early initiation of statin treatment in children with familial hypercholesterolaemia. Curr Opin Lipidol. 2015;26(3):236-9. KQ6E2, KQ7E2. [pmid: 25943840].
37 Braamskamp MJ, Tsimikas S, Wiegman A, et al. Statin therapy and secretory phospholipase A2 in children with heterozygous familial hypercholesterolemia. Atherosclerosis. 2013;229(2):404-7. KQ6E9, KQ7E6. [pmid: 23880195].
38 Braga MF, Grace MG, Lenis J, et al. Efficacy and safety of ursodeoxycholic acid in primary, type IIa or IIb hypercholesterolemia: a multicenter, randomized, double-blind clinical trial. Atherosclerosis. 2009;203(2):479-82. KQ6E5, KQ7E5. [pmid: 18801487].
39 Brandao MP, Pimentel FL, Cardoso MF. Impact of academic exposure on health status of university students. Rev Saude Publica. 2011;45(1):49-58. KQ3E5. [pmid: 21203695].
40 Brewster TG, Waite DJ, Hudson GA. Quantitation of beta-lipoprotein in cord serum by rate nephelometric immunoassay: a potential screening test for familial hypercholesterolemia. Clin Chem. 1982;28(5):1192-6. KQ4E6. [pmid: 7074903].
41 Broekhuizen K, van Poppel MN, Koppes LL, et al. A tailored lifestyle intervention to reduce the cardiovascular disease risk of individuals with Familial Hypercholesterolemia (FH): design of the PRO-FIT randomised controlled trial. BMC Public Health. 2010;10:69. KQ6E2, KQ7E2. [pmid: 20156339].
42 Browne B, Vasquez S. Pediatric dyslipidemias: Prescription medication efficacy and safety. J Clin Lipidol. 2008;2(3):189-201. KQ6E2, KQ5E13, KQ7E2. [pmid: 21291737].
43 Brun LD, Gagne C, Coulombe P, et al. Effects of dextrothyroxine on the pituitary-thyroid axis in hypercholesterolemic children and goitrous adults. J Clin Endocrinol Metab. 1980;51(6):1306-1310. KQ7E13, KQ8E13. [pmid: 6777394].
44 Calonge N, Guirguis-Blake J. Screening for familial hypercholesterolaemia. BMJ. 2007;335(7620):573-4. KQ2E2, KQ1E2, KQ4E13, KQ3E2. [pmid: 17884865].
45 Campagna F, Martino F, Bifolco M, et al. Detection of familial hypercholesterolemia in a cohort of children with hypercholesterolemia: results of a family and DNA-based screening. Atherosclerosis. 2008;196(1):356-64. KQ2E7. [pmid: 17196209].
46 Cannioto Z, Tamburlini G, Marchetti F. Statins for children? A word of caution. Eur J Clin Pharmacol. 2009;65(2):217-8. KQ8E2. [pmid: 18987851].
47 Civeira F, Ros E, Jarauta E, et al. Comparison of genetic versus clinical diagnosis in familial hypercholesterolemia. Am J Cardiol. 1193;102(9):1187-93. 1193 e1. KQ3E5, KQ4E5. [pmid: 18940289].
48 Clauss S, Wai KM, Kavey RE, et al. Ezetimibe treatment of pediatric patients with hypercholesterolemia. J Pediatr. 2009;154(6):869-72. KQ6E9, KQ7E9. [pmid: 19230898].
49 Codoner-Franch P, Lopez-Jaen AB, Muniz P, et al. Mandarin juice improves the antioxidant status of hypercholesterolemic children. J Pediatr Gastroenterol Nutr. 2008;47(3):349-55. KQ6E9, KQ7E9. [pmid: 18728533].
50 Colletti RB, Neufeld EJ, Roff NK, et al. Niacin treatment of hypercholesterolemia in children. Pediatrics. 1993;92(1):78-82. KQ7E13, KQ8E13. [pmid: 8516088].
51 Coskun A. Preanalytical factors for non-HDL cholesterol measurements/ Serum lipid profiles including non-high density lipoprotein cholesterol levels in Turkish school-children. Anadolu Kardiyol Derg. 2008;8(1):84-5. author reply 85-6. KQ2E2, KQ1E2, KQ3E2, KQ4E13, KQ5E13. [pmid: 18258549].
52 Croyle RT, Sun YC, Louie DH. Psychological minimization of cholesterol test results: moderators of appraisal in college students and community residents. Health Psychol. 1993;12(6):503-7. KQ7E13, KQ8E13. [pmid: 8293735].
53 Curtis DM, Driscoll DJ, Goldman DH, et al. Loss of dental enamel in a patient taking cholestyramine. Mayo Clin Proc. 1991;66(11):1131. KQ7E13, KQ8E13. [pmid: 1943246].
54 da Luz Giroldo M, Villela Baroncini LA, Champoski AF, et al. Household cardiovascular screening in adolescents from high-risk families. Atherosclerosis. 2013;226(1):286-90. KQ2E4, KQ3E4, KQ1E4, KQ4E4. [pmid: 23195519].
55 Daniels SR. Management of hyperlipidemia in pediatrics. Curr Opin Cardiol. 2012;27(2):92-7. KQ6E2, KQ7E2. [pmid: 22233976].
56 Daniels SR. Screening and treatment of dyslipidemias in children and adolescents. Horm Res Paediatr. Suppl 1. 2011;76:47-51. KQ1E2. [pmid: 21778749].
57 Daniels SR. Screening for familial hypercholesterolemia: what is the most effective strategy?. Nat Clin Pract Cardiovasc Med. 2008;5(3):130-1. KQ3E13, KQ4E13. [pmid: 18059381].
58 Daniels SR, Gidding SS, de Ferranti SD, et al. Pediatric aspects of familial hypercholesterolemias: recommendations from the National Lipid Association Expert Panel on Familial Hypercholesterolemia. J Clin Lipidol. 2011;5(3 Suppl):S30-7. KQ3E13, KQ4E13, KQ6E13. [pmid: 21600527].
59 Daniels SR, Greer FR, Committee on Nutrition. Lipid screening and cardiovascular health in childhood. Pediatrics. 2008;122(1):198-208. KQ3E2, KQ4E2. [pmid: 18596007].
60 Darmady JM, Fosbrooke AS, Lloyd JK. Prospective study of serum cholesterol levels during first year of life. Br Med J. 1972;2(5815):685-8. KQ4E6. [pmid: 5067674].
61 Das B, Daga MK, Gupta SK. Lipid Pentad Index: A novel bioindex for evaluation of lipid risk factors for atherosclerosis in young adolescents and children of premature coronary artery disease patients in India. Clin Biochem. 2007;40(1-2):18-24. KQ3E4, KQ4E4. [pmid: 17052698].
62 Davidson DM, Bradley BJ, Landry SM, et al. School-based blood cholesterol screening. J Pediatr Health Care. 1989;3(1). 8-Mar. KQ4E6. [pmid: 2492600].
63 Davidson DM, Van Camp J, Iftner CA, et al. Family history fails to detect the majority of children with high capillary blood total cholesterol. J Sch Health. 1991;61(2):75-80. KQ4E6. [pmid: 2016863].
64 Davidson MH. A systematic review of bile acid sequestrant therapy in children with familial hypercholesterolemia. J Clin Lipidol. 2011;5(2):76-81. KQ6E13, KQ7E13. [pmid: 21392720].
65 Davidson M. The efficacy of colesevelam HCl in the treatment of heterozygous familial hypercholesterolemia in pediatric and adult patients. Clin Ther. 2013;35(8):1247-52. KQ6E13, KQ7E13. [pmid: 23916045].
66 de Ferranti S, Shapiro D, Markowitz R, et al. Nonfasting low-density lipoprotein testing: utility for cholesterol screening in pediatric primary care. Clin Pediatr (Phila). 2007;46(5):441-5. KQ3E6, KQ4E6. [pmid: 17556742].
67 de Jongh S, Kerckhoffs MC, Grootenhuis MA, et al. Quality of life, anxiety and concerns among statin-treated children with familial hypercholesterolaemia and their parents. Acta Paediatr. 2003;92(9):1096-101. KQ7E13, KQ8E13. [pmid: 14599077].
68 Defesche JC. Defining the challenges of FH screening for familial hypercholesterolemia. J Clin Lipidol. 2010;4(5):338-41. KQ5E13. [pmid: 21122674].
69 Demerath E, Muratova V, Spangler E, et al. School-based obesity screening in rural Appalachia. Prev Med. 2003;37(6 Pt 1):553-60. KQ4E6. [pmid: 14636788].
70 Dennison BA, Jenkins PL, Pearson TA. Challenges to implementing the current pediatric cholesterol screening guidelines into practice. Pediatrics. 1994;94(3):296-302. KQ4E6. [pmid: 8065853].
71 Dennison BA, Kikuchi DA, Srinivasan SR, et al. Parental history of cardiovascular disease as an indication for screening for lipoprotein abnormalities in children. J Pediatr. 1989;115(2):186-94. KQ4E6. [pmid: 2754548].
72 Derinoz O, Tumer L, Hasanoglu A, et al. Cholesterol screening in school children: is family history reliable to choose the ones to screen?. Acta Paediatr. 2007;96(12):1794-8. KQ3E4, KQ4E4. [pmid: 17971187].
73 Derks M, Abt M, Mwangi A, et al. Lack of effect of dalcetrapib on QT interval in healthy subjects following multiple dosing. Eur J Clin Pharmacol. 2010;66(8):775-83. KQ7E5. [pmid: 20521033].
74 Derks M, Abt M, Phelan M. Lack of clinically relevant drug-drug interactions when dalcetrapib is co-administered with ezetimibe. Br J Clin Pharmacol. 2010;70(6):825-33. KQ7E5. [pmid: 21175438].
75 Derks M, Anzures-Cabrera J, Turnbull L, et al. Safety, tolerability and pharmacokinetics of dalcetrapib following single and multiple ascending doses in healthy subjects: a randomized, double-blind, placebo-controlled, phase I study. Clin Drug Investig. 2011;31(5):325-35. KQ7E5. [pmid: 21366361].
76 Derks M, Fowler S, Kuhlmann O. A single-center, open-label, one-sequence study of dalcetrapib coadministered with ketoconazole, and an in vitro study of the S-methyl metabolite of dalcetrapib. Clin Ther. 2009;31(3):586-99. KQ7E5. [pmid: 19393849].
77 Descamps OS, Tenoutasse S, Stephenne X, et al. Management of familial hypercholesterolemia in children and young adults: consensus paper developed by a panel of lipidologists, cardiologists, paediatricians, nutritionists, gastroenterologists, general practitioners and a patient organization. Atherosclerosis. 2011;218(2):272-80. KQ6E2, KQ7E2. [pmid: 21762914].
78 Diller PM, Huster GA, Leach AD, et al. Definition and application of the discretionary screening indicators according to the National Cholesterol Education Program for Children and Adolescents. J Pediatr. 1995;126(3):345-52. KQ4E6. [pmid: 7869190].
79 Dirisamer A, Hachemian N, Bucek RA, et al. The effect of low-dose simvastatin in children with familial hypercholesterolaemia: a 1-year observation. Eur J Pediatr. 2003;162(6):421-5. Epub 2003 Mar 15. KQ7E13, KQ8E13. [pmid: 12756561].
80 Doll H, Shine B, Kay J, et al. The rise of cholesterol testing: how much is unnecessary. Br J Gen Pract. 2011;61(583):e81-8. KQ4E5. [pmid: 21276328].
81 Doshi N, Perrin EM, Lazorick S, et al. Short-term change in body mass index in overweight adolescents following cholesterol screening. Arch Pediatr Adolesc Med. 2009;163(9):812-7. KQ3E6, KQ4E6. [pmid: 19736334].
82 Douglas MB, Birrer RB, Medidi S, et al. Obese children should be screened for hypercholesterolemia. J Health Care Poor Underserved. 1996;7(1):24-35. KQ4E6. [pmid: 8645782].
83 Drogari E, Ragia G, Mollaki V, et al. POR*28 SNP is associated with lipid response to atorvastatin in children and adolescents with familial hypercholesterolemia. Pharmacogenomics. 2014;15(16):1963-72. KQ7E13, KQ8E13. [pmid: 25521355].
84 Ducobu J, Brasseur D, Chaudron JM, et al. Simvastatin use in children. Lancet. 1992;339(8807):1488. KQ7E13, KQ8E13. [pmid: 1351171].
85 Dulay D, LaHaye SA, Lahey KA, et al. Efficacy of alternate day versus daily dosing of rosuvastatin. Can J Cardiol. 2009;25(2):e28-31. KQ6E5, KQ7E5. [pmid: 19214297].
86 Duncan CJ, Rowland R, Lillie PJ, et al. Incidental diagnosis in healthy clinical trial subjects. Clin Transl Sci. 2012;5(4):348-50. KQ2E5, KQ1E5, KQ3E5. [pmid: 22883613].
87 Eiland LS, Luttrell PK. Use of statins for dyslipidemia in the pediatric population. J Pediatr Pharmacol Ther. 2010;15(3):160-72. KQ6E9, KQ7E9. [pmid: 22477808].
88 Eissa MA, Wen E, Mihalopoulos NL, et al. Evaluation of AAP guidelines for cholesterol screening in youth: Project HeartBeat!. Am J Prev Med. 2009;37:S71-7. KQ3E6, KQ4E6. [pmid: 19524159].
89 Elis A, Zhou R, Stein EA. Treatment of familial hypercholesterolaemia in children and adolescents in the last three decades. Cardiol Young. 2013;24(3):437-41. KQ5E13, KQ6E9, KQ7E10. [pmid: 23659280].
90 Espinheira Mdo C, Vasconcelos C, Medeiros AM, et al. Hypercholesterolemia--a disease with expression from childhood. Rev Port Cardiol. 2013;32(5):379-86. KQ6E9, KQ7E10. [pmid: 23669405].
91 Estevez-Gonzalez MD, Saavedra-Santana P, Lopez-Rios L, et al. HDL cholesterol levels in children with mild hypercholesterolemia: effect of consuming skim milk enriched with olive oil and modulation by the TAQ 1B polymorphism in the CETP gene. Ann Nutr Metab. 2010;56(4):288-93. KQ6E5, KQ7E5. [pmid: 20413969].
92 Eyre H, Kahn R, Robertson RM, et al. Preventing cancer, cardiovascular disease, and diabetes: a common agenda for the American Cancer Society, the American Diabetes Association, and the American Heart Association. Circulation. 2004;109(25):3244-55. KQ4E6. [pmid: 15198946].
93 Faigel HC. Screening college students for hypercholesterolemia. J Am Coll Health. 1992;40(6):272-5. KQ4E6. [pmid: 1602094].
94 Farah JR, Kwiterovich PO Jr, Neill CA, et al. Dose-effect relation of cholestryamine in children and young adults with familial hypercholesterolaemia. Lancet. 1977;1(8002):59-63. KQ7E13, KQ8E13. [pmid: 63709].
95 Farah JR, Kwiterovich PO, Neill CA. A study of the dose-effect relationship of cholestyramine in children with familial hypercholesterolemia. Adv Exp Med Biol. 1977;82:212-215. KQ7E13, KQ8E13. [pmid: 200092].
96 Farrokhi F, Moohebati M, Aghdaei HR, et al. Effects of statin therapy on serum trace element status in dyslipidemic patients: results of a randomized placebo-controlled cross-over trial. Clin Lab. 2012;58(9-10):1005-15. KQ7E5. [pmid: 23163117].
97 Fazio S, Guyton JR, Polis AB, et al. Long-term safety and efficacy of triple combination ezetimibe/simvastatin plus extended-release niacin in patients with hyperlipidemia. Am J Cardiol. 2010;105(4):487-94. KQ6E5, KQ7E5. [pmid: 20152243].
98 Feliciano-Alfonso JE, Mendivil CO, Ariza ID, et al. Cardiovascular risk factors and metabolic syndrome in a population of young students from the National University of Colombia. Rev Assoc Med Bras. 2010;56(3):293-8. KQ3E4, KQ4E4. [pmid: 20676535].
99 Fisher-Hoch SP, Vatcheva KP, Laing ST, et al. Missed opportunities for diagnosis and treatment of diabetes, hypertension, and hypercholesterolemia in a Mexican American population, Cameron County Hispanic Cohort, 2003-2008. Prev Chronic Dis. 2012;9:110298. KQ3E5, KQ4E5. [pmid: 22863308].
100 Flechtner-Mors M, Wiegand S, Gellhaus I, et al. Screening for co-morbidity in 65,397 obese pediatric patients from Germany, Austria and Switzerland: adherence to guidelines improved from the year 2000 to 2010. Obes Facts. 2013;6(4):360-8. KQ3E6, KQ4E6. [pmid: 23970145].
101 Flouris AD, Bouziotas C, Christodoulos AD, et al. Longitudinal preventive-screening cutoffs for metabolic syndrome in adolescents. Int J Obes (Lond). 2008;32(10):1506-12. KQ3E6, KQ2E6. [pmid: 18698315].
102 Frich JC, Malterud K, Fugelli P. Experiences of guilt and shame in patients with familial hypercholesterolemia: a qualitative interview study. Patient Educ Couns. 2007;69(1-3):108-13. KQ7E13, KQ4E7. [pmid: 17889493].
103 Frontini MS, Srinivasan SR, Xu J, et al. Usefulness of childhood non-high density lipoprotein cholesterol levels versus other lipoprotein measures in predicting adult subclinical atherosclerosis: the Bogalusa Heart Study. Pediatrics. 2008;121(5):924-9. KQ2E5, KQ8E13, KQ3E13. [pmid: 18450895].
104 Fujita Y, Kouda K, Nakamura H, et al. Height-specific serum cholesterol levels in pubertal children: data from population-based Japanese school screening. J Epidemiol. 2011;21(2):102-7. KQ3E6, KQ4E6. [pmid: 21212578].
105 Futema M, Shah S, Cooper JA, et al. Refinement of variant selection for the LDL cholesterol genetic risk score in the diagnosis of the polygenic form of clinical familial hypercholesterolemia and replication in samples from 6 countries. Clin Chem. 2015;61(1):231-8. KQ4E13. [pmid: 25414277].
106 Gaeta G, Cuomo S, Capozzi G, et al. Lipoprotein(a) levels are increased in healthy young subjects with parental history of premature myocardial infarction. Nutr Metab Cardiovasc Dis. 2008;18(7):492-6. KQ3E6, KQ4E6. [pmid: 17962002].
107 Gagliano NJ, Emans SJ, Woods ER. Cholesterol screening in the adolescent. J Adolesc Health. 1993;14(2):104-8. KQ4E6. [pmid: 8476872].
108 Gagne C, Kusters M, Caceres M, et al. Efficacy and safety of ezetimibe monotherapy in 6-10 year old children with heterozygous familial or nonfamilial hypercholesterolemia. J Clin Lipidol. 2013. KQ7E13, KQ8E13.
109 Garaiova I, Muchova J, Nagyova Z, et al. Effect of a plant sterol, fish oil and B vitamin combination on cardiovascular risk factors in hypercholesterolemic children and adolescents: a pilot study. Nutr J. 2013;12:7. KQ7E4, KQ6E4. [pmid: 23297818].
110 Garcia RE, Moodie DS. Routine cholesterol surveillance in childhood. Pediatrics. 1989;84(5):751-5. KQ4E6. [pmid: 2640549].
111 Gauer R. Hyperlipidemia treatment in children: the younger, the better. Am Fam Physician. 2010;82(5):460. KQ6E2, KQ7E2. [pmid: 20822078].
112 Giannini C, Diesse L, D'Adamo E, et al. Influence of the Mediterranean diet on carotid intima-media thickness in hypercholesterolaemic children: A 12-month intervention study. Nutr Metab Cardiovasc Dis. 2013;24(1):75-82. KQ6E5, KQ7E5. [pmid: 23809150].
113 Gidding SS, Prospero C, Hossain J, et al. A double-blind randomized trial of fish oil to lower triglycerides and improve cardiometabolic risk in adolescents. J Pediatr. 2014;165(3):497-503 e2. KQ7E13, KQ8E13. [pmid: 25008950].
114 Gillman MW, Cupples LA, Moore LL, et al. Impact of within-person variability on identifying children with hypercholesterolemia: Framingham Children's Study. J Pediatr. 1992;121(3):342-7. KQ4E6. [pmid: 1517906].
115 Giugliano RP, Desai NR, Kohli P, et al. Efficacy, safety, and tolerability of a monoclonal antibody to proprotein convertase subtilisin/kexin type 9 in combination with a statin in patients with hypercholesterolaemia (LAPLACE-TIMI 57): a randomised, placebo-controlled, dose-ranging, phase 2 study. Lancet. 2012;380(9858):2007-17. KQ6E5, KQ7E5. [pmid: 23141813].
116 Glassman MS, Schwarz SM. Cholesterol screening in children: should obesity be a risk factor?. J Am Coll Nutr. 1993;12(3):270-3. KQ4E6. [pmid: 8409081].
117 Glueck CJ, Fallat R, Tsang R. Pediatric familial type II hyperlipoproteinemia: therapy with diet and cholestyramine resin. Pediatrics. 1973;52(5):669-679. KQ7E13, KQ8E13. [pmid: 4355362].
118 Glueck CJ, Mellies MJ, Dine M, et al. Safety and efficacy of long-term diet and diet plus bile acid-binding resin cholesterol-lowering therapy in 73 children heterozygous for familial hypercholesterolemia. Pediatrics. 1986;78(2):338-348. KQ7E13, KQ8E13. [pmid: 3526270].
119 Glueck CJ, Tsang RC, Fallat RW, et al. Therapy of familial hypercholesterolemia in childhood: diet and cholestyramine resin for 24 to 36 months. Pediatrics. 1977;59(3):433-441. KQ7E13, KQ8E13. [pmid: 840563].
120 Glueck CJ, Tsang RC, Fallat RW, et al. Plasma vitamin A and E levels in children with familial type II hyperlipoproteinemia during therapy with diet and cholestyramine resin. Pediatrics. 1974;54(1):51-55. KQ7E13, KQ8E13. [pmid: 4365953].
121 Goff DC Jr, Donker GA, et al. Cholesterol screening in pediatric practice. Pediatrics. 1991;88(2):250-8. KQ4E6. [pmid: 1861922].
122 Goldstein JL, Albers JJ, Schrott HG, et al. Plasma lipid levels and coronary heart disease in adult relatives of newborns with normal and elevated cord blood lipids. Am J Hum Genet. 1974;26(6):727-35. KQ4E6. [pmid: 4440681].
123 Gong CD, Wu QL, Chen Z, et al. Glycolipid metabolic status of overweight/obese adolescents aged 9- to 15-year-old and the BMI-SDS/BMI cut-off value of predicting dyslipidemiain boys, Shanghai, China: a cross-sectional study. Lipids Health Dis. 2013;12:129. KQ3E6, KQ4E6. [pmid: 23984682].
124 Graves L, Garnett SP, Cowell CT, et al. Waist-to-height ratio and cardiometabolic risk factors in adolescence: findings from a prospective birth cohort. Pediatr Obes. 2013;9(5):327-38. KQ3E6, KQ4E6. [pmid: 23894119].
125 Groot PH, Dijkhuis-Stoffelsma R, Grose WF, et al. The effects of colestipol hydrochloride on serum lipoprotein lipid and apolipoprotein B and A-I concentrations in children heterozygous for familial hypercholesterolemia. Acta Paediatr Scand. 1983;72(1):81-85. KQ7E13, KQ8E13. [pmid: 6407278].
126 Guardamagna O, Abello F, Anfossi G, et al. Lipoprotein(a) and family history of cardiovascular disease in children with familial dyslipidemias. J Pediatr. 2011;159(2):314-9. KQ3E7, KQ4E7. [pmid: 21392785].
127 Guardamagna O, Abello F, Baracco V, et al. The treatment of hypercholesterolemic children: efficacy and safety of a combination of red yeast rice extract and policosanols. Nutr Metab Cardiovasc Dis. 2011;21(6):424-9. KQ6E5, KQ7E5. [pmid: 20153154].
128 Guardamagna O, Abello F, Cagliero P, et al. Could dyslipidemic children benefit from glucomannan intake?. Nutrition. 2013;29(7-8):1060-5. KQ6E6, KQ7E6. [pmid: 23759268].
129 Guardamagna O, Cagliero P, Abello F. Management of inherited atherogenic dyslipidemias in children. Ther Apher Dial. 2013;17(2):150-61. KQ6E9, KQ7E9. [pmid: 23551671].
130 Guyton JR, Brown BG, Fazio S, et al. Lipid-altering efficacy and safety of ezetimibe/simvastatin coadministered with extended-release niacin in patients with type IIa or type IIb hyperlipidemia. J Am Coll Cardiol. 2008;51(16):1564-72. KQ6E5, KQ7E5. [pmid: 18420099].
131 Guyton JR, Fazio S, Adewale AJ, et al. Effect of extended-release niacin on new-onset diabetes among hyperlipidemic patients treated with ezetimibe/simvastatin in a randomized controlled trial. Diabetes Care. 2012;35(4):857-60. KQ7E5. [pmid: 22338103].
132 Gylling H, Hallikainen M, Nissinen MJ, et al. The effect of a very high daily plant stanol ester intake on serum lipids, carotenoids, and fat-soluble vitamins. Clin Nutr. 2010;29(1):112-8. KQ6E5, KQ7E5. [pmid: 19709787].
133 Gylling H, Plat J, Turley S, et al. Plant sterols and plant stanols in the management of dyslipidaemia and prevention of cardiovascular disease. Atherosclerosis. 2014;232(2):346-60. KQ6E2, KQ5E2, KQ7E2, KQ8E2. [pmid: 24468148].
134 Hadfield SG, Horara S, Starr BJ, et al. Family tracing to identify patients with familial hypercholesterolaemia: the second audit of the Department of Health Familial Hypercholesterolaemia Cascade Testing Project. Ann Clin Biochem. 2009;46:24-32. KQ2E6, KQ1E6, KQ3E7, KQ4E7. [pmid: 19028807].
135 Hajat C, Harrison O, Al Siksek Z. Weqaya: a population-wide cardiovascular screening program in Abu Dhabi, United Arab Emirates. Am J Public Health. 2012;102(5):909-14. KQ3E6, KQ4E6. [pmid: 21940918].
136 Hammond J, Chinn S, Richardson H, et al. Response to venepuncture for monitoring in primary schools. Arch Dis Child. 1994;70(5):367-9. discussion 369-72. KQ4E6. [pmid: 8017955].
137 Hanlin ER, Hendricks B, Jenkins K, et al. Cardiovascular risk profile: comparison between white and Southeast Asian youth in Wausau SCHOOL Project. WMJ. 2009;108(4):189-93. KQ2E6, KQ3E6, KQ1E6, KQ4E6. [pmid: 19753824].
138 Hanna KJ, Ewart CK, Kwiterovich PO, et al. Child problem solving competence, behavioral adjustment and adherence to lipid-lowering diet. Patient Educ Couns. 1990;16(2):119-31. KQ7E13, KQ8E13. [pmid: 2290766].
139 Hansen D, Michaelsen KF, Skovby F. Growth during treatment of familial hypercholesterolemia. Acta Paediatr. 1992;81(12):1023-1025. KQ7E13, KQ8E13. [pmid: 1290846].
140 Harada-Shiba M, Arai H, Oikawa S, et al. Guidelines for the management of familial hypercholesterolemia. J Atheroscler Thromb. 2012;19(12):1043-60. KQ6E9, KQ7E9. [pmid: 23095242].
141 Harris N, Neufeld EJ, Newburger JW, et al. Analytical performance and clinical utility of a direct LDL-cholesterol assay in a hyperlipidemic pediatric population. Clin Chem. 1996;42(8 Pt 1):1182-8. KQ4E6. [pmid: 8697574].
142 Harvengt C, Desager JP. Colestipol in familial type II hyperlipoproteinemia: a three-year trial. Clin Pharmacol Ther. 1976;20(3):310-314. KQ7E13, KQ8E13. [pmid: 182429].
143 Haymond S, Mohanty N. Pediatric lipid screening rates in the us are low: what can labs do to help?. Clin Chem. 2015. KQ6E6. [pmid: 25724661].
144 Haymond S, Mohanty N. Insulin-like growth factor-1, insulin-like growth factor binding protein-3, and cardiovascular disease risk factors in young black men and white men: the CARDIA Male Hormone Study. Clin Chem. 2004;61(8):1019-21. KQ4E13. [pmid: 25724661].
145 Hernandez-Mijares A, Banuls C, Rocha M, et al. Effects of phytosterol ester-enriched low-fat milk on serum lipoprotein profile in mildly hypercholesterolaemic patients are not related to dietary cholesterol or saturated fat intake. Br J Nutr. 2010;104(7):1018-25. KQ6E5, KQ7E5. [pmid: 20456813].
146 Heyden S, Schneider KA, Roberts KF. Effectiveness of education-screening on cholesterol levels of students. Ann Nutr Metab. 1991;35(2):71-6. KQ4E6. [pmid: 1872595].
147 Hirschler V, Maccallini G, Aranda C, et al. Dyslipidemia without obesity in indigenous Argentinean children living at high altitude. J Pediatr. 2012;161(4):646-51 e1. KQ3E4, KQ4E4. [pmid: 22658786].
148 Hirschler V, Molinari C, Maccallini G, et al. Comparison of different anthropometric indices for identifying dyslipidemia in school children. Clin Biochem. 42225. 2011;44:659-64. KQ3E4, KQ4E4. [pmid: 21349259].
149 Hopcroft KA. Familial hypercholesterolaemia: Child-parent screening may have adverse psychological effects. BMJ. 2007;335(7622):683. KQ3E2, KQ4E2. [pmid: 17916819].
150 Hu C, Tao F, Wan Y, et al. Normal reference values for serum lipid levels in Chinese adolescents between 12 and 18 years of age. J Trop Pediatr. 2010;56(1):13-8. KQ3E6, KQ4E6. [pmid: 19506026].
151 Hui Y, Jie M, Ying L, et al. Profiles of levels of lipids and dyslipidaemia in children from Beijing, China. Cardiol Young. 2009;19(5):456-64. KQ3E6, KQ4E6. [pmid: 19674498].
152 Huijgen R, Abbink EJ, Bruckert E, et al. Colesevelam added to combination therapy with a statin and ezetimibe in patients with familial hypercholesterolemia: a 12-week, multicenter, randomized, double-blind, controlled trial. Clin Ther. 2010;32(4):615-25. KQ6E5, KQ7E5. [pmid: 20435231].
153 Huijgen R, Homsma SJ, Hutten BA, et al. Improved access to life insurance after genetic diagnosis of familial hypercholesterolaemia: cross-sectional postal questionnaire study. Eur J Hum Genet. 2012;20(7):722-8. KQ4E5. [pmid: 22293687].
154 Huijgen R, Kindt I, Verhoeven SB, et al. Two years after molecular diagnosis of familial hypercholesterolemia: majority on cholesterol-lowering treatment but a minority reaches treatment goal. PLoS One. 2010;5(2):e9220. KQ6E5, KQ7E5. [pmid: 20169164].
155 Hussein O, Minasian L, Itzkovich Y, et al. Ezetimibe's effect on platelet aggregation and LDL tendency to peroxidation in hypercholesterolaemia as monotherapy or in addition to simvastatin. Br J Clin Pharmacol. 2008;65(5):637-45. KQ7E5, KQ8E13, KQ6E5. [pmid: 18241285].
156 Ice CL, Cottrell L, Neal WA. Body mass index as a surrogate measure of cardiovascular risk factor clustering in fifth-grade children: results from the coronary artery risk detection in the Appalachian Communities Project. Int J Pediatr Obes. 2009;4(4):316-24. KQ3E6, KQ4E6. [pmid: 19922047].
157 Ice CL, Murphy E, Cottrell L, et al. Morbidly obese diagnosis as an indicator of cardiovascular disease risk in children: results from the CARDIAC Project. Int J Pediatr Obes. 2011;6(2):113-9. KQ3E6, KQ4E6, KQ5E9. [pmid: 20545480].
158 Igase M, Kohara K, Katagi R, et al. Predictive value of the low-density lipoprotein cholesterol to high-density lipoprotein cholesterol ratio for the prevention of stroke recurrence in Japanese patients treated with rosuvastatin. Clin Drug Investig. 2012;32(8):513-21. KQ1E5, KQ2E5, KQ3E5. [pmid: 22741749].
159 Im JA, Lee JW, Shim JY, et al. Association between brachial-ankle pulse wave velocity and cardiovascular risk factors in healthy adolescents. J Pediatr. 2007;150(3):247-51. KQ3E6, KQ4E6. [pmid: 17307539].
160 Izzo R, de Simone G, Giudice R, et al. Effects of nutraceuticals on prevalence of metabolic syndrome and on calculated Framingham Risk Score in individuals with dyslipidemia. J Hypertens. 2010;28(7):1482-7. KQ6E5, KQ7E5. [pmid: 20498621].
161 Jacobson TA, Wertz DA, Kuznik A, et al. Cardiovascular event rates in atorvastatin patients versus patients switching from atorvastatin to simvastatin. Curr Med Res Opin. 2013;29(7):773-81. KQ1E13. [pmid: 23647370].
162 Jago R, Drews KL, McMurray RG, et al. Fatness, fitness, and cardiometabolic risk factors among sixth-grade youth. Med Sci Sports Exerc. 2010;42(8):1502-10. KQ3E6, KQ4E6. [pmid: 20139783].
163 Jahagirdar R, Hemchand KP, Chiplonkar SA, et al. Relationship between body mass index, fat distribution and cardiometabolic risk factors in Indian children and adolescents. Pediatr Obes. 2012;7(4):E37-41. KQ3E4, KQ4E4. [pmid: 22585579].
164 Jehlicka P, Stozicky F, Mayer O, et al. Asymmetric dimethylarginine and the effect of folate substitution in children with familial hypercholesterolemia and diabetes mellitus type 1. Physiol Res. 2009;58(2):179-84. KQ6E6, KQ7E6, KQ8E13. [pmid: 18380539].
165 Jenssen BP, Jacobson MS. Screening adolescents for lipid disorders: what is the best approach?. Adolesc Med State Art Rev. 2008;19(3):507-20. x. KQ1E13, KQ3E13. [pmid: 19227389].
166 John C, Neal W. Screening children for hyperlipidemia by primary care physicians in West Virginia. W V Med J. 2012;108(3):30-5. KQ3E6, KQ4E6. [pmid: 22792653].
167 Jones ML, Martoni CJ, Prakash S. Oral supplementation with probiotic L. reuteri NCIMB 30242 increases mean circulating 25-hydroxyvitamin D: a post hoc analysis of a randomized controlled trial. J Clin Endocrinol Metab. 2013;98(7):2944-51. KQ6E13, KQ7E13. [pmid: 23609838].
168 Juonala M, Viikari JS, Kahonen M, et al. Childhood levels of serum apolipoproteins B and A-I predict carotid intima-media thickness and brachial endothelial function in adulthood: the cardiovascular risk in young Finns study. J Am Coll Cardiol. 2008;52(4):293-9. KQ1E13, KQ8E5. [pmid: 18634985].
169 Kamerow D. Should we screen for and treat childhood dyslipidaemia?. BMJ. 2008;337:a886. KQ1E13. [pmid: 18650230].
170 Kaneshi T, Yoshida T, Ohshiro T, et al. Birthweight and risk factors for cardiovascular diseases in Japanese schoolchildren. Pediatr Int. 2007;49(2):138-43. KQ3E6. [pmid: 17445028].
171 Kang WM, Zhang JS, Liu XX, et al. Prevalence of abnormity of blood lipid and associated factors in health examination population in Beijing. Chin Med Sci J. 2009;24(3):142-6. KQ3E4, KQ4E4. [pmid: 19848313].
172 Kapur NK. Rosuvastatin: a highly potent statin for the prevention and management of coronary artery disease. Expert Rev Cardiovasc Ther. 2007;5(2):161-75. KQ6E2, KQ7E2. [pmid: 17338662].
173 Kastelein JJP, Kusters M, Caceres M, et al. Efficacy and safety of ezetimibe monotherapy in children six to ten years of age with heterozygous familial or non-familial hypercholesterolemia. J Am Coll Cardiol. 2013. KQ7E13, KQ8E13.
174 Kaur S, Kapil U. Dyslipidemia amongst obese children in national capital territory (NCT) of Delhi. Indian J Pediatr. 2011;78(1):55-7. KQ3E4, KQ4E4. [pmid: 20936509].
175 Kavey RE, Allada V, Daniels SR, et al. Cardiovascular risk reduction in high-risk pediatric patients: a scientific statement from the American Heart Association Expert Panel on Population and Prevention Science; the Councils on Cardiovascular Disease in the Young, Epidemiology and Prevention, Nutrition, Physical Activity and Metabolism, High Blood Pressure Research, Cardiovascular Nursing, and the Kidney in Heart Disease; and the Interdisciplinary Working Group on Quality of Care and Outcomes Research. J Cardiovasc Nurs. 2007;22(3):218-53. KQ1E2, KQ8E2, KQ6E2, KQ7E2. [pmid: 17545824].
176 Kavey RE, McBride PE. Should family physicians routinely screen for hypercholesterolemia in children? Yes: the evidence supports universal screening. Am Fam Physician. 2012;86(8). 2-Jan. KQ2E2, KQ1E2, KQ3E2, KQ4E2, KQ5E13. [pmid: 23062164].
177 Kelishadi R, Cook SR, Motlagh ME, et al. Metabolically obese normal weight and phenotypically obese metabolically normal youths: the CASPIAN Study. J Am Diet Assoc. 2008;108(1):82-90. KQ2E4, KQ1E4, KQ3E4, KQ4E4, KQ5E13. [pmid: 18155992].
178 Kelishadi R, Sabri M, Motamedi N, et al. Factor analysis of markers of inflammation and oxidation and echocardiographic findings in children with a positive family history of premature coronary heart disease. Pediatr Cardiol. 2009;30(4):477-81. KQ3E4, KQ4E4. [pmid: 19322601].
179 Kenny D, Ward OC, Mulhern B, et al. Failure of cord serum cholesterol and betalipoprotein as screening tests for familial hyperlipoproteinaemia. Ir J Med Sci. 1984;153(3):100-5. KQ4E6. [pmid: 6724853].
180 Kessler DA, Ortiz C, Grima K, et al. Cardiovascular disease risk assessment and prevention in blood donors. Transfusion. 2012;52(10):2174-82. KQ3E5. [pmid: 22320854].
181 Khalil A, Aggarwal A, Arora S, et al. Lipoprotein (a)--lipid profile and apolipoprotein B in children of young parents with coronary artery disease. Indian Heart J. 2011;63(5):450-3. KQ3E4, KQ4E4. [pmid: 23550425].
182 Kim J, Bhattacharjee R, Kheirandish-Gozal L, et al. Insulin sensitivity, serum lipids, and systemic inflammatory markers in school-aged obese and nonobese children. Int J Pediatr. 2010;2010:846098. KQ3E6, KQ4E13. [pmid: 21274450].
183 Kit BK, Carroll MD, Lacher DA, et al. Trends in serum lipids among U.S. youths aged 6 to 19 years, 1988-2010. JAMA. 2012;308(6):591-600. KQ3E6. [pmid: 22871871].
184 Kleiser C, Schienkiewitz A, Schaffrath Rosario A, et al. Indicators of overweight and cardiovascular disease risk factors among 11- to 17-year-old boys and girls in Germany. Obes Facts. 2011;4(5):379-85. KQ3E7. [pmid: 22166758].
185 Klos K, Hamon A, Clark A, et al. APOA5 polymorphisms influence plasma triglycerides in young, healthy African Americans and whites of the CARDIA Study. J Lipid Res. 2005;46(3):564-571. KQ4E13. [pmid: 15604515].
186 Knebel W, Gastonguay MR, Malhotra B, et al. Population pharmacokinetics of atorvastatin and its active metabolites in children and adolescents with heterozygous familial hypercholesterolemia: selective use of informative prior distributions from adults. J Clin Pharmacol. 2013;53(5):505-16. KQ6E6, KQ7E6. [pmid: 23381936].
187 Koletzko B, Kupke I, Wendel U. Treatment of hypercholesterolemia in children and adolescents. Acta Paediatr. 1992;81(1421908):682-685. KQ7E13, KQ8E13. [pmid: 1421908].
188 Kones R. Primary prevention of coronary heart disease: integration of new data, evolving views, revised goals, and role of rosuvastatin in management. A comprehensive survey. Drug Des Devel Ther. 2011;5:325-80. KQ1E9. [pmid: 21792295].
189 Koren MJ, Scott R, Kim JB, et al. Efficacy, safety, and tolerability of a monoclonal antibody to proprotein convertase subtilisin/kexin type 9 as monotherapy in patients with hypercholesterolaemia (MENDEL): a randomised, double-blind, placebo-controlled, phase 2 study. Lancet. 2012;380(9858):1995-2006. KQ7E5, KQ8E13, KQ6E5. [pmid: 23141812].
190 Koskinen J, Kahonen M, Viikari JS, et al. Conventional cardiovascular risk factors and metabolic syndrome in predicting carotid intima-media thickness progression in young adults: the cardiovascular risk in young Finns study. Circulation. 2009;120(3):229-36. KQ2E5, KQ1E13, KQ3E6. [pmid: 19581494].
191 Kouda K, Nakamura H, Nishio N, et al. Trends in body mass index, blood pressure, and serum lipids in Japanese children: Iwata population-based annual screening (1993-2008). J Epidemiol. 2010;20(3):212-8. KQ3E6. [pmid: 20208399].
192 Krysiak R, Zmuda W, Okopien B. The effect of ezetimibe and simvastatin on hemostasis in patients with isolated hypercholesterolemia. Fundam Clin Pharmacol. 2012;26(3):424-31. KQ6E5, KQ7E5. [pmid: 21392096].
193 Kuba VM, Leone C, Damiani D. Is waist-to-height ratio a useful indicator of cardio-metabolic risk in 6-10-year-old children?. BMC Pediatr. 2013;13:91. KQ3E4. [pmid: 23758779].
194 Kumar SS, Lahey KA, Day A, et al. Comparison of the efficacy of administering a combination of ezetimibe plus fenofibrate versus atorvastatin monotherapy in the treatment of dyslipidemia. Lipids Health Dis. 2009;8:56. KQ7E5, KQ8E13, KQ6E5. [pmid: 20017910].
195 Kusters DM, de Beaufort C, Widhalm K, et al. Paediatric screening for hypercholesterolaemia in Europe. Arch Dis Child. 2012;97(3):272-6. KQ3E2. [pmid: 21949015].
196 Kwiterovich PO Jr, Barton BA, et al. Effects of diet and sexual maturation on low-density lipoprotein cholesterol during puberty: the Dietary Intervention Study in Children (DISC). Circulation. 1997;96(8):2526-33. KQ4E6. [pmid: 9355889].
197 Kwiterovich PO Jr, Heiss G, et al. Assessment of plasma total cholesterol as a test to detect elevated low density (beta) lipoprotein cholesterol levels (type IIa hyperlipoproteinemia) in young subjects from a population-based sample. Am J Epidemiol. 1982;115(2):192-204. KQ4E6. [pmid: 7058778].
198 Lamaida N, Capuano E, Pinto L, et al. The safety of statins in children. Acta Paediatr. 2013;102(9):857-62. KQ6E13, KQ7E13, KQ8E13. [pmid: 23631461].
199 Lamb MM, Ogden CL, Carroll MD, et al. Association of body fat percentage with lipid concentrations in children and adolescents: United States, 1999-2004. Am J Clin Nutr. 2011;94(3):877-83. KQ3E6. [pmid: 21775565].
200 Lambert M, Lupien PJ, Gagne C, et al. Treatment of familial hypercholesterolemia in children and adolescents: effect of lovastatin. Canadian Lovastatin in Children Study Group. Pediatrics. 1996;97(5):619-28. KQ7E13, KQ8E13. [pmid: 8628597].
201 Langslet G, Ose L. Screening methods in the diagnosis and assessment of children and adolescents with familial hypercholesterolemia. Expert Rev Cardiovasc Ther. 2013;11(8):1061-6. KQ2E2, KQ3E2, KQ1E2. [pmid: 23984929].
202 Lannon CM, Earp J. Parents' behavior and attitudes toward screening children for high serum cholesterol levels. Pediatrics. 1992;89:1159-63. KQ7E13, KQ8E13. [pmid: 1594369].
203 Lapinleimu J, Lapinleimu H, Nuotio IO, et al. Expression of common familial dyslipidemias in early childhood. Atherosclerosis. 2009;204(2):573-9. KQ3E7, KQ4E6. [pmid: 19026413].
204 Larsson B, Vaara I. Cholesterol screening of seven-year-old children. How to identify children at risk. Acta Paediatr. 1992;81(4):315-8. KQ4E6. [pmid: 1606391].
205 Lebenthal Y, Horvath A, Dziechciarz P, et al. Are treatment targets for hypercholesterolemia evidence based? Systematic review and meta-analysis of randomised controlled trials. Arch Dis Child. 2010;95(9):673-80. KQ6E13, KQ7E13, KQ8E13, KQ5E6. [pmid: 20515970].
206 Leone L, Malamisura M, Matteo A, et al. Efficacy of a new symbiotic formulation containing lactobacillus paracasei B21060 in children with familial hypercholesterolemia. Digestive and liver disease. 2013. KQ7E13, KQ8E13.
207 Liacouras CA, Coates PM, Gallagher PR, et al. Use of cholestyramine in the treatment of children with familial combined hyperlipidemia. J Pediatr. 8441109. 1993;122:477-482. KQ7E13, KQ8E13. [pmid: 8441109].
208 Lilley JS, Linton MF, Fazio S. Dyslipidemias in children. Pediatr Ann. 2012;41(2):e1-7. KQ1E2. [pmid: 22299622].
209 Lindman AS, Veierod MB, Tverdal A, et al. Nonfasting triglycerides and risk of cardiovascular death in men and women from the Norwegian Counties Study. Eur J Epidemiol. 2010;25(11):789-98. KQ8E5. [pmid: 20890636].
210 Lipshultz SE, Schaechter J, Carrillo A, et al. Can the consequences of universal cholesterol screening during childhood prevent cardiovascular disease and thus reduce long-term health care costs?. Pediatr Endocrinol Rev. 2012;9(4):698-705. KQ4E2, KQ3E2. [pmid: 23304806].
211 Lipska K, Sylaja PN, Sarma PS, et al. Risk factors for acute ischaemic stroke in young adults in South India. J Neurol Neurosurg Psychiatry. 2007;78(9):959-63. KQ2E4, KQ1E4, KQ3E4, KQ4E4, KQ5E13. [pmid: 17220290].
212 Magnussen CG, Raitakari OT, Thomson R, et al. Utility of currently recommended pediatric dyslipidemia classifications in predicting dyslipidemia in adulthood: evidence from the Childhood Determinants of Adult Health (CDAH) study, Cardiovascular Risk in Young Finns Study, and Bogalusa Heart Study. Circulation. 2008;117(1):32-42. KQ3E6, KQ4E13, KQ8E5. [pmid: 18071074].
213 Magnussen CG, Venn A, Thomson R, et al. The association of pediatric low- and high-density lipoprotein cholesterol dyslipidemia classifications and change in dyslipidemia status with carotid intima-media thickness in adulthood evidence from the cardiovascular risk in Young Finns study, the Boga. J Am Coll Cardiol. 2009;53(10):860-9. KQ3E13, KQ4E13, KQ8E5. [pmid: 19264243].
214 Malhotra A, Shafiq N, Arora A, et al. Dietary interventions (plant sterols, stanols, omega-3 fatty acids, soy protein and dietary fibers) for familial hypercholesterolaemia. Cochrane Database Syst Rev. 2014;6. CD001918. KQ1E9, KQ6E13. [pmid: 24913720].
215 Malloy MJ, Kane JP, Rowe JS. Familial hypercholesterolemia in children: treatment with p-aminosalicylic acid. Pediatrics. 1978;61(3):365-72. KQ7E13, KQ8E13. [pmid: 205828].
216 Manchester RA, McDuffie C, Diamond E. Screening for hypercholesterolemia in college students. J Am Coll Health. 1989;37(4):149-53. KQ4E6. [pmid: 2926025].
217 Mar Bibiloni M, Martinez E, Llull R, et al. Metabolic syndrome in adolescents in the Balearic Islands, a Mediterranean region. Nutr Metab Cardiovasc Dis. 2011;21(6):446-54. KQ3E6, KQ4E6. [pmid: 20211550].
218 Marais AD, Raal FJ, Stein EA, et al. A dose-titration and comparative study of rosuvastatin and atorvastatin in patients with homozygous familial hypercholesterolaemia. Atherosclerosis. 2008;197(1):400-6. KQ6E5, KQ7E5. [pmid: 17727860].
219 Martin AC, Coakley J, Forbes DA, et al. Familial hypercholesterolaemia in children and adolescents: a new paediatric model of care. J Paediatr Child Health. 2013;49(4):E263-72. KQ1E2, KQ6E2, KQ8E13, KQ7E2. [pmid: 23252991].
220 Martin SS, Blaha MJ, Elshazly MB, et al. Comparison of a novel method vs the Friedewald equation for estimating low-density lipoprotein cholesterol levels from the standard lipid profile. JAMA. 2013;310(19):2061-8. KQ3E6. [pmid: 24240933].
221 Martin SS, Blaha MJ, Toth PP, et al. Very large database of lipids: rationale and design. Clin Cardiol. 2013;36(11):641-8. KQ2E7, KQ1E7, KQ3E7. [pmid: 24122913].
222 Mata N, Alonso R, Badimon L, et al. Clinical characteristics and evaluation of LDL-cholesterol treatment of the Spanish Familial Hypercholesterolemia Longitudinal Cohort Study (SAFEHEART). Lipids Health Dis. 2011;10:94. KQ6E5, KQ3E5, KQ2E5. [pmid: 21663647].
223 Matsuyama T, Shoji K, Takase H, et al. Effects of phytosterols in diacylglycerol as part of diet therapy on hyperlipidemia in children. Asia Pac J Clin Nutr. 2007;16:40-48. KQ6E9, KQ8E13, KQ7E9. [pmid: 17215179].
224 McCrindle BW, O'Neill MB, Cullen-Dean G, et al. Acceptability and compliance with two forms of cholestyramine in the treatment of hypercholesterolemia in children: a randomized, crossover trial. J Pediatr. 1997;130(2):266-73. KQ7E13, KQ8E13. [pmid: 9042130].
225 McDuffie JR, Calis KA, Uwaifo GI, et al. Three-month tolerability of orlistat in adolescents with obesity-related comorbid conditions. Obes Res. 2002;10(7):642-650. KQ7E13, KQ8E13. [pmid: 12105286].
226 McHale SM, Tershakovec AM, Corneal DA, et al. Psychosocial factors in nutrition education for hypercholesterolemic children. Ann Behav Med. 1998;20(3):233-40. KQ7E13, KQ8E13. [pmid: 9989332].
227 Meulenkamp TM, Tibben A, Mollema ED, et al. Predictive genetic testing for cardiovascular diseases: impact on carrier children. Am J Med Genet A. 2008;146A(24):3136-46. KQ4E7. [pmid: 19012345].
228 Mitka M. Screening misses high LDL in many youths. JAMA. 2010;304(9):952-3. KQ3E2, KQ4E2. [pmid: 20810367].
229 Mohaupt MG, Karas RH, Babiychuk EB, et al. Association between statin-associated myopathy and skeletal muscle damage. CMAJ. 2009;181(1-2):E11-8. KQ7E5. [pmid: 19581603].
230 Moodie D. Cholesterol screening in children. Congenit Heart Dis. 2012;7(1). 2-Jan. KQ3E2. [pmid: 22276662].
231 Muir LA, George PM, Whitehead L. Using the experiences of people with familial hypercholesterolaemia to help reduce the risk of cardiovascular disease: a qualitative systematic review. J Adv Nurs. 2012;68(9):1920-32. KQ4E13, KQ3E2. [pmid: 22348692].
232 Nader PR, Yang M, Luepker RV, et al. Parent and physician response to children's cholesterol values of 200 mg/dL or greater: the Child and Adolescent Trial for Cardiovascular Health Experiment. Pediatrics. 1997;99(5):E5. KQ7E13, KQ8E13. [pmid: 9113962].
233 Negele L, Schneider B, Ristl R, et al. Effect of a low-fat diet enriched either with rapeseed oil or sunflower oil on plasma lipoproteins in children and adolescents with familial hypercholesterolaemia. Results of a pilot study. Eur J Clin Nutr. 2015;69(3):337-43. KQ6E9. [pmid: 25424602].
234 Neil A, Cooper J, Betteridge J, et al. Reductions in all-cause, cancer, and coronary mortality in statin-treated patients with heterozygous familial hypercholesterolaemia: a prospective registry study. Eur Heart J. 2008;29(21):2625-33. KQ5E13, KQ8E5. [pmid: 18840879].
235 Noto D, Cefalu AB, Barraco G, et al. Plasma non-cholesterol sterols: a useful diagnostic tool in pediatric hypercholesterolemia. Pediatr Res. 2010;67(2):200-4. KQ3E6. [pmid: 20091938].
236 O'Gorman CS, Higgins MF, O'Neill MB. Systematic review and metaanalysis of statins for heterozygous familial hypercholesterolemia in children: evaluation of cholesterol changes and side effects. Pediatr Cardiol. 2009;30(4):482-9. KQ5E13, KQ6E13, KQ7E13. [pmid: 19189168].
237 O'Gorman CS, O'Neill MB, Conwell LS. Considering statins for cholesterol-reduction in children if lifestyle and diet changes do not improve their health: a review of the risks and benefits. Vasc Health Risk Manag. 2011;7. 14-Jan. KQ5E13, KQ6E2, KQ7E2. [pmid: 21339908].
238 O'Grady MJ, Brown AM, O'Neill MB. Cholesterol screening in an at-risk pediatric population. Pediatr Cardiol. 2008;29(3):609-13. KQ3E7, KQ4E6. [pmid: 18094916].
239 Ohta T, Nakamura R, Ikeda Y, et al. Follow up study on children with dyslipidaemia detected by mass screening at 18 months of age: effect of 12 months dietary treatment. Eur J Pediatr. 1993;152(11):939-43. KQ7E13, KQ8E13. [pmid: 8276030].
240 O'Loughlin J, Lauzon B, Paradis G, et al. Usefulness of the American Academy of Pediatrics recommendations for identifying youths with hypercholesterolemia. Pediatrics. 2004;113(6):1723-7. KQ4E6. [pmid: 15173497].
241 Pasquali SK, Li JS. Prevention of future cardiovascular disease in high-risk pediatric patients: a role for lipid lowering therapy?. Circ Cardiovasc Qual Outcomes. 2008;1(2):131-3. KQ1E2. [pmid: 20031800].
242 Perry CM. Colesevelam: in pediatric patients with heterozygous familial hypercholesterolemia. Paediatr Drugs. 2010;12(2):133-40. KQ6E11, KQ7E11. [pmid: 20218749].
243 Plana N, Nicolle C, Ferre R, et al. Plant sterol-enriched fermented milk enhances the attainment of LDL-cholesterol goal in hypercholesterolemic subjects. Eur J Nutr. 2008;47(1):32-9. KQ6E5, KQ7E5. [pmid: 18193377].
244 Pletcher MJ, Bibbins-Domingo K, Liu K, et al. Nonoptimal lipids commonly present in young adults and coronary calcium later in life: the CARDIA (Coronary Artery Risk Development in Young Adults) study. Ann Intern Med. 2010;153(3):137-46. KQ5E13. [pmid: 20679558].
245 Polonsky SM, Bellet PS, Sprecher DL. Primary hyperlipidemia in a pediatric population: classification and effect of dietary treatment. Pediatrics. 1993;91(1):92-6. KQ4E6. [pmid: 8416512].
246 Porkka KV, Viikari JS, Taimela S, et al. Tracking and predictiveness of serum lipid and lipoprotein measurements in childhood: a 12-year follow-up. The Cardiovascular Risk in Young Finns study. Am J Epidemiol. 1994;140(12):1096-110. KQ4E6. [pmid: 7998592].
247 Primrose ED, Savage JM, Boreham CA, et al. Cholesterol screening and family history of vascular disease. Arch Dis Child. 1994;71(3):239-42. KQ4E6. [pmid: 7979498].
248 Raal FJ, Stein EA, Dufour R, et al. PCSK9 inhibition with evolocumab (AMG 145) in heterozygous familial hypercholesterolaemia (RUTHERFORD-2): a randomised, double-blind, placebo-controlled trial. Lancet. 2015;385(9965):331-40. KQ1E5, KQ3E5. [pmid: 25282519].
249 Resnicow K, Cross D, Lacosse J, et al. Evaluation of a school-site cardiovascular risk factor screening intervention. Prev Med. 1993;22(6):838-56. KQ4E6. [pmid: 8115342].
250 Resnicow K, Futterman R, Vaughan RD. Body mass index as a predictor of systolic blood pressure in a multiracial sample of U.S. schoolchildren. Ethn Dis. 1993;3(4):351-61. KQ4E6. [pmid: 7888986].
251 Richard Hobbs FD, Gensini G, John Mancini GB, et al. International open-label studies to assess the efficacy and safety of single-pill amlodipine/atorvastatin in attaining blood pressure and lipid targets recommended by country-specific guidelines: the JEWEL programme. Eur J Cardiovasc Prev Rehabil. 2009;16(4):472-80. KQ6E5, KQ7E5, KQ5E5. [pmid: 19407658].
252 Rifai N, Neufeld E, Ahlstrom P, et al. Failure of current guidelines for cholesterol screening in urban African-American adolescents. Pediatrics. 1996;98(3 Pt 1):383-8. KQ4E6. [pmid: 8784361].
253 Ritchie SK, Murphy EC, Ice C, et al. Universal versus targeted blood cholesterol screening among youth: The CARDIAC project. Pediatrics. 2010;126(2):260-5. KQ3E11, KQ4E6. [pmid: 20624798].
254 Rohatgi A. Cholesterol screening in children: makes sense but what is the impact?. Future Cardiology. 2010;6(3):275-280. KQ1E2. [pmid: 20462333].
255 Rosenberg E, Lamping DL, Joseph L, et al. Cholesterol screening of children at high risk: behavioural and psychological effects. CMAJ. 1997;156(4):489-96. KQ7E13, KQ8E13. [pmid: 9054818].
256 Roseneu M, Van Biervliet JP. Screening and follow-up of infants with dyslipoproteinemia. Prog Clin Biol Res. 1985;188:79-86. KQ4E6. [pmid: 3933016].
257 Rosenthal SL, Knauer-Black S, Stahl MP, et al. The psychological functioning of children with hypercholesterolemia and their families. A preliminary investigation. Clin Pediatr (Phila). 1993;32(3):135-41. KQ7E13, KQ8E13. [pmid: 8453828].
258 Rowan C, Brinker AD, Nourjah P, et al. Rhabdomyolysis reports show interaction between simvastatin and CYP3A4 inhibitors. Pharmacoepidemiol Drug Saf. 2009;18(4):301-9. KQ7E5. [pmid: 19206087].
259 Russo MW, Scobey M, Bonkovsky HL. Drug-induced liver injury associated with statins. Semin Liver Dis. 2009;29(4):412-22. KQ7E5. [pmid: 19826975].
260 Ryu SK, Hutten BA, Vissers MN, et al. Lipoprotein-associated phospholipase A2 mass and activity in children with heterozygous familial hypercholesterolemia and unaffected siblings: effect of pravastatin. J Clin Lipidol. 2011;5(1):50-6. KQ6E11, KQ7E6. [pmid: 21262507].
261 Sabzghabaee AM, Ataei E, Kelishadi R, et al. Effect of hibiscus sabdariffa calices on dyslipidemia in obese adolescents: a triple-masked randomized controlled trial. Mater Sociomed. 2013;25(2):76-9. KQ6E5, KQ7E5. [pmid: 24082826].
262 Sabzghabaee AM, Khayam I, Kelishadi R, et al. Effect of Zizyphus jujuba fruits on dyslipidemia in obese adolescents: a triple-masked randomized controlled clinical trial. Med Arch. 2013;67(3):156-9. KQ6E5, KQ7E5. [pmid: 23848030].
263 Saenger AK. Universal lipid screening in children and adolescents: a baby step toward primordial prevention?. Clin Chem. 2012;58(8):1179-81. KQ1E2. [pmid: 22510399].
264 Sanchez Bayle M, Gonzalez Vergaz A, Garcia Cuartero B, et al. Is a parental history of coronary arterial disease in children as discriminating as their lipoprotein profile? Nino Jesus Group. Int J Cardiol. 1992;36(3):267-71. KQ4E6. [pmid: 1428260].
265 Schwarz KB, Goldstein PD, Witztum JL, et al. Fat-soluble vitamin concentrations in hypercholesterolemic children treated with colestipol. Pediatrics. 7354970. 1980;65:243-250. KQ7E13, KQ8E13. [pmid: 7354970].
266 Shafiq N, Bhasin B, Pattanaik S, et al. A meta-analysis to evaluate the efficacy of statins in children with familial hypercholesterolemia. Int J Clin Pharmacol Ther. 2007;45(10):548-55. KQ6E13, KQ7E13. [pmid: 17966840].
267 Shafiq N, Singh M, Kaur S, et al. Dietary treatment for familial hypercholesterolaemia. Cochrane Database Syst Rev. 2010;(1). CD001918. KQ6E13, KQ7E13. [pmid: 20091526].
268 Shah S, Ceska R, Gil-Extremera B, et al. Efficacy and safety of extended-release niacin/laropiprant plus statin vs. doubling the dose of statin in patients with primary hypercholesterolaemia or mixed dyslipidaemia. Int J Clin Pract. 2010;64(6):727-38. KQ6E5, KQ7E5. [pmid: 20518948].
269 Shamir R, Feig JE, Fisher EA. Therapeutic approach to childhood hypercholesterolemia. Pediatr Endocrinol Rev. 2007;5(2):649-55. KQ3E2, KQ4E2. [pmid: 18084159].
270 Shannon BM, Tershakovec AM, Martel JK, et al. Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94(6 Pt 1):923-7. KQ4E6. [pmid: 7971012].
271 Sharma P, Boyers D, Boachie C, et al. Elucigene FH20 and LIPOchip for the diagnosis of familial hypercholesterolaemia: a systematic review and economic evaluation. Health Technol Assess. 2012;16(17):1-266. KQ3E5. [pmid: 22469073].
272 Shea S, Basch CE, Irigoyen M, et al. Failure of family history to predict high blood cholesterol among Hispanic preschool children. Prev Med. 1990;19(4):443-55. KQ4E6. [pmid: 2204914].
273 Shepherd J, Vidt DG, Miller E, et al. Safety of rosuvastatin: update on 16,876 rosuvastatin-treated patients in a multinational clinical trial program. Cardiology. 2007;107(4):433-43. KQ7E5. [pmid: 17363845].
274 Shulman ST. Screening all children for lipid disorders. Pediatr Ann. 2012;41(7):260-1. KQ1E2. [pmid: 22765033].
275 Sonnett T, Robinson J, Milani P, et al. Role of colesevelam in managing heterozygous familial hypercholesterolemia in adolescents and children. Adolesc Health Med Ther. 2010;1:53-60. KQ6E2, KQ7E2. [pmid: 24600261].
276 Starc TJ, Belamarich PF, Shea S, et al. Family history fails to identify many children with severe hypercholesterolemia. Am J Dis Child. 1991;145(1):61-4. KQ4E13, KQ5E13. [pmid: 1985431].
277 Stefanutti C, Lucani G, Vivenzio A, et al. Diet only and diet plus simvastatin in the treatment of heterozygous familial hypercholesterolemia in childhood. Drugs Exp Clin Res. 1999;25(1):23-8. KQ7E13, KQ8E13. [pmid: 10337501].
278 Stein EA. Treatment of familial hypercholesterolemia with drugs in children. Arteriosclerosis. 1989;9(1 Suppl):145-151. KQ7E13, KQ8E13. [pmid: 2912428].
279 Stein EA. Statins and children: whom do we treat and when?. Circulation. 2007;116(6):594-5. KQ6E2, KQ7E2. [pmid: 17679628].
280 Stein EA, Honarpour N, Wasserman SM, et al. Effect of the proprotein convertase subtilisin/kexin 9 monoclonal antibody, AMG 145, in homozygous familial hypercholesterolemia. Circulation. 2013;128(19):2113-20. KQ6E5, KQ7E5. [pmid: 24014831].
281 Steiner NJ, Neinstein LS, Pennbridge J. Hypercholesterolemia in adolescents: effectiveness of screening strategies based on selected risk factors. Pediatrics. 1991;88(2):269-75. KQ4E6. [pmid: 1861925].
282 Steinmetz J, Morin C, Panek E, et al. Biological variations in hyperlipidemic children and adolescents treated with fenofibrate. Clin Chim Acta. 1981;112(1):43-43. KQ7E13, KQ8E13. [pmid: 6113065].
283 Sultan SM, Schupf N, Dowling MM, et al. Review of lipid and lipoprotein(a) abnormalities in childhood arterial ischemic stroke. Int J Stroke. 2014;9(1):79-87. KQ1E13, KQ8E9. [pmid: 24148253].
284 Superko HR, Garrett BC, King SB, et al. Effect of combination nicotinic acid and gemfibrozil treatment on intermediate density lipoprotein, and subclasses of low density lipoprotein and high density lipoprotein in patients with combined hyperlipidemia. Am J Cardiol. 2009;103(3):387-92. KQ6E5, KQ7E5. [pmid: 19166694].
285 Tan AT, Low LP, Lim CH, et al. Effects of rosuvastatin on low-density lipoprotein cholesterol and plasma lipids in Asian patients with hypercholesterolemia. J Atheroscler Thromb. 2009;16(4):509-16. KQ6E13, KQ7E13. [pmid: 19729865].
286 Tandon N, Garg MK, Singh Y, et al. Prevalence of metabolic syndrome among urban Indian adolescents and its relation with insulin resistance (HOMA-IR). J Pediatr Endocrinol Metab. 42320. 2013;26:1123-30. KQ3E4, KQ4E4. [pmid: 23751385].
287 Task Force for the management of dyslipidaemias of the European Society of Cardiology and the European Atherosclerosis Society, Catapano AL, Reiner Z, et al. ESC/EAS Guidelines for the management of dyslipidaemias: the Task Force for the management of dyslipidaemias of the European Society of Cardiology (ESC) and the European Atherosclerosis Society (EAS). Atherosclerosis. 2011:S1-44. KQ6E2, KQ7E2. [pmid: 21723445].
288 Teber S, Deda G, Akar N, et al. Lipoprotein (a) levels in childhood arterial ischemic stroke. Clin Appl Thromb Hemost. 2010;16(2):214-7. KQ8E5. [pmid: 19752039].
289 Terai N, Spoerl E, Fischer S, et al. Statins affect ocular microcirculation in patients with hypercholesterolaemia. Acta Ophthalmol. 2011;89(6):e500-4. KQ6E5, KQ7E5. [pmid: 21457486].
290 Teramoto T, Ohashi Y, Nakaya N, et al. Practical risk prediction tools for coronary heart disease in mild to moderate hypercholesterolemia in Japan: originated from the MEGA study data. Circ J. 2008;72(10):1569-75. KQ1E5, KQ3E5, KQ4E5. [pmid: 18762707].
291 Teramoto T, Shirakawa M, Kikuchi M, et al. Efficacy and safety of the cholesteryl ester transfer protein inhibitor anacetrapib in Japanese patients with dyslipidemia. Atherosclerosis. 2013;230(1):52-60. KQ6E6, KQ7E7. [pmid: 23958252].
292 Ticho BS, Neufeld EJ, Newburger JW, et al. Utility of direct measurement of low-density lipoprotein cholesterol in dyslipidemic pediatric patients. Arch Pediatr Adolesc Med. 1998;152(8):787-91. KQ4E6. [pmid: 9701139].
293 Tonstad S. Familial hypercholesterolaemia: a pilot study of parents' and children's concerns. Acta Paediatr. 1996;85(11):1307-13. KQ7E13, KQ8E13. [pmid: 8955457].
294 Tonstad S, Novik TS, Vandvik IH. Psychosocial function during treatment for familial hypercholesterolemia. Pediatrics. 1996;98(2 Pt 1):249-55. KQ4E6. [pmid: 8692626].
295 Tonstad S, Ose L. Colestipol tablets in adolescents with familial hypercholesterolaemia. Acta Paediatr. 1996;85(9):1080-1082. KQ7E13, KQ8E13. [pmid: 8888922].
296 Tonstad S, Refsum H, Ose L, et al. The C677T mutation in the methylenetetrahydrofolate reductase gene predisposes to hyperhomocysteinemia in children with familial hypercholesterolemia treated with cholestyramine. J Pediatr. 9506661. 1998;132:365-368. KQ7E13, KQ8E13. [pmid: 9506661].
297 Toth PP, Ballantyne CM, Davidson MH, et al. Changes in prescription patterns before and after reporting of the Ezetimibe and Simvastatin in Hypercholesterolemia Enhances Atherosclerosis Regression trial (ENHANCE) results and expected effects on low-density lipoprotein-cholesterol reduction. J Clin Lipidol. 2012;6(2):180-91. KQ6E5, KQ7E5. [pmid: 22385552].
298 Troxler RG, Park MK, Miller MA, et al. Predictive value of family history in detecting hypercholesterolemia in predominantly Hispanic adolescents. Tex Med. 1991;87(11):75-9. KQ4E6. [pmid: 1759247].
299 Van Biervliet JP, Vercaemst R, De Keersgieter W, et al. Evolution of lipoprotein patterns in newborns. Acta Paediatr Scand. 1980;69(5):593-6. KQ4E6. [pmid: 7234379].
300 Van Biervliet JP, Vinaimont N, Caster H, et al. A screening procedure for dyslipoproteinemia in the newborn. Apoprotein quantitation on dried blood spots. Clin Chim Acta. 1982;120(2):191-200. KQ4E6. [pmid: 7067144].
301 van der Graaf A, Cuffie-Jackson C, Vissers MN, et al. Online appendix to ‘Efficacy and safety of coadministration of ezetimibe and simvastatin in adolescents with heterozygous familial hypercholesterolemia.’. J Am Coll Cardiol. 2008;52(17):1421-9. KQ6E13, KQ7E13. [pmid: 18940534].
302 van der Graaf A, Kastelein JJ, Wiegman A. Heterozygous familial hypercholesterolaemia in childhood: cardiovascular risk prevention. J Inherit Metab Dis. 2009;32(6):699-705. KQ6E2, KQ7E2. [pmid: 19898954].
303 van der Graaf A, Rodenburg J, Vissers MN, et al. Atherogenic lipoprotein particle size and concentrations and the effect of pravastatin in children with familial hypercholesterolemia. J Pediatr. 2008;152(6):873-8. KQ7E6, KQ6E6. [pmid: 18492534].
304 Verduci E, Agostoni C, Radaelli G, et al. Blood lipids profile in hyperlipidemic children undergoing different dietary long chain polyunsaturated supplementations: a preliminary clinical trial. Int J Food Sci Nutr. 2013;65(3):375-9. KQ6E5, KQ7E5. [pmid: 24228803].
305 Viigimaa M, Vaverkova H, Farnier M, et al. Ezetimibe/simvastatin 10/20 mg versus rosuvastatin 10 mg in high-risk hypercholesterolemic patients stratified by prior statin treatment potency. Lipids Health Dis. 2010;9:127. KQ6E5, KQ7E5. [pmid: 21050476].
306 Vladutiu GD, Glueck CJ, Schultz MT, et al. beta-Lipoprotein quantitation in cord blood spotted on filter paper: a screening test. Clin Chem. 1980;26(9):1285-90. KQ4E6. [pmid: 7398043].
307 Vobecky JS, David P, Vobecky J. Dietary habits in relation to tracking of cholesterol level in young adolescents: a nine-year follow-up. Ann Nutr Metab. 1988;32(42130):312-23. KQ4E6. [pmid: 3254688].
308 Vuorio A, Docherty KF, Humphries SE, et al. Statin treatment of children with familial hypercholesterolemia--trying to balance incomplete evidence of long-term safety and clinical accountability: are we approaching a consensus?. Atherosclerosis. 2013;226(2):315-20. KQ5E13, KQ6E2, KQ7E2. [pmid: 23141908].
309 Vuorio A, Kuoppala J, Kovanen PT, et al. Statins for children with familial hypercholesterolemia. Cochrane Database Syst Rev. 2010;(7). CD006401. KQ5E13, KQ6E13, KQ7E13. [pmid: 20614444].
310 Vuorio A, Kuoppala J, Kovanen PT, et al. Statins for children with familial hypercholesterolemia. Cochrane Database Syst Rev. 2014;7. CD006401. KQ6E13, KQ7E13, KQ8E13. [pmid: 25054950].
311 Wadowski SJ, Karp RJ, Murray-Bachmann R, et al. Family history of coronary artery disease and cholesterol: screening children in a disadvantaged inner-city population. Pediatrics. 1994;93(1):109-13. KQ4E6. [pmid: 8265303].
312 Wald DS, Bestwick JP, Wald NJ. Child-parent screening for familial hypercholesterolaemia: screening strategy based on a meta-analysis. BMJ. 2007;335(7620):599. KQ3E9. [pmid: 17855284].
313 Warner M. Child-parent screening for familial hypercholesterolaemia: screening strategy based on a meta-analysis. Ann Clin Biochem. 2008;45:114. KQ3E2, KQ8E13. [pmid: 18275690].
314 Weghuber D, Widhalm K. Effect of 3-month treatment of children and adolescents with familial and polygenic hypercholesterolaemia with a soya-substituted diet. Br J Nutr. 2008;99(2):281-6. KQ6E13, KQ7E13. [pmid: 17697400].
315 Weiner K, Durrington PN. Patients' understandings and experiences of familial hypercholesterolemia. Community Genet. 2008;11(5):273-82. KQ4E5. [pmid: 18493125].
316 West RJ, Fosbrooke AS, Lloyd JK. Treatment of children with familial hypercholesterolaemia. Postgrad Med J. 1975;51(8). suppl 82-87. KQ7E13, KQ8E13. [pmid: 768952].
317 West RJ, Lloyd JK. Use of cholestyramine in treatment of children with familial hypercholesterolaemia. Arch Dis Child. 1973;48(5):370-374. KQ7E13, KQ8E13. [pmid: 4703066].
318 West RJ, Lloyd JK. The effect of cholestyramine on intestinal absorption. Gut. 1975;16(2):93-98. KQ7E13, KQ8E13. [pmid: 1168607].
319 West RJ, Lloyd JK, Leonard JV. Long-term follow-up of children with familial hypercholesterolaemia treated with cholestyramine. Lancet. 1980;2(8200):873-875. KQ7E13, KQ8E13. [pmid: 6107543].
320 Wheeler KA, West RJ, Lloyd JK, et al. Double blind trial of bezafibrate in familial hypercholesterolaemia. Arch Dis Child. 1985;60(1):34-7. KQ7E13, KQ8E13. [pmid: 3882058].
321 Widhalm K, Dirisamer A, Lindemayr A, et al. Diagnosis of families with familial hypercholesterolaemia and/or Apo B-100 defect by means of DNA analysis of LDL-receptor gene mutations. J Inherit Metab Dis. 2007;30(2):239-47. KQ3E7. [pmid: 17347910].
322 Wierzbicki AS, Viljoen A. Hyperlipidaemia in paediatric patients: the role of lipid-lowering therapy in clinical practice. Drug Saf. 2010;33(2):115-25. KQ7E2. [pmid: 20082538].
323 Wilcken DE, Blades BL, Dudman NP. A neonatal screening approach to the detection of familial hypercholesterolaemia and family-based coronary prevention. J Inherit Metab Dis. Suppl 1. 1988;11:87-90. KQ4E6. [pmid: 3141689].
324 Williams RR, Hunt SC, Barlow GK, et al. Prevention of familial cardiovascular disease by screening for family history and lipids in youths. Clin Chem. 1992;38(8B Pt 2):1555-60. KQ4E6. [pmid: 1643739].
325 Wilson DP, Gidding SS. Learning More about Dyslipidemia in Childhood. J Pediatr. 2013;164(3):442-4. KQ1E2. [pmid: 24373576].
326 Wineinger NE, Harper A, Libiger O, et al. Genomic risk models improve prediction of longitudinal lipid levels in children and young adults. Front Genet. 2013;4:86. KQ3E5, KQ6E5, KQ7E5. [pmid: 23734161].
327 Wong H, Chahal N, Manlhiot C, et al. Flaxseed in pediatric hyperlipidemia: a placebo-controlled, blinded, randomized clinical trial of dietary flaxseed supplementation for children and adolescents with hypercholesterolemia. JAMA Pediatr. 2013;167(8):708-13. KQ6E5, KQ7E5. [pmid: 23733031].
328 Wong ND, Hei TK, Qaqundah PY, et al. Television viewing and pediatric hypercholesterolemia. Pediatrics. 1992;90(1 Pt 1):75-9. KQ4E6. [pmid: 1614784].
329 Wu BU, Pandol SJ, Liu IL. Simvastatin is associated with reduced risk of acute pancreatitis: findings from a regional integrated healthcare system. Gut. 2015;64(1):133-8. KQ8E13. [pmid: 24742713].
330 Xu H, Li Y, Liu A, et al. Prevalence of the metabolic syndrome among children from six cities of China. BMC Public Health. 2012;12:13. KQ3E4, KQ4E4. [pmid: 22225617].
331 Zachariah JP, Johnson PK. Pediatric lipid management: an earlier approach. Endocrinol Metab Clin North Am. 2014;43(4):981-92. KQ1E2, KQ3E2. [pmid: 25432392].
332 Zakim D, Fritz C, Braun N, et al. Computerized history-taking as a tool to manage dyslipidemia. Vasc Health Risk Manag. 2010;6:1039-46. KQ3E5, KQ6E5, KQ7E5. [pmid: 21127700].
333 Zung A, Shachar S, Zadik Z, et al. Soy-derived isoflavones treatment in children with hypercholesterolemia: a pilot study. J Pediatr Endocrinol Metab. 42006. 2010;23:133-41. KQ6E5, KQ7E5. [pmid: 20432816].