# Ongoing Studies

We identified one potentially relevant ongoing or recently completed RCT through four registries: ClinicalTrials.gov (http://clinicaltrials.gov), Current Controlled Trials (http://www.controlled-trials.com), Australian New Zealand Clinical Trials Registry (http://www.anzctr.org.au) and the World Health Organization's International Clinical Trials Registry Platform (http://www.who.int/ictrp). We restricted our searches to (heterozygous) familial hypercholesterolemia in children.

One RCT studied rapeseed oil and sunflower oil as treatments for FH in children. This study, “Effect of a Diet With Rapeseed Oil /Sunflower Oil on Lipoprotein in Children and Adolescents With Familial Hypercholesterolemia,” was last updated on clinicaltrials.gov in June of 2009 (NCT00924274).1 It is a randomized double-blind trial for the purpose of treatment. One group received rapeseed oil as a dietary supplement, and the active comparator group received sunflower oil. The current recruitment status of the study is unknown.

We identified one patient registry study currently recruiting participants as of February 27, 2015. This study is based in Montreal and is establishing an FH patient registry of children, adults, and seniors with FH. The primary outcome measure is the number of patients with FH. The secondary outcome measure is the prevalence of FH. The study began in November 2013. The estimated study completion date is November 2020.^2^

We identified a Russian cohort and registry of FH begun in January 2014 that has an estimated completion date of December 2026, and a primary outcome measure completion date of December 2016.^3^

One randomized double crossover study of a Mediterranean diet in children with FH or familial combined hyperlipidemia has completed. Results are not yet available.4

## References

1 Effect of a Diet With Rapeseed Oil/Sunflower Oil on Lipoprotein in Children and Adolescents With Familial Hypercholesterolemia. Bethesda (MD). National Library of Medicine (US). [2015 March 3]. https://clinicaltrials.gov/ct2/show/NCT00924274.
2 Familial Hypercholesterolemia Canada / Hypercholesterolemie Familiale Canada. Bethesda (MD). National Library of Medicine (US). [2015 March 3]. https://clinicaltrials.gov/ct2/show/NCT02009345.
3 Prospective Russian Study Evaluating the Extent of Underdiagnosed and Undertreated of Familial Hypercholesterolaemia in the Population. National Library of Medicine (US). [2015 March 3]. https://clinicaltrials.gov/ct2/show/NCT02208869.
4 Endothelial Assessment of Risk From Lipids in Youth: Mediterranean Diet. Bethesda (MD). National Library of Medicine (US). [2015 March 3]. https://clinicaltrials.gov/ct2/show/NCT01308710.