# Detailed Methods

## Search Strategy

Sources searched:

Cochrane Central Register of Controlled Clinical Trials, via Wiley

Medline, via Ovid

PubMed, publisher-supplied

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- adj# = adjacent within x number of words
- pt = publication type
- * = truncation
- ae = adverse effects
- ci = chemically induced
- de=drug effects
- mo=mortality
- nm = name of substance

### Cochrane Central Register of Controlled Clinical Trials

#1 (hyperlipid*emia*:ti,ab,kw or dyslipid*emia*:ti,ab,kw or hypercholesterol*emia*:ti,ab,kw or hyperlipoprotein*emia*:ti,ab,kw or hypertriglycerid*emia*:ti,ab,kw or dysbetalipoprotein*emia*:ti,ab,kw)
#2 (familial next hypercholesterol*emi*):ti,ab,kw or (familial next hyperlipid*emi*):ti,ab,kw or (essential next hypercholesterol*emi*):ti,ab,kw or (familial near/3 apolipoprotein):ti,ab,kw
#3 “heterozygous fh”:ti,ab,kw or “homozygous fh”:ti,ab,kw
#4 (lipid next disorder*):ti,ab,kw or (lipid near/3 dysfunction*):ti,ab,kw
#5 (high or elevated or abnormal or aberr*):ti,ab,kw near/3 (cholesterol or lipid* or LDL*):ti,ab,kw #6 (low or decrease* or deficien* or abnormal or aberr*):ti,ab,kw near/3 HDL*:ti,ab,kw
#7 (cholesterol or lipid* or lipoprotein* or LDL* or HDL*):ti,ab,kw near/3 (detect* or measure* or check* or assess* or analyz* or analys* or test* or panel* or profile*):ti,ab,kw
#8 (fasting or nonfasting or non-fasting):ti,ab,kw next (lipid* or lipoprotein* or cholesterol):ti,ab,kw
#9 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8
#10 (child*:ti,ab,kw or adolesc*:ti,ab,kw or teen:ti,ab,kw or teens:ti,ab,kw or teenage*:ti,ab,kw or youth:ti,ab,kw or youths:ti,ab,kw or p*ediatric*:ti,ab,kw)
#11 #9 and #10 from 2007 to 2014, in Trials

### MEDLINE

#### Dyslipidemia screening, screening harms

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process and Other Non-Indexed Citations <June 2, 2015>, Ovid MEDLINE(R) Daily Update <June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. or/1-23
25. Cholesterol/bl
26. Triglycerides/bl
27. Lipoproteins/bl
28. Cholesterol, HDL/
29. Cholesterol, LDL/
30. Apolipoprotein B-100/
31. Apolipoprotein B 100.ti,ab.
32. apob 100.ti,ab.
33. apo b 100.ti,ab.
34. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
35. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
36. or/25-35
37. Mass screening/
38. screen$.ti,ab.
39. ((cholesterol or lipid$ or lipoprotein$ or LDL$ or HDL$) adj3 (detect$ or measur$ or check$ or assess$ or analyz$ or analys$ or test$ or panel$ or profile$)).ti,ab.
40. (fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
41. (non-fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
42. 37 or 38 or 39 or 40 or 41
43. (24 or 36) and 42
44. adolescent/ or child/ or young adult/
45. 43 and 44
46. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
47. 43 and 46
48. limit 47 to (“in data review” or in process or “pubmed not medline”)
49. 45 or 48
50. limit 49 to english language
51. limit 50 to yr=“2007 -Current”
52. remove duplicates from 51

#### Dx yield/accuracy

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process and Other Non-Indexed Citations <June 2, 2015>, Ovid MEDLINE(R) Daily Update <June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. or/1-23
25. Cholesterol/bl
26. Triglycerides/bl
27. Lipoproteins/bl
28. Cholesterol, HDL/
29. Cholesterol, LDL/
30. Apolipoprotein B-100/
31. Apolipoprotein B 100.ti,ab.
32. apob 100.ti,ab.
33. apo b 100.ti,ab.
34. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
35. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
36. ((cholesterol or lipid$ or lipoprotein$ or LDL$ or HDL$) adj3 (detect$ or measur$ or check$ or assess$ or analyz$ or analys$ or test$ or panel$ or profile$)).ti,ab.
37. (fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
38. (non-fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
39. or/25-38
40. “Sensitivity and Specificity”/
41. “Predictive Value of Tests”/
42. ROC Curve/
43. False Negative Reactions/
44. False Positive Reactions/
45. Diagnostic Errors/
46. “Reproducibility of Results”/
47. Reference Values/
48. Reference Standards/
49. Observer Variation/
50. Receiver operat$.ti,ab.
51. ROC curve$.ti,ab.
52. sensitivit$.ti,ab.
53. specificit$.ti,ab.
54. predictive value.ti,ab.
55. accuracy.ti,ab.
56. false positive$.ti,ab.
57. false negative$.ti,ab.
58. miss rate$.ti,ab.
59. error rate$.ti,ab.
60. 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59
61. (24 or 39) and 60
62. adolescent/ or child/ or young adult/
63. 61 and 62
64. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
65. 61 and 64
66. limit 65 to (“in data review” or in process or “pubmed not medline”)
67. 63 or 66
68. limit 67 to (english language and yr=“2007 -Current”)
69. remove duplicates from 68

#### Drug Tx Harms

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process and Other Non-Indexed Citations <June 2, 2015>, Ovid MEDLINE(R) Daily Update <June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
25. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
26. or/1-25
27. hypolipidemic agents/ or bezafibrate/ or butoxamine/ or clofenapate/ or clofibrate/ or clofibric acid/ or colestipol/ or fenofibrate/ or gemfibrozil/ or halofenate/ or meglutol/ or nafenopin/ or niacin/ or niceritrol/ or pyridinolcarbamate/ or simvastatin/ or triparanol/
28. anticholesteremic agents/ or azacosterol/ or chitosan/ or cholestyramine resin/ or clofibrate/ or clofibric acid/ or lovastatin/ or meglutol/ or pravastatin/ or probucol/ or simvastatin/ or “trans-1,4-bis(2-chlorobenzaminomethyl)cyclohexane dihydrochloride”/
29. hydroxymethylglutaryl-coa reductase inhibitors/ or lovastatin/
30. 3-hydroxy-3-methylglutaryl coenzyme A reductase inhibitor$.ti,ab.
31. hydroxymethylglutaryl coa reductase inhibitor$.ti,ab.
32. hydroxymethylglutaryl coa inhibitor$.ti,ab.
33. hydroxymethylglutaryl coenzyme a reductase.ti,ab.
34. hydroxymethylglutaryl coenzyme a inhibitor$.ti,ab.
35. hmg coa reductase inhibitor$.ti,ab.
36. hmg coa inhibitor$.ti,ab.
37. atorvastatin.ti,ab.
38. fluvastatin.ti,ab.
39. lovastatin.ti,ab.
40. pitavastatin.ti,ab.
41. pravastatin.ti,ab.
42. rosuvastatin.ti,ab.
43. simvastatin.ti,ab.
44. hypolipidemic$.ti,ab.
45. anticholesteremic$.ti,ab.
46. antilipidemic.ti,ab.
47. statin$.ti,ab.
48. lipid lower$.ti,ab.
49. (treat$ or therap$ or medicat$).ti.
50. or/27-49
51. ae.fs.
52. “Drug-Related Side Effects and Adverse Reactions”/
53. Mortality/
54. Morbidity/
55. Death/
56. mo.fs.
57. (harm or harms or harmful or harmed).ti,ab.
58. (adverse adj (effect$ or event$ or outcome$)).ti,ab.
59. safety.ti,ab.
60. overtreat$.ti,ab.
61. (death or deaths).ti,ab.
62. drug-induced liver injury/
63. drug-induced liver injury, chronic/
64. Liver Neoplasms/ci
65. Liver/de
66. Liver failure/ci
67. Liver failure, acute/ci
68. (liver adj3 (injur$ or dysfunction$ or failure$)).ti,ab.
69. (Hepatic adj3 (injur$ or dysfunction$ or failure$)).ti,ab.
70. (transaminase adj3 (elevat$ or abnormal$ or dysfunction$)).ti,ab.
71. Liver enzyme$.ti,ab.
72. alanine transaminase.ti,ab.
73. alanine aminotransferase.ti,ab.
74. aspartate transaminase.ti,ab.
75. aspartate aminotransferase.ti,ab.
76. (AST or ALT).ti,ab.
77. Muscular Diseases/ci
78. Myositis/
79. Myositis.ti,ab.
80. Dermatomyositis/
81. Dermatomyositis.ti,ab.
82. myositis ossificans.ti,ab.
83. Rhabdomyolysis/
84. rhabdomyolysis.ti,ab.
85. myotoxicity.ti,ab.
86. myopathy.ti,ab.
87. muscle enzyme$.ti,ab.
88. (creatine adj3 (high or elevat$ or abnormal$)).ti,ab.
89. Myalgia/
90. myalgia.ti,ab.
91. or/51-90
92. 26 and 50 and 91
93. adolescent/ or child/ or young adult/
94. 92 and 93
95. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
96. 92 and 95
97. limit 96 to (“in data review” or in process or “pubmed not medline”)
98. 94 or 97
99. limit 98 to english language
100. limit 99 to yr=“2007 -Current”

#### Drug and lifestyle treatment efficacy

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process and Other Non-Indexed Citations <June 2, 2015>, Ovid MEDLINE(R) Daily Update <June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
25. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
26. or/1-25
27. hypolipidemic agents/ or bezafibrate/ or butoxamine/ or clofenapate/ or clofibrate/ or clofibric acid/ or colestipol/ or fenofibrate/ or gemfibrozil/ or halofenate/ or meglutol/ or nafenopin/ or niacin/ or niceritrol/ or pyridinolcarbamate/ or simvastatin/ or triparanol/
28. anticholesteremic agents/ or azacosterol/ or chitosan/ or cholestyramine resin/ or clofibrate/ or clofibric acid/ or lovastatin/ or meglutol/ or pravastatin/ or probucol/ or simvastatin/ or “trans-1,4-bis(2-chlorobenzaminomethyl)cyclohexane dihydrochloride”/
29. hydroxymethylglutaryl-coa reductase inhibitors/ or lovastatin/
30. 3-hydroxy-3-methylglutaryl coenzyme A reductase inhibitor$.ti,ab.
31. hydroxymethylglutaryl coa reductase inhibitor$.ti,ab.
32. hydroxymethylglutaryl coa inhibitor$.ti,ab.
33. hydroxymethylglutaryl coenzyme a reductase.ti,ab.
34. hydroxymethylglutaryl coenzyme a inhibitor$.ti,ab.
35. hmg coa reductase inhibitor$.ti,ab.
36. hmg coa inhibitor$.ti,ab.
37. atorvastatin.ti,ab.
38. fluvastatin.ti,ab.
39. lovastatin.ti,ab.
40. pitavastatin.ti,ab.
41. pravastatin.ti,ab.
42. rosuvastatin.ti,ab.
43. simvastatin.ti,ab.
44. hypolipidemic$.ti,ab.
45. anticholesteremic$.ti,ab.
46. antilipidemic.ti,ab.
47. statin$.ti,ab.
48. lipid lower$.ti,ab.
49. (treat$ or therap$ or medicat$).ti.
50. or/27-49
51. diet/
52. diet, carbohydrate-restricted/
53. diet, fat-restricted/
54. diet, mediterranean/
55. diet, protein-restricted/
56. diet, reducing/
57. diet, vegetarian/
58. caloric restriction/
59. portion size/
60. Food habits/
61. Diet Therapy/
62. Soybean Proteins/
63. Fatty Acids, Omega-3/
64. Phytosterols/
65. Dietary Fiber/
66. Dietary Protein/
67. Dietary Carbohydrates/
68. Dietary Fats/
69. diet$.ti,ab.
70. ((reduce$ or reduction$ or manipulat$ or restrict$) adj3 (fat$ or carbohydrate$ or cholesterol)).ti,ab.
71. low fat.ti,ab.
72. lowfat.ti,ab.
73. fiber.ti,ab.
74. omega 3 fatty acid$.ti,ab.
75. n 3 polyunsaturated fatty acid$.ti,ab.
76. n 3 fatty acid$.ti,ab.
77. n 3 pufa.ti,ab.
78. soy$ protein$.ti,ab.
79. plant stanol$.ti,ab.
80. esters.ti,ab.
81. 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80
82. Exercise/
83. Exercise therapy/
84. Motor activity/
85. Physical fitness/
86. Plyometric Exercise/
87. Physical Conditioning, Human/
88. Running/
89. Jogging/
90. Swimming/
91. Walking/
92. Resistance training/
93. (exercise or exercising or exercises).ti,ab.
94. physical fitness.ti,ab.
95. physical conditioning.ti,ab.
96. (running or jog$ or swim$ or walk$).ti,ab.
97. (lifestyle$ or life style$).ti,ab.
98. 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97
99. 26 and (50 or 81 or 98)
100. Hyperlipidemias/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention and Control, Therapy]
101. Dyslipidemias/dh, dt, pc, th
102. Hypercholesterolemia/dh, dt, pc, th
103. Lipid Metabolism Disorders/dh, dt, pc, th
104. Hyperlipoproteinemias/dh, dt, pc, th
105. Hypertriglyceridemia/dh, dt, pc, th
106. Hyperlipoproteinemia Type II/dh, dt, pc, th
107. Hyperlipidemia, Familial Combined/dh, dt, pc, th
108. Hypobetalipoproteinemias/dh, dt, pc, th
109. Abetalipoproteinemia/dh, dt, pc, th
110. 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109
111. adolescent/ or child/ or young adult/
112. 110 and 111
113. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
114. 110 and 113
115. limit 114 to (“in data review” or in process or “pubmed not medline”)
116. 112 or 115
117. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
118. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
119. Random$.ti,ab.
120. control groups/ or double-blind method/ or single-blind method/
121. clinical trial$.ti,ab.
122. controlled trial$.ti,ab.
123. meta analy$.ti,ab.
124. 117 or 118 or 119 or 120 or 121 or 122 or 123
125. 116 and 124
126. limit 125 to (english language and yr=“2007 -Current”)
127. remove duplicates from 126

### PubMed search strategy [publisher-supplied references only]

Search | Query
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #10 AND publisher[sb] Filters: Publication date from 2007/01/01 to 2015/06/02; English
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #8 AND #9
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search child*[tiab] OR teen[tiab] OR teens[tiab] OR teenage*[tiab] OR adolescen*[tiab] OR youth[tiab] OR youths[tiab] OR “young people”[tiab] OR pediatric*[tiab] OR paediatric*[tiab]
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 or #2 or #3 or #4 or #5 or #6 or #7
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (fasting[tiab] or non fasting[tiab] OR nonfasting[tiab]) AND (lipid*[tiab] OR lipoprotein*[tiab] OR cholesterol[tiab])
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (lipid[tiab] OR lipids[tiab] OR lipoprotein*[tiab] OR cholesterol[tiab] OR LDL*[tiab] OR HDL*[tiab]) AND (detect*[tiab] OR measur*[tiab] OR check*[tiab] OR assess*[tiab] OR analyz*[tiab] OR analys*[tiab] OR test*[tiab] OR panel*[tiab] OR profile*[tiab])
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (lipid[tiab] OR lipids[tiab] OR lipoprotein*[tiab] OR cholesterol[tiab] OR LDL*[tiab] OR HDL*[tiab]) AND (low[tiab] OR high[tiab] OR elevated[tiab] OR abnormal[tiab] OR aberr*[tiab])
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search lipid disorder*[tiab] OR lipid dysfunction*[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search familial[tiab] AND apolipoprotein[tiab]
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search familial hypercholesterolemia*[tiab] OR familial hypercholesterolaemia*[tiab] OR familial hyperlipidemi*[tiab] OR familial hyperlipidaemi*[tiab] OR essential hypercholesterolemi*[tiab] OR essential hypercholesterolaemi*[tiab] OR heterozygous fh[tiab] OR homozygous fh[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (hyperlipidemia*[tiab] OR hyperlipidaemia*[tiab] OR dyslipidemia*[tiab] OR dyslipidaemia*[tiab] OR hypercholesterolemia*[tiab] OR hypercholesterolaemia*[tiab] OR hyperlipoproteinemia*[tiab] OR hyperlipoproteinaemia*[tiab] OR hypertriglyceridemia*[tiab] OR hypertriglyceridaemia*[tiab] OR dysbetalipoproteinemia*[tiab] OR dysbetalipoproteinaemia*[tiab])

Appendix A Figure 1 Literature Flow Diagram

^1^ Number of articles that were not included in prior review: KQ1=0; KQ2=0; KQ3=2; KQ6=4; KQ7=12; KQ8=0

Abbreviation: KQ=key question.

Appendix Figure 1 is a flow chart that summarizes the search and selection of articles. There were 9,305 citations identified through literature databases. An additional 344 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 6,753 unique citations were screened at the title/abstract stage. The full text of 375 citations were examined for inclusion for one or more of the eight Key Questions, or for contextual questions.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Population | KQs 1–4: Asymptomatic children and adolescents ages 0 to 20 years at time of screening KQs 5–7: Children and adolescents ages 0 to 20 years at time of treatment initiation with a diagnosis of FH KQ 8: Children and adolescents ages 0 to 20 years at beginning of study period with a diagnosis of FH | KQs 1–4: Children and adolescents with any of the following:; - Known dyslipidemia; - Diagnosis associated with secondary dyslipidemia*; - Established family history of FH; KQs 5–7: Children and adolescents with dyslipidemia not due to FH
Diseases | KQs 5–7: FH | KQs 5–7:; - Monogenic dyslipidemia other than FH; - Secondary dyslipidemia*; - Multifactorial dyslipidemia
Screening interventions | KQs 1–4:; - Lipid panel (fasting or nonfasting lipid measurement, total or LDL cholesterol alone or in combination with HDL cholesterol); - Comparison with no screening or usual care; - Universal or selective screening strategy | KQs 1–4:; - Genetic screening alone; - Cascade screening
Treatments | KQs 5–7:; - Lipid-lowering medications; - Lifestyle modifications, including diet or exercise | KQs 5–7:; - Apheresis; - Revascularization
Outcomes | KQs 1, 5, 8:; - MI; - Ischemic stroke; KQs 2, 6:; - Lipid concentrations (total and LDL cholesterol); - Atherosclerosis markers (carotid intima–media thickness, calcium score, pathological findings); KQ 3:; - Diagnostic yield (true positives/number screened); - Positive predictive value (true positives/true positives + false positives); KQ 4: All harms (e.g., false-positive or false-negative results, psychosocial effects, overdiagnosis) KQ 7: All harms from lipid-lowering medications (e.g., AEs, long-term safety, overtreatment) | KQs 1, 5, 8:; - Diabetes; - Metabolic syndrome; - Hypothyroidism; - Renal failure; - Obstructive liver disease; - Nephrotic syndrome; - Lipodystrophy
Study design | KQs 1–3: RCTs, CCTs, cohort studies, systematic reviews KQs 4, 7: RCTs, CCTs, cohort studies, systematic reviews, observational studies, systematically selected case series KQs 5, 6: RCTs, systematic reviews KQ 8: RCTs, CCTs, cohort studies, systematic reviews, registry studies, long-term trial followup, high-quality case-control studies | All KQs: Studies rated as poor quality KQs 1–3, 5, 6, 8: Qualitative studies, case reports, cost-effectiveness studies KQs 4, 7: None KQs 5, 6: Cohort studies, plus all study designs excluded for KQ 1 KQ 8: All study designs excluded for KQ 1
Settings | - Publication date of 2007 to present; - Conducted in countries with a Human Development Index score of ≥0.9, as defined by the United Nations | Settings not generalizable to primary care

Abbreviations: KQ=key question, LDL=low-density lipoprotein, HDL=high-density lipoprotein, MI=myocardial infarction, AE=adverse effects, RCT=randomized, controlled trial, CCT=controlled clinical trial; FH=familial hypercholesterolemia.

Additional definitions: Secondary dyslipidemias: Renal (chronic renal disease, hemolytic uremic syndrome, nephrotic syndrome); Infectious (acute viral or bacterial infections, HIV, hepatitis); hepatic (obstructive liver disease, cholestasis, biliary cirrhosis, Alagille syndrome); inflammatory (systemic lupus erythematosus, juvenile rheumatoid arthritis); storage (glycogen storage disease, Gaucher's disease, cystine storage disease, Tay-Sachs, Niemann-Pick); other (Kawasaki disease, anorexia nervosa, cancer, previous solid organ transplantation, progeria, idiopathic hypercalcemia, Klinefelter, Werner's syndrome.

Appendix A Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized, controlled trials (adapted from the USPSTF methods)^*^ | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?

* Source: U.S. Preventive Services Task Force Procedure Manual.