# References

1 Cook S, Auinger P, Huang TT. Growth curves for cardio-metabolic risk factors in children and adolescents. J Pediatr. 2009;155(3):S6 e15-26. [pmid: 19732566].
2 National Cholesterol Education Program (NCEP): highlights of the report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents. Pediatrics. 1992;89(3):495-501. [pmid: 1741227].
3 Daniels SR. Screening for familial hypercholesterolemia: what is the most effective strategy?. Nat Clin Pract Cardiovasc Med. 2008;5(3):130-1. [pmid: 18059381].
4 Tamir I, Heiss G, Glueck CJ, et al. Lipid and lipoprotein distributions in white children ages 6-19 yr. The Lipid Research Clinics Program Prevalence Study. J Chronic Dis. 1981;34(1):27-39. [pmid: 7451637].
5 Martinez-Gomez D, Eisenmann JC, Gomez-Martinez S, et al. Sedentary behavior, adiposity and cardiovascular risk factors in adolescents. The AFINOS study. Rev Esp Cardiol. 2010;63(3):277-85. [pmid: 20196988].
6 Raman A, Sharma S, Fitch MD, et al. Anthropometric correlates of lipoprotein profile and blood pressure in high BMI African American children. Acta Paediatr. 2010;99(6):912-9. [pmid: 20064141].
7 Ice CL, Murphy E, Cottrell L, et al. Morbidly obese diagnosis as an indicator of cardiovascular disease risk in children: results from the CARDIAC Project. Int J Pediatr Obes. 2011;6(2):113-9. [pmid: 20545480].
8 Kit BK, Kuklina E, Carroll MD, et al. Prevalence of and trends in dyslipidemia and blood pressure among U.S. children and adolescents, 1999-2012. JAMA Pediatr. 2015;169(3):272-9. [pmid: 25599372].
9 Ogden CL, Carroll MD, Kit BK, et al. Prevalence of childhood and adult obesity in the United States, 2011-2012. JAMA. 2014;311(8):806-14. [pmid: 24570244].
10 Gidding SS, Barton BA, Dorgan JA, et al. Higher self-reported physical activity is associated with lower systolic blood pressure: the Dietary Intervention Study in Childhood (DISC). Pediatrics. 2006;118(6):2388-93. [pmid: 17142523].
11 Wong ND, Hei TK, Qaqundah PY, et al. Television viewing and pediatric hypercholesterolemia. Pediatrics. 1992;90(1 Pt 1):75-9. [pmid: 1614784].
12 Austin MA, Hutter CM, Zimmern RL, et al. Genetic causes of monogenic heterozygous familial hypercholesterolemia: a HuGE prevalence review. Am J Epidemiol. 2004;160(5):407-20. [pmid: 15321837].
13 Rodriguez CJ, Daviglus ML, Swett K, et al. Dyslipidemia patterns among Hispanics/Latinos of diverse background in the United States. Am J Med. 2014;127(12):1186-94 e1. [pmid: 25195188].
14 Frank AT, Zhao B, Jose PO, et al. Racial/ethnic differences in dyslipidemia patterns. Circulation. 2014;129(5):570-9. [pmid: 24192801].
15 Kit BK, Carroll MD, Lacher DA, et al. Trends in serum lipids among U.S. youths aged 6 to 19 years, 1988-2010. JAMA. 2012;308(6):591-600. [pmid: 22871871].
16 Gillman MW, Cupples LA, Moore LL, et al. Impact of within-person variability on identifying children with hypercholesterolemia: Framingham Children's Study. J Pediatr. 1992;121(3):342-7. [pmid: 1517906].
17 National Institutes of Health. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143-421. [pmid: 12485966].
18 Centers for Disease Control and Prevention. Prevalence of coronary heart disease--United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2011;60(40):1377-81. [pmid: 21993341].
19 Hoyert DL. 75 years of mortality in the United States, 1935-2010. NCHS Data Brief. 2012;(88):1-8. [pmid: 22617094].
20 Minino AM. Death in the United States, 2011. NCHS Data Brief. 2013;(115):1-8. [pmid: 23742756].
21 Helfand M, Carson S. Screening for Lipid Disorders in Adults: Selective Update of 2001 U.S. Preventive Services Task Force Review. Evidence Synthesis No. 49. AHRQ Publication no. 08-05114-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. April. 2008. [pmid: 20722146].
22 Newman WP 3rd, Freedman DS, Voors AW, et al. Relation of serum lipoprotein levels and systolic blood pressure to early atherosclerosis. The Bogalusa Heart Study. N Engl J Med. 1986;314(3):138-44. [pmid: 3455748].
23 Berenson GS, Srinivasan SR, Bao W, et al. Association between multiple cardiovascular risk factors and atherosclerosis in children and young adults. The Bogalusa Heart Study. N Engl J Med. 1998;338(23):1650-6. [pmid: 9614255].
24 Davis PH, Dawson JD, Riley WA, et al. Carotid intimal-medial thickness is related to cardiovascular risk factors measured from childhood through middle age: The Muscatine Study. Circulation. 2001;104(23):2815-9. [pmid: 11733400].
25 Frontini MG, Srinivasan SR, Xu J, et al. Usefulness of childhood non-high density lipoprotein cholesterol levels versus other lipoprotein measures in predicting adult subclinical atherosclerosis: the Bogalusa Heart Study. Pediatrics. 2008;121(5):924-9. [pmid: 18450895].
26 Raitakari OT, Ronnemaa T, Jarvisalo MJ, et al. Endothelial function in healthy 11-year-old children after dietary intervention with onset in infancy: the Special Turku Coronary Risk Factor Intervention Project for children (STRIP). Circulation. 2005;112(24):3786-94. [pmid: 16330680].
27 Raitakari OT, Juonala M, Kahonen M, et al. Cardiovascular risk factors in childhood and carotid artery intima-media thickness in adulthood: the Cardiovascular Risk in Young Finns Study. JAMA. 2003;290(17):2277-83. [pmid: 14600186].
28 Juonala M, Viikari JS, Kahonen M, et al. Childhood levels of serum apolipoproteins B and A-I predict carotid intima-media thickness and brachial endothelial function in adulthood: the cardiovascular risk in young Finns study. J Am Coll Cardiol. 2008;52(4):293-9. [pmid: 18634985].
29 McGill HC, McMahan CA, Malcom GT, et al. Effects of Serum Lipoproteins and Smoking on Atherosclerosis in Young Men and Women. Arterioscler Thromb Vasc Biol. 1997;17(1):95-106. [pmid: 9012643].
30 McGill HC Jr., McMahan CA, Zieske AW, et al. Associations of coronary heart disease risk factors with the intermediate lesion of atherosclerosis in youth. The Pathobiological Determinants of Atherosclerosis in Youth (PDAY) Research Group. Arterioscler Thromb Vasc Biol. 2000;20(8):1998-2004. [pmid: 10938023].
31 Mittelman SD, Gilsanz P, Mo AO, et al. Adiposity predicts carotid intima-media thickness in healthy children and adolescents. J Pediatr. 2010;156(4):592-7 e2. [pmid: 20004913].
32 Raynor LA, Schreiner PJ, Loria CM, et al. Associations of retrospective and concurrent lipid levels with subclinical atherosclerosis prediction after 20 years of follow-up: the Coronary Artery Risk Development in Young Adults (CARDIA) study. Ann Epidemiol. 2013;23(8):492-7. [pmid: 23889858].
33 Pletcher MJ, Bibbins-Domingo K, Liu K, et al. Nonoptimal lipids commonly present in young adults and coronary calcium later in life: the CARDIA (Coronary Artery Risk Development in Young Adults) study. Ann Intern Med. 2010;153(3):137-46. [pmid: 20679558].
34 Haney EM, Huffman LH, Bougatsos C, et al. Screening and treatment for lipid disorders in children and adolescents: systematic evidence review for the U.S. Preventive Services Task Force. Pediatrics. 2007;120(1):e189-e214. [pmid: 17606543].
35 Juhola J, Magnussen CG, Viikari JS, et al. Tracking of serum lipid levels, blood pressure, and body mass index from childhood to adulthood: the Cardiovascular Risk in Young Finns Study. J Pediatr. 2011;159(4):584-90. [pmid: 21514597].
36 Clarke WR, Schrott HG, Leaverton PE, et al. Tracking of blood lipids and blood pressures in school age children: the Muscatine study. Circulation. 1978;58(4):626-34. [pmid: 688572].
37 Magnussen CG, Raitakari OT, Thomson R, et al. Utility of currently recommended pediatric dyslipidemia classifications in predicting dyslipidemia in adulthood: evidence from the Childhood Determinants of Adult Health (CDAH) study, Cardiovascular Risk in Young Finns Study, and Bogalusa Heart Study. Circulation. 2008;117(1):32-42. [pmid: 18071074].
38 National Cholesterol Education Program: highlights of the report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents. Pediatrics. 1992;89(3):495-501. [pmid: 1741227].
39 Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents: Summary Report. Pediatrics. Suppl 5. 2011;128:S213-56. [pmid: 22084329].
40 Harris N, Neufeld EJ, Newburger JW, et al. Analytical performance and clinical utility of a direct LDL-cholesterol assay in a hyperlipidemic pediatric population. Clin Chem. 1996;42(8 Pt 1):1182-8. [pmid: 8697574].
41 Skinner AC, Steiner MJ, Chung AE, et al. Cholesterol curves to identify population norms by age and sex in healthy weight children. Clin Pediatr (Phila). 2012;51(3):233-7. [pmid: 22157422].
42 Kwiterovich PO. Clinical and laboratory assessment of cardiovascular risk in children: Guidelines for screening, evaluation, and treatment. J Clin Lipidol. 2008;2(4):248-66. [pmid: 21291741].
43 U.S. Preventive Services Task Force. Screening for lipid disorders in children: U.S. Preventive Services Task Force recommendation statement. Pediatrics. 2007;120(1):e215-e9. [pmid: 17606545].
44 Daniels SR, Greer FR, Committee on Nutrition. Lipid screening and cardiovascular health in childhood. Pediatrics. 2008;122(1):198-208. [pmid: 18596007].
45 Vinci SR, Rifas-Shiman SL, Cheng JK, et al. Cholesterol testing among children and adolescents during health visits. JAMA. 2014;311(17):1804-7. [pmid: 24794376].
46 Joyce N, Wellenius GA, Dore DD, et al. Patterns of Lipid Lowering Therapy among Children Ages 8-20 Years. J Pediatr. 2015;167(1):113-9 e1. [pmid: 25953004].
47 Daniels SR, Gidding SS, de Ferranti SD, et al. Pediatric aspects of familial hypercholesterolemias: recommendations from the National Lipid Association Expert Panel on Familial Hypercholesterolemia. J Clin Lipidol. 2011;5(3 Suppl):S30-7. [pmid: 21600527].
48 United Nations Development Programme. Human Development Index: 2013 Rankings. United Nations Development Programme. 2014. http://hdr.undp.org/en/2013-report.
49 Garcia RE, Moodie DS. Routine cholesterol surveillance in childhood. Pediatrics. 1989;84(5):751-5. [pmid: 2640549].
50 Griffin TC, Christoffel KK, Binns HJ, et al. Family history evaluation as a predictive screen for childhood hypercholesterolemia. Pediatric Practice Research Group. Pediatrics. 1989;84(2):365-73. [pmid: 2748269].
51 Douglas MB, Birrer RB, Medidi S, et al. Obese children should be screened for hypercholesterolemia. J Health Care Poor Underserved. 1996;7(1):24-35. [pmid: 8645782].
52 Manchester RA, McDuffie C, Diamond E. Screening for hypercholesterolemia in college students. J Am Coll Health. 1989;37(4):149-53. [pmid: 2926025].
53 Gagliano NJ, Emans SJ, Woods ER. Cholesterol screening in the adolescent. J Adolesc Health. 1993;14(2):104-8. [pmid: 8476872].
54 Faigel HC. Screening college students for hypercholesterolemia. J Am Coll Health. 1992;40(6):272-5. [pmid: 1602094].
55 Ford ES, Li C, Zhao G, et al. Concentrations of low-density lipoprotein cholesterol and total cholesterol among children and adolescents in the United States. Circulation. 2009;119(8):1108-15. [pmid: 19221218].
56 Centers for Disease Control and Prevention. Prevalence of abnormal lipid levels among youths --- United States, 1999-2006. MMWR Morb Mortal Wkly Rep. 2010;59(2):29-33. [pmid: 20094024].
57 Ritchie SK, Murphy EC, Ice C, et al. Universal versus targeted blood cholesterol screening among youth: The CARDIAC project. Pediatrics. 2010;126(2):260-5. [pmid: 20624798].
58 Margolis KL, Greenspan LC, Trower NK, et al. Lipid screening in children and adolescents in community practice: 2007 to 2010. Circ Cardiovasc Qual Outcomes. 2014;7(5):718-26. [pmid: 25160839].
59 National Center for Health Statistics. Analytic and Reporting Guidelines: the Third National Health and Nutrition Examination Survey (NHANES III) 1988-1994. Hyattsville, MD. National Center for Health Statistics; Centers for Disease Control and Prevention. 1996.
60 Wong H, Chahal N, Manlhiot C, et al. Flaxseed in pediatric hyperlipidemia: a placebo-controlled, blinded, randomized clinical trial of dietary flaxseed supplementation for children and adolescents with hypercholesterolemia. JAMA Pediatr. 2013;167(8):708-13. [pmid: 23733031].
61 Dietary intervention study in children (DISC) with elevated low-density-lipoprotein cholesterol. Design and baseline characteristics. DISC Collaborative Research Group. Ann Epidemiol. 1993;3(4):393-402. [pmid: 8275216].
62 Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol. The Dietary Intervention Study in Children (DISC). The Writing Group for the DISC Collaborative Research Group. JAMA. 1995;273(18):1429-35. [pmid: 7723156].
63 Obarzanek E, Kimm SY, Barton BA, et al. Long-term safety and efficacy of a cholesterol-lowering diet in children with elevated low-density lipoprotein cholesterol: seven-year results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107(2):256-64. [pmid: 11158455].
64 Dorgan JF, Liu L, Barton BA, et al. Adolescent diet and metabolic syndrome in young women: Results of the Dietary Intervention Study in Children (DISC) follow-up study. J Clin Endocrinol Metab. 2011;96(12):E1999-2008. [pmid: 21994964].
65 Heiss G, Tamir I, Davis CE, et al. Lipoprotein-cholesterol distributions in selected North American populations: the lipid research clinics program prevalence study. Circulation. 1980;61(2):302-15. [pmid: 7351055].
66 Lozano P, Henrikson N, Dunn J, et al. Lipid screening in childhood for detection of familial hypercholesterolemia. Rockville, MD. Agency for Healthcare Research and Quality; U.S. Department of Health and Human Services. in process.
67 Obarzanek E, Hunsberger SA, Van Horn L, et al. Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 1997;100(1):51-9. [pmid: 9200359].
68 Lavigne JV, Brown KM, Gidding S, et al. A cholesterol-lowering diet does not produce adverse psychological effects in children: three-year results from the dietary intervention study in children. Health Psychol. 1999;18(6):604-13. [pmid: 10619534].
69 Guardamagna O, Amaretti A, Puddu PE, et al. Bifidobacteria supplementation: effects on plasma lipid profiles in dyslipidemic children. Nutrition. 2014;30(7-8):831-6. [pmid: 24985000].
70 Saydah S, Bullard KM, Imperatore G, et al. Cardiometabolic risk factors among U.S. adolescents and young adults and risk of early mortality. Pediatrics. 2013;131(3):e679-e86. [pmid: 23420920].
71 Psaty BM, Rivara FP. Universal screening and drug treatment of dyslipidemia in children and adolescents. JAMA. 2012;307(3):257-8. [pmid: 22174386].
72 Van Horn L, Obarzanek E, Friedman LA, et al. Children's adaptations to a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 2005;115(6):1723-33. [pmid: 15930237].
73 Niinikoski H, Lagstrom H, Jokinen E, et al. Impact of repeated dietary counseling between infancy and 14 years of age on dietary intakes and serum lipids and lipoproteins: the STRIP study. Circulation. 2007;116(9):1032-40. [pmid: 17698729].
74 Yeste D, Chacon P, Clemente M, et al. Ezetimibe as monotherapy in the treatment of hypercholesterolemia in children and adolescents. J Pediatr Endocrinol Metab. 2009;22(6):487-92. [pmid: 19694195].
75 Expert Panel on Integrated Guidelines for Cardiovascular H, Risk Reduction in C, Adolescents, et al. Expert panel on integrated guidelines for cardiovascular health and risk reduction in children and adolescents: summary report. Pediatrics. Suppl 5. 2011;128:S213-56. [pmid: 22084329].
76 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
77 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Ottawa. Ottawa Hospital Research Institute. 2014. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
78 Université de Montréal. Intima Media Thickness Regression in Dyslipidemic Teenagers. ClinicalTrials.gov [Internet]. Bethesda, MD. National Library of Medicine (U.S.). 2000. [cited 2015 June 3]. https://clinicaltrials.gov/ct2/show/NCT01768481. NLM Identifier: NCT01768481.