# Discussion

Findings from the systematic review of lipid screening for detecting multifactorial dyslipidemia are discussed here. The reader is reminded that screening for detecting FH is the focus of the companion report.

## Screening

### Summary of Evidence

We found no direct evidence for the effect of screening for multifactorial dyslipidemia on intermediate or health outcomes or on the harms of screening. No RCTs tested screening programs for multifactorial dyslipidemia, either selective or universal.

There is fair evidence that TC screening with a cut point of 200 mg/dL has a PPV of 77 percent for multifactorial dyslipidemia. Recent nationally representative prevalence estimates suggest a simulated diagnostic yield of 5.4 percent for 8- to 12-year-olds and 6.5 percent for 13- to 17-year-olds. Simulated diagnostic yield ranges between 4 and 12 percent for different age and BMI subgroups. Based on large, recent U.S. studies, the highest diagnostic yield appears to be in obese children (12.3%), children ages 9 to 11 years (7.2%), and adolescents ages 16 to 19 years (7.2%). The CARDIAC study was conducted in the same age group that the NHLBI expert panel recommends for universal testing, so the diagnostic yields of 5.8 percent, 8.9 percent, and 12.3 percent for healthy weight, overweight, and obese 10- to 11-year-olds, respectively, provide reasonable estimates of what might be seen for those subgroups if screening among 9- to 11-year-olds was more widely adopted.

The prevalence of elevated TC and LDL-C concentrations (on which diagnostic yields were calculated) were consistent across three large, recent U.S. studies. The NHANES studies show a gradual decrease in the prevalence of elevated concentrations of TC and LDL-C in recent years. However, prevalence estimated from a single lipid test overestimates the true prevalence of dyslipidemia because two tests are needed to appropriately classify children according to the NCEP ranges of acceptable, borderline, or high cholesterol concentrations.16

### Limitations of the Body of Evidence

The fact that only one of the included studies performed confirmatory testing of hypercholesterolemia required that we simulate diagnostic yield. The screening evidence draws heavily from epidemiologic studies rather than screening trials. The prevalence of cholesterol elevations across broad age ranges, as is often reported, is less meaningful than age group–specific rates, given the variation of TC concentrations by age.

Only one school-based study7 was relevant to the primary care setting. The use of the fixed NCEP thresholds for TC and LDL-C concentrations make the prevalence of dyslipidemia (and diagnostic yield) difficult to determine because these thresholds ignore age and sex variability. There were no studies using non–HDL-C as a screening test. Finally, incomplete tracking of lipid concentrations from childhood through adolescence and into adulthood34 is a current limitation of the evidence. Multifactorial dyslipidemia detected in persons younger than age 20 years is likely to resolve in young adulthood;37 thus, dyslipidemia identified in childhood or adolescence has unclear significance for adult health.

### Evidence Gaps

There are several gaps in the evidence regarding potential benefit and harms of screening for multifactorial dyslipidemia. We found no data on potential benefits of screening such as reducing atherosclerosis. There is a need for screening trials for detection of multifactorial dyslipidemia in childhood and adolescence using both primary and confirmatory testing. Many studies were excluded because they used cut points below accepted cut points (e.g., an LDL-C concentration of 175 or 180 mg/dL rather than 200 mg/dL). Even the accepted fixed 1992 NCEP cut points for elevated LDL-C and TC concentrations may be inadequate because they may over- or underidentify children and adolescents with high TC concentrations, depending on age and sex. We found no trials that compared screening (universal or selective approaches) to no screening. There was also a lack of data on prevalence and diagnostic yield in racially/ethnically diverse populations of children.

We found no studies of the harms of screening children and adolescents for multifactorial dyslipidemia. The 2007 USPSTF review reported that harms of screening for childhood dyslipidemia in general were poorly reported, but none of the studies in that review met our criteria. In fact, screening for dyslipidemia in children and adolescents has several potential harms. The fixed NCEP cut points likely overidentify children in the age groups currently targeted for screening (ages 9 to 11 years). Even if the 95th percentiles of age- and sex-adjusted norms for specific populations are used as thresholds, up to 5 percent of the population will be identified as having some degree of biochemical abnormality. However, dyslipidemia is a risk factor, not a disease. The association between elevated TC or LDL-C concentrations in youth and current or future disease is unknown. At least some identified individuals may never progress to develop clinically important lipid concentrations or cardiovascular disease. Such “nondisease” could result in subtle harms, such as labeling a child as “sick” or causing parent or child anxiety. In some cases, screening may lead to unnecessary or even harmful additional testing and treatment.71 The 2011 NHLBI consensus panel recommends that statin therapy be considered in children age 10 years and older with various combinations of LDL-C concentrations exceeding specific cut points, family history, and risk factors.39 However, statins have unknown benefits and harms in children and adolescents with multifactorial dyslipidemia. In one NHANES study, as many as 0.8 percent of adolescents met the NHLBI indications for statin therapy.55 Depending on the proportion of children and adolescents with FH among those with elevated LDL-C concentrations, screening could result in some children and adolescents being started inappropriately on lipid-lowering medications.

## Treatment

### Summary of Evidence

No direct evidence was found for an effect of treatment on health outcomes.

This review identified only one RCT of a dietary intervention (the DISC Study), so the body of evidence is fair at best. This RCT provided good-quality evidence of a modest effect of dietary counseling for a low-fat, low-cholesterol diet on lowering lipid concentrations in children with mild-to-moderate dyslipidemia. After 1 year of relatively intensive intervention, mean differences between groups compared to baseline were a decrease of 6 mg/dL in mean TC and a decrease of 5 mg/dL in mean LDL-C; both differences were statistically significant. Both between-group differences shrank to about 3 mg/dL at year 3 and by year 5 were no longer statistically significant. Adherence to the diet during the intervention period was good,62 and there is evidence that the children in the intervention group had improved dietary quality.72

Dietary changes made by children in the treatment group in the DISC study did not adversely affect their nutritional status, growth, or development. This finding is consistent with data from the Special Turku Coronary Risk Factor Intervention Project, which found that a preventive dietary intervention (consisting of counseling for a low-saturated fat, low-cholesterol diet) begun in infancy had no adverse effect on growth or maturation through age 14 years.73

A small, 4-week RCT of flaxseed found no effect on TC concentrations. There was no evidence to support any other type of treatment for multifactorial dyslipidemia, including nutritional supplements or medications.

The 2007 USPSTF review included the DISC trial but not the more recent flaxseed RCT.

### Limitations of the Body of Evidence

The DISC trial enrolled children with milder hyperlipidemia, making it difficult to generalize results to children with TC concentrations greater than 200 mg/dL or LDL-C greater than 130 mg/dL. This trial also targeted 8- to 10-year-olds, so the impact of a dietary intervention on adolescents is unknown. The intensity of the counseling intervention limits the generalizability of this treatment to primary care settings, where trained nutritional counselors may not be part of the health care team. Finally, the clinical importance of the small impact on cholesterol concentrations in the 1- to 3-year time frame is unclear. The flaxseed RCT included children with a family history of dyslipidemia and although they were not identified as having FH, it is possible that some of the participants could have met FH criteria.

### Evidence Gaps

We found only one high-quality RCT of dietary intervention for multifactorial dyslipidemia in children. There is a need for other large RCTs with long-term followup. Rigorous trials of dietary supplements and medications to reduce concentrations of atherogenic lipids in children and adolescents are also lacking. Several trials that did not meet our inclusion criteria examined supplements, such as psyllium/soluble fiber, niacin, polyunsaturated fatty acid, Bifidobacterium, glucomannan, red yeast extract, and plant stanols. Our search revealed few studies of medications for children or adolescents with multifactorial dyslipidemia. We excluded a trial of ezetimibe (an inhibitor of intestinal cholesterol absorption) for lack of a control group74 and found no trials of statins in this population. It should be noted that the current guidelines do not recommend the use of lipid-lowering medications to treat multifactorial dyslipidemia in children and adolescents. The treatment studies reviewed for inclusion also relied on various TC and LDL-C cut points, often below the standard NCEP thresholds. Few studies followed participants for a year or longer.

## Outcomes

### Summary of Evidence

A single high-quality, longitudinal study that included adolescents and young adults from the NHANES found no association between TC concentrations and death before age 55 years when both sexes were combined. The study did find that very high TC concentrations (≥240 mg/dL) were significantly associated with premature death in women only, although the authors caution that this estimate was based on a small number of deaths. The subgroup of females with TC concentrations greater than 240 mg/dL may well be dominated by individuals who have FH, for whom premature CHD deaths are expected. The importance of this finding is unclear, given the small number of deaths in this subgroup. (This study was published after the 2007 USPSTF review).

### Limitations of the Body of Evidence

In this single included study (NHANES), outcomes for adolescents were not reported separately from those for young adults. Because the 12- to 20-year-olds only reached ages 30 to 38 years (in the 1988 NHANES survey) or 24 to 32 years (in the 1994 NHANES survey), the findings were weighted toward mortality outcomes for the 21- to 39-year-olds. This issue might have been more of a limitation if there had been positive findings. In that case, an association for the overall cohort might have been driven by the 20- to 39-year-olds. However, given the largely negative findings, this is only a minor limitation. Another limitation is that this study reported all-cause and endogenous-cause mortality but not cardiovascular mortality, an outcome more closely linked to the causal pathway.

### Evidence Gaps

Long-term followup studies of pediatric cohorts are needed to better understand the association between cholesterol concentrations in children and adolescents with multifactorial dyslipidemia and adult health outcomes.

## Conclusions

We found no direct evidence of effect of TC screening on intermediate or health outcomes. Only one study provided a diagnostic yield for TC screening (5.8%). Simulated diagnostic yields in data from large, U.S. population-based studies show variation in TC by age and BMI. There were no studies of the diagnostic yield of selective screening and no studies on the harms of screening.

No evidence was found supporting an effect of treatment on health outcomes in adulthood (MI and stroke events). Dietary counseling may lower TC and LDL-C concentrations by 5 to 7 mg/dL over 3 years, but this intervention was relatively intensive and the effect on lipids dissipated over 5 years. No studies of lipid-lowering medications met the inclusion criteria. There is fair evidence of the safety of dietary interventions.

In one longitudinal study using NHANES data, neither very high nor moderately increased TC concentrations in 12- to 39-year-olds was independently associated with death before age 55 years (when males and females were combined).

Research needs include randomized trials of screening strategies with confirmatory testing and longitudinal followup, as well as rigorous treatment RCTs of promising medications, supplements, and dietary interventions with long-term followup. Long-term followup studies of pediatric cohorts, including racially/ethnically diverse cohorts, are needed to better establish the long-term health risks conferred by elevated TC and LDL-C concentrations. Although not the focus of this systematic review, our findings support a re-examination of the commonly accepted fixed NCEP threshold TC and LDL-C concentrations that define dyslipidemia and a reconsideration of age- and sex-specific cut points.