# Results

## Literature Search

We reviewed 7,137 unique abstracts and excluded 6,600. We reviewed 537 full-text articles and excluded 521 (Appendix C). The remaining 16 articles are the body of evidence for this review. We included four screening studies (the source for eight articles) (Table 3) and two treatment studies (the source for seven articles) (Table 4). There was overlap between the two KQs on treatment: two studies (the source for five articles) were included for KQ6 and one study (the source for five articles) was included for KQ7. One of these studies and three of the articles were included for both KQ6 and KQ7. We included one study of association between intermediate and health outcomes (Table 5).

## Results of Included Studies

### KQ1 Does Screening for Multifactorial Dyslipidemia in Asymptomatic Children and Adolescents Delay or Reduce the Incidence of MI or Stroke in Adulthood?

No studies were identified.

### KQ2 Does Screening for Multifactorial Dyslipidemia in Asymptomatic Children and Adolescents Improve Intermediate Outcomes in Childhood and Adolescence?

No studies were identified.

### KQ3 What Is the Diagnostic Yield of Screening for Multifactorial Dyslipidemia in Children and Adolescents?

#### Description of Included Studies

One fair-quality study in a large group practice in Ohio met all inclusion criteria.49 This study was also included in the 2007 USPSTF review. Several screening studies were excluded because they did not conduct confirmatory testing of individuals who screened positive. Diagnostic yield is the number of true-positive results divided by the total number of individuals screened. This means that individuals screening positive needed to undergo a second test to differentiate true- from false-positive results. Among studies with confirmatory testing, several screened children using various definitions of dyslipidemia that did not meet our inclusion criteria, such as relying only on nonfasting concentrations, using a lower TC threshold in the 170 to 185 mg/dL range,50-53 and including elevated triglyceride and decreased HDL-C concentrations along with TC and LDL-C concentrations in the definition of dyslipidemia.54

Given the dearth of studies meeting our criteria, we searched for large, recent U.S. studies that reported results of lipid screening—using a TC concentration of 200 mg/dL or greater, an LDL-C concentration of 130 mg/dL or greater, or both—on a single occasion. We reviewed several such population-based studies that had initially been excluded and chose three to include in this review. These studies provide a population-based prevalence of screening yield for elevated TC and LDL-C concentrations in children and adolescents in different demographic and risk factor subgroups. In addition to offering contextual information, the prevalence of elevated TC concentrations can be combined with the PPV from the older Ohio study to compute a simulated diagnostic yield: screening yield × PPV of the initial screen = diagnostic yield.

The three included screening studies (seven publications) using a single lipid test were:

1. NHANES. This survey is conducted in consecutive 2-year cycles on a national sample selected with a multistage, stratified sampling design. NHANES is designed to produce results representative of the civilian, noninstitutionalized U.S. population. Four good-quality published reports used data from NHANES surveys conducted between 1999 and 2012 to describe the epidemiology of elevated TC and LDL-C concentrations in U.S. children and adolescents and among different subgroups.8, 15, 55, 56
2. West Virginia CARDIAC Program. Two publications report 2003 to 2008 TC and LDL-C data from this statewide screening program targeting fifth graders.7, 57
3. A retrospective analysis of electronic health records from three large U.S. health systems (in California, Colorado, and Minnesota) reported on the frequency of pediatric lipid screening and also provided data on the prevalence of elevated TC and LDL-C concentrations in a sample of almost 30,000 children and adolescents.58

There were no studies that used non–HDL-C to screen children or adolescents for multifactorial dyslipidemia. All of the included studies were published after the 2007 USPSTF review on this topic.

#### Included Populations

The Ohio study49 (Table 6) screened 6,500 3- to 18-year-olds (mean age, 6.4 years) receiving care at a large pediatric group practice between 1986 and 1988. No exclusion criteria were stated, so the study population may have included children with known primary or secondary dyslipidemia. Refusal rate was not reported. The authors described the population as “largely white, middle class.”

NHANES is based on a nationally representative sample. The overall response rate among persons selected to take part in NHANES was 77 percent.59 In 2011 to 2012, the survey oversampled Asians (30.5%), and the 1999 to 2006 data appear to reflect an oversampling of blacks (40.0%) and Mexican Americans (34.4%), with whites representing only 25.5 percent of the sample. The four NHANES publications included here focused on overlapping age ranges, with the lower limit at ages 6 to 8 years and the upper limit at 17 to 19 years. These publications have partially overlapping populations; however, only data from nonoverlapping NHANES samples are shown in Tables 7–9. Individuals were not excluded from analyses for a diagnosis of primary or secondary dyslipidemia.

The CARDIAC study recruited fifth-grade students from schools in all 55 West Virginia counties. The racial/ethnic distribution was 93 percent white, 3 percent black, 2 percent biracial, and less than 1 percent each Asian, Hispanic, and other.7, 57 No exclusion criteria are stated, so the study population may have included children with known primary or secondary dyslipidemia.

The health system study included 3- to 19-year-olds enrolled in three large health systems in California, Colorado, and Minnesota. The racial/ethnic distribution for girls was 38.8 percent white, 9.9 percent black, 6.5 percent Asian, 19.8 percent Hispanic, 1.5 percent other, and 23.5 percent missing. The distribution for boys was similar. Individuals with known primary or secondary dyslipidemia were excluded.

All included studies had approximately equal numbers of boys and girls.

#### Included Interventions

The Ohio and CARDIAC studies were designed as population-based screening trials; both used a universal screening approach. The Ohio study drew a nonfasting blood sample from children and adolescents who presented for well-child care. Those with nonfasting TC concentrations of 200 mg/dL or greater were asked to return to the clinic for a fasting lipid profile. An LDL-C concentration of 130 mg/dL or higher was considered to be elevated. Children and adolescents with elevated LDL-C received counseling and were referred to a nutritionist. No further workup or diagnostic evaluation for these children is described.

In CARDIAC, parents of all fifth-grade students in West Virginia were asked to participate in a cardiac risk factor assessment, including the collection of anthropometric data, blood pressure measurements, an examination for acanthosis nigricans, and a fasting lipid panel, including TC, LDL-C, HDL-C, and triglyceride concentrations. Survey staff based in schools disseminated information to parents, obtained parent consent and child assent, and conducted screenings. Parents were asked to complete a five-item family history questionnaire about premature CHD, defined as first- or second-degree relatives who had experienced MI, coronary bypass surgery, angioplasty or stent, or coronary death before age 55 years. Children with TC concentrations of 200 mg/dL or greater or with LDL-C concentrations of greater than 130 mg/dL were considered screen-positive. Families received a health report with the results of screening, interpretations of the findings, and followup care recommendations.

In contrast to the Ohio and CARDIAC screening trials, NHANES and the health system study were designed to determine population-based prevalence. Thus, the actual screening approaches described should not be considered to be directly applicable to primary care settings, but the blood tests and cut points are relevant to primary care. NHANES participants were interviewed at home and invited to attend a mobile examination center, where they underwent examinations and provided a blood sample. Participants of all ages provided nonfasting samples for TC testing. In addition, 12- to 19-year-olds also provided fasting samples for LDL-C testing.

All NHANES publications included in this review used the NCEP cut points of 200 mg/dL for TC and 130 mg/dL for LDL-C.38 One of the NHANES publications55 also used as cut points the Lipid Research Clinic's age- and sex-specific 95th percentile values for TC and LDL-C.44 The health system study collected laboratory data on TC and fasting LDL-C from laboratory data in the electronic health record. This study also used the NCEP cut points.

#### Quality

Four publications from three studies were rated as fair quality7, 49, 57, 58 and four publications from a single study (NHANES) were rated as good quality.8, 15, 55, 56 The major limitations for the fair-quality studies were nongeneralizable populations, inappropriately addressed nonindependence of observations, and the use of nonfasting lipid concentrations. Three articles were excluded for quality, 40 for study design issues, and 24 for screening method (Appendix C).

#### Overall Results and Summary of Findings

The 1989 Ohio study used nonfasting TC concentrations to screen children and adolescents universally. At a cut point of 200 mg/dL, this screening approach had a PPV of 77 percent and a diagnostic yield of 5.8 percent. We then sought more recent estimates of the prevalence of elevated TC concentrations in U.S. children for simulating the expected diagnostic yield of this test. From the literature, we identified prevalence estimates for elevated TC concentrations (and standard errors [SEs] or confidence intervals [CIs]) for the overall population and for relevant subgroups. We applied the PPV of 77 percent and obtained simulated diagnostic yields ranging from 4.8 to 12.3 percent (Table 9).

#### Detailed Results

##### The Ohio Practice-Based Study

The Ohio practice-based study screened 6,500 children and adolescents presenting for care. The prevalence of elevated nonfasting TC concentrations was 8.5 percent. Of these children, 88 percent returned for a second screen after 1 to 6 weeks, and 77 percent of these had a fasting LDL-C concentration of 130 mg/dL or greater (i.e., PPV of 77%). The diagnostic yield was 5.8 percent. The authors do not report prevalence by subgroups, such as age or BMI categories.

The Ohio study met all our inclusion criteria, but it is older and limited to a single pediatric practice. Therefore, we analyzed three large U.S. studies. All lacked confirmatory testing and so did not report diagnostic yield. However, they did provide point estimates (and two provided CIs) of the prevalence of elevated TC in the U.S. population and relevant subgroups. We estimated diagnostic yield by combining these more current estimates of the prevalence of elevated TC with the PPV from the older Ohio study. Of note, these studies report data on the prevalence of both TC and LDL-C abnormalities. Although the simulation requires TC as the initial test, we also present LDL data from these studies here to provide additional context for LDL-C elevations.

##### NHANES

Of the four included NHANES studies, three reported the prevalence of elevated TC concentrations8, 15, 55 and three on the prevalence of elevated LDL-C concentrations.15, 55, 56 Favorable (decreasing) trends in TC were seen between 1988 and 1994 and between 2011 and 2012.^8, 15^ Age- and sex-specific mean lipid concentrations were consistent with other studies: mean TC concentrations varied with age, rising from age 3 years until age 8 to 10 years, dropping during puberty, and then rising again at ages 15 to 17 years.55 This trajectory was similar for both sexes, although boys lagged behind girls by 1 to 2 years. The highest rates of elevated TC concentrations by age group were found in ages 9 to 11 years (9.4%) and 16 to 19 years (9.4%).15 Despite this association with age, differences in age-specific prevalence of elevated TC concentrations were not statistically significant in any of the NHANES studies (Table 7).8, 15, 55

Of the three publications that reported the prevalence of elevated LDL-C concentrations, two have entirely overlapping samples (from the 1999 to 2006 NHANES cycles), so we report LDL-C data from the one with an analysis of BMI subgroups and exclude the other from Table 8.^55^ Favorable trends in LDL-C were seen between the 1988 to 1994 survey and the 2007 to 2010 survey.15 The highest age-specific rate of elevated LDL-C concentrations was reported in 18- to 19-year-olds.56 Again, despite this association with age, differences in age-specific prevalence were not statistically significant in any of the NHANES studies.15, 55, 56 The prevalence of elevated LDL-C concentrations was significantly greater in children with obesity (BMI >95th percentile for age and sex) than in healthy-weight children (prevalence ratio, 2.5 [95% CI, 1.6 to 3.8]). A similar but nonsignificant association was found for overweight children (BMI between the 85th and 95th percentile for age and sex; prevalence ratio, 1.4 [95% CI, 0.8 to 2.5]) (Table 8).

One of these NHANES studies55 also estimated the number of adolescents who would meet the criteria for pharmacotherapy, as recommended by the NHLBI consensus panel; that is, LDL-C concentrations greater than 190 mg/dL, greater than 160 mg/dL with two risk factors, or greater than 130 mg/dL with diabetes. Among 12- to 17-year-olds, 0.8 percent meet these criteria for lipid-lowering medications. Of these, about half had LDL-C concentrations greater than 190 mg/dL, a concentration consistent with FH.55

##### The CARDIAC Study

The West Virginia CARDIAC study screened 23,263 fifth-grade students (ages 10 to 11 years) statewide between 2003 and 2008^7, 57^ for several cardiac risk factors. Of all eligible children, 24.6 percent had fasting lipid profiles available for analysis. The prevalence of elevated TC concentrations (≥200 mg/dL) was 10.7 percent.7 (Neither of the two publications on this trial reported CIs for prevalence estimates.) Point estimates were 7.5 percent for children with a BMI below the 85th percentile, 11.5 percent for overweight children (between the 85th and 95th percentiles), and 16.0 percent for obese children (>95th percentile). Elevated LDL-C (>130 mg/dL) was reported in 8.7 percent of children.7

A second publication from this same study examined the prevalence of elevated LDL-C concentrations in children with and without a family history of premature CHD, defined as first- or second-degree relatives who had experienced MI, coronary bypass surgery, angioplasty or stent, or coronary death before age 55 years. Point estimates for the prevalence of elevated LDL-C concentrations were 8.3 percent for those with a family history and 9.5 percent for those without (Tables 7 and 8).57

##### The Health System Study

In this retrospective analysis of automated medical records, children ages 3 to 19 years with at least one clinic visit in the period from 2007 through 2010 were included.58 Out of the initial cohort (N=301,080), 29,360 (9.8%) had at least one TC measurement on record. The first TC or LDL-C measurement was used in the analyses (Tables 7 and 8). The highest point estimates for both TC and LDL-C measurements were in 9- to 11-year-olds and 17- to 19-year-olds, compared with 3- to 8-year-olds and 12- to 16-year-olds. Elevated TC concentrations increased with BMI. The percentage of children and adolescents with elevated TC measurements was 10.7 percent in the obese group, 8.6 percent in the overweight group, and 6.7 percent in the healthy-weight group. The 95% CIs did not overlap. A similar association was found for LDL-C measurements, although the CIs for overweight and obese children overlapped a little.

##### Simulating the Prevalence of Dyslipidemia

Combining point estimates of the prevalence of elevated TC concentrations in participants from the NHANES8, 15 and CARDIAC studies7 with the PPV of an initial TC screen derived from the Ohio study, we simulated a range of diagnostic yields (Table 9).49 For this simulation, we selected TC estimates from the two NHANES publications that provided the most recent and age-specific data. Because of the variability across age groups, we did not use an overall population estimate. In addition, the BMI category-specific data from the CARDIAC study highlighted the greater prevalence of TC elevations in obese children. The highest estimated diagnostic yield was for obese 10- to 11-year-olds (12.3%).7 Across the age categories reported in the 2007 to 2010 NHANES publication, the prevalence (and projected diagnostic yield) rose and fell, reflecting the known biological trajectory of TC.15

### KQ4 What Are Harms of Screening for Multifactorial Dyslipidemia in Children and Adolescents?

No studies were identified.

### KQ5 Does Treatment of Multifactorial Dyslipidemia With Lifestyle Modifications and/or Lipid-Lowering Medications in Children and Adolescents Delay or Reduce the Incidence of Adult MI and Stroke Events?

No studies were identified.

### KQ6 Does Treatment of Multifactorial Dyslipidemia With Lifestyle Modifications and/or Lipid-Lowering Medications in Children and Adolescents Improve Intermediate Outcomes in Childhood and Adolescence?

#### Description of Included Studies

We included two treatment trials (five publications),60-64 one good- and one fair-quality in children and adolescents with elevated TC and LDL-C concentrations (Table 4). One of these trials62 was included in the 2007 USPSTF childhood dyslipidemia review, and one was published in 2013.^60^ The Dietary Intervention Study in Children (DISC) was an RCT of a modified NCEP Step II diet2 with a multiyear intervention and long-term followup. One report of this trial was published after the 2007 review.64 Although the DISC trial enrolled children with lower LDL-C concentrations than stipulated in our inclusion criteria, we included it because it is the largest published high-quality trial of dietary intervention to lower cholesterol concentrations in children with mild-to-moderate dyslipidemia. The other trial was a small, short-term study of a dietary supplement (flaxseed) in children with moderate-to-severe dyslipidemia.60 No studies meeting the inclusion criteria evaluated the effect of interventions for childhood dyslipidemia on atherosclerosis outcomes, and none evaluated the effect of drugs on intermediate outcomes in children with multifactorial dyslipidemia. No studies meeting the inclusion criteria evaluated interventions targeting primarily HDL-C or triglyceride concentrations.

#### Included Populations

The two trials included 32 and 663 participants (Table 4). Trial participants were drawn from somewhat different age groups. The DISC trial included children ages 8 to 10 years, whereas the flaxseed trial recruited children ages 8 to 18 years (mean, 13.2 years [standard deviation (SD), 2.3 years]).60 Girls and boys were well represented in both trials. The dietary trial was conducted in the United States61 and the other in Canada.60 In DISC, 86.6 percent of participants were white.61 The flaxseed trial did not report race. The DISC trial recruited participants by screening asymptomatic children recruited from schools, health plans, and primary care clinics.61 The flaxseed trial derived its participants from a tertiary care lipid clinic.60

Dyslipidemia was defined using elevated fasting lipid concentrations in both trials, but the trials differed with regard to degree of dyslipidemia. The flaxseed trial was the only one that met the predetermined inclusion criteria of abnormal LDL-C or TC concentrations, as defined by the NCEP criteria. This trial required children to have elevated fasting serum LDL-C concentrations (135 to 193 mg/dL) on a single occasion. The dietary trial had lower cut points for LDL-C and TC values, representing mild-to-moderate elevations.61 As described in the Methods section, the DISC trial was included despite not meeting these inclusion criteria because this large, high-quality diet trial with good retention and long-term followup was likely to provide useful information, given the lack of other large studies and the lack of any other dietary trials.

In the DISC trial, asymptomatic children were recruited from primary care sites. Lipid concentrations were measured on three occasions and compared to percentiles from the Lipid Research Clinics study.65 Children were initially selected on the basis of a nonfasting TC concentration greater than 175 mg/dL. Children with fasting LDL-C concentrations between the 70th and 99th percentiles for age and sex were offered a second fasting LDL-C test at the next visit. Children met the dyslipidemia criterion if the average of the two LDL-C measurements was between the 80th and 98th percentiles for age and sex. This criterion put many of the DISC participants below the NCEP definitions of high TC (200 mg/dL) and LDL-C (130 mg/dL) concentrations. Thus, the DISC trial consisted of children with moderately elevated LDL-C concentrations. In addition, DISC also excluded children with triglyceride concentrations greater than 200 mg/dL or HDL-C concentrations less than 30 mg/dL.

The flaxseed trial differed from the DISC trial in several other respects. It required participants to have a first-degree relative with a history of hypercholesterolemia or premature atherosclerotic cardiovascular disease, and participants had to have adhered to the NCEP Step II diet for a minimum of 6 months before enrollment. Thus, these participants had a family history of dyslipidemia and more severe elevations that did not respond to a low-fat diet. Although not identified as having FH, and therefore excluded from the concurrent review on screening for FH,66 these 32 children have a more severe phenotype than those who participated in the DISC trial.

Children and youth with illnesses known to cause secondary hyperlipidemia or taking any lipid-lowering medications were excluded from both trials. The DISC trial excluded children with any sign of puberty at baseline. The flaxseed trial excluded children with known allergies to flaxseed.

Mean lipid concentrations in the DISC trial were close to the 95th percentile of the Lipid Research Clinics population for this age group, in accordance with the studies' inclusion criteria. The mean TC and LDL-C concentrations were somewhat higher in the flaxseed trial, which also included older children, so these lipid concentrations represented a greater degree of elevation relative to age-specific norms.

#### Included Interventions

The DISC trial evaluated a modified NCEP Step II diet delivered using a family-based counseling approach (Table 1). The initial intervention period lasted 3 years. During the first 6 months, participants had 11 group visits and two individual family visits. In the subsequent 2.5-year maintenance phase, group and individual visits tapered to monthly and then quarterly, with monthly telephone contacts in between. Parents of control group participants received written educational materials about a heart-healthy diet and were informed of their child's baseline cholesterol concentrations. The trial was later extended beyond the initial 3 years, and participants in the intervention group continued to receive dietary counseling, albeit at a lower intensity, for about 8 years.63 Finally, a subset of female participants was assessed again 9 years after the conclusion of the study, during which time no intervention was delivered.64 Outcomes were evaluated at 1, 3, and 5 years after randomization, at the end of the trial (about 8 years after randomization), and again 9 years after the end of the trial (about 17 years after assignment).

The flaxseed intervention consisted of 30 g per day of ground flaxseed delivered through specified quantities of specially prepared muffins and bread. The control group received placebo muffins and bread with whole wheat flour instead of flaxseed.60 Outcomes were assessed at the end of the 4-week intervention.

#### Quality

The flaxseed trial was rated as fair quality60 and the DISC trial as good quality.61-64, 67, 68 The major limitations for the flaxseed study were the small sample size, 4-week duration, and recruitment from a tertiary care clinic. One trial was excluded for poor quality, and 50 studies were excluded for not being RCTs (Appendix C).

#### Overall Results

The two RCTs in children and adolescents with multifactorial dyslipidemia that met our inclusion criteria evaluated different treatments. Details from these studies are discussed below (Table 4). A low-fat dietary counseling intervention lowered mean LDL-C and TC concentrations relative to the control group 1 and 3 years later. This effect diminished with time.64, 67 A small, fair-quality trial of flaxseed found no effect on TC or LDL-C concentrations after 4 weeks.60

#### Detailed Results

##### Effect on Lipid Concentrations

One good-quality RCT evaluated the effect of a modified NCEP Step II diet with behavioral counseling to reduce moderately-elevated LDL-C concentrations in 663 children. Mean baseline fasting TC concentration for DISC participants was 200 mg/dL (SD, 14.6 mg/dL) for both the intervention and control groups. Mean fasting LDL-C concentrations were 130.6 mg/dL (SD, 12.2 mg/dL) and 130.5 mg/dL (SD, 11.6 mg/dL) for the intervention and control groups, respectively (Table 10). Mean baseline HDL-C and triglyceride concentrations were in the normal range. Intervention and control groups were otherwise similar at baseline.

This study was initially planned as a 3-year RCT, with a 6-month intensive intervention phase followed by 2.5 years of a lower-intensity maintenance phase. After DISC was extended to follow participants to age 18 years, intervention and annual assessments continued. Youth were last assessed at age 18 years (15.3%) or, because of funding constraints, at a closeout visit before age 18 years (84.7%).63 An additional 19 participants (3%) who had initially declined to continue returned for a closeout visit. The age 18 and closeout visits were combined in all analyses and were referred to as “last visit” or year 7; 580 of the original 663 DISC participants (87.5%) were assessed at year 7. Mean age at year 7 was 17.0 years (SD, 0.91 years).63 Retention varied across DISC time points, ranging from 94.0 percent at year 3 to 78.7 percent at year 5. An ancillary funded study (DISC06) recruited women who had taken part in DISC as children and adolescents to undergo a single assessment 9 years after the end of DISC (18 years after randomization). The DISC06 followup study examined a series of biomarkers related to breast cancer risk as well as certain metabolic measurements.64

Attendance at all study contacts (individual and group sessions as well as phone calls) was recorded. Attendance was highest in the first year, with participants attending a mean of 96 percent of the 19 total contacts. By year 5, attendance had dropped to a mean of 72 percent of about four contacts, and in the final year of the initial trial (about 8 years after randomization), intervention participants attended a mean of 1.3 contacts per year.

Adherence to dietary recommendations was assessed using a 24-hour dietary recall instrument administered by trained certified dietitians on three nonconsecutive days within 2 weeks of the clinic visit. At baseline, dietary intake of cholesterol, fat (total, saturated, monounsaturated, and polyunsaturated), protein, carbohydrate, and energy did not differ significantly between groups. Mean total fat intake (as a percentage of energy intake) in the intervention group was 28.5 percent (SD, 5.8%) at year 1 and 28.6 percent (SD, 5.8%) at year 3. These values were both consistent with the recommended fat intake for the DISC diet (28%) and significantly lower than the mean total fat intake for control subjects of 33.1 percent (SD, 5.5%) at year 1 and 33.0 percent (SD, 4.7%) at year 3 (p<0.001 for adjusted mean differences at both time points). Mean intake of cholesterol, fat subtypes (saturated, monounsaturated, and polyunsaturated), and energy was significantly lower in the intervention group than in the control group at year 1 for all measures, except polyunsaturated fat, and at year 3 for all measures (p<0.001 for all adjusted differences, except that energy intake at year 1 had p=0.004 and polyunsaturated fat intake at year 3 had p=0.03). Protein and carbohydrate intake was significantly higher in the intervention group than in the control group at both year 1 and year 3 (p<0.001 for all adjusted mean differences, except that protein intake at year 1 had p=0.001).

To minimize regression to the mean, two fasting blood samples were analyzed for lipid concentrations 1 month apart, once at baseline and again at year 3. Single lipid measurements were obtained at years 1, 5, and 7. Concentrations of TC, HDL-C, and triglycerides were measured with standard methods, and LDL-C concentration was calculated.

Decreases in LDL-C and TC relative to the control group were seen in participants randomized to the dietary intervention (Table 10, Figures 2 and 3). These were statistically significant only at years 1 and 3. The mean adjusted differences between groups were greatest 1 year after randomization (-6.1 mg/dL for TC and -4.8 mg/dL for LDL-C; p<0.001) and were smaller but still statistically significant at year 3. The groups did not differ significantly at year 5 (LDL-C and TC), year 7 (LDL-C and TC), or year 18 (LDL-C only).

Figure 2 Results From DISC Study: Mean Total Cholesterol

Mean age of study participants was 9.5 years at baseline and 17.0 years at year 7. Mean age was not reported at other time points.

Abbreviation: DISC=Dietary Intervention Study in Children.

Figure 2 is a graph showing the results of the DISC (Dietary Intervention Study in Children) study on total cholesterol, from baseline through year 7. The graph shows that participants randomized to the dietary intervention experienced decreases in total cholesterol relative to the control group, but these decreases were statistically significant only at years 1 and 3.

Figure 3 Results From DISC Study: Mean Low-Density Lipoprotein Cholesterol

Mean age of study participants was 9.5 years at baseline and 17.0 years at year 7. Mean age was not reported at other time points.

* Years 5 and 7 have no error bars because the articles did not report standard deviations for mean LDL levels.

Abbreviation: DISC=Dietary Intervention Study in Children; LDL-C=low-density lipoprotein cholesterol.

Figure 3 is a graph showing the results of the DISC (Dietary Intervention Study in Children) study on LDL (low-density lipoprotein) cholesterol, from baseline through year 7. The graph shows that participants randomized to the dietary intervention experienced decreases in LDL cholesterol relative to the control group, but these decreases were statistically significant only at years 1 and 3.

One fair-quality, double-blind, 4-week RCT evaluated flaxseed supplementation against placebo.60 Mean fasting lipid concentrations for participants at baseline were: TC of 208 mg/dL (SD, 30 mg/dL); LDL-C of 138 mg/dL (SD, 25 mg/dL); HDL-C of 49 mg/dL (SD, 12 mg/dL); and triglycerides of 112 mg/dL (SD, 47 mg/dL) (Table 11). Differences between intervention and control groups at baseline were not statistically significant, except for HDL-C, which was higher in the flaxseed group (p=0.05) (Table 11). Outcomes were compared between groups after 4 weeks of receiving baked goods with flaxseed or placebo (whole wheat). One patient was lost to followup; analyses were conducted based on intent-to-treat. Daily logs and an accounting of unconsumed foods revealed a mean of 80 percent (SD, 18%) adherence to the dietary supplement in the placebo group and 85 percent (SD, 12%) in those receiving flaxseed. Flaxseed was associated with lower, but not statistically significant, TC and LDL-C concentrations relative to placebo (4% and 5%, respectively) (Table 11). The decrease in HDL-C in the intervention group was 15 percent greater than the decrease in the placebo group (p=0.001). The relative difference between groups in change in triglycerides was 26 percent (p=0.02; increase in intervention group compared to placebo).

##### Effect on Atherosclerosis Markers

No studies assessed the effect on atherosclerosis markers of treating dyslipidemia in children with multifactorial dyslipidemia.

There were too few studies of any one treatment to allow for exploration of heterogeneity or publication bias.

### KQ7 What Are the Harms of Treatment of Multifactorial Dyslipidemia With Lifestyle Modifications and/or Lipid-Lowering Medications in Children and Adolescents?

#### Description of Included Studies

One RCT, the DISC trial, included in KQ6, met all inclusion criteria for assessing potential harms of treating children and adolescents with elevated TC or LDL-C concentrations (Table 4). This trial yielded five good-quality publications with harms data; one was published after the 2007 USPSTF review.64 Also, as mentioned above, the DISC trial was included, despite the fact that its LDL-C requirement was lower than our inclusion criterion, because of its potential contribution to understanding the impact of dietary intervention to lower cholesterol concentrations in children with mild-to-moderate dyslipidemia. Studies reporting on treatments that had at least some evidence of effectiveness were considered for inclusion for KQ7. We excluded the flaxseed trial included in KQ6 because the intervention had no benefit.60

#### Included Populations

The DISC trial cohort is described above under KQ6.

#### Included Interventions

The DISC modified NCEP Step II diet and family-based counseling approach are described above under KQ6.

#### Assessment of Harms

The DISC participants' anthropometric measurements (weight, height, and BMI) were assessed at baseline and annually through the final visit in the original study (referred to here as “year 7,” although the actual time after randomization ranged from 6.5 to 9.3 years).63 Anthropometrics were measured again at the 2006–2008 followup (referred to here as “year 18”).64 In addition, measurement of skin fold thicknesses in various locations and of mid-arm, waist, and hip circumferences was taken at baseline, year 1, and year 3. Waist circumference was also measured at year 18. Sexual maturation was evaluated at every visit through year 5 or until the participant reached Tanner Stage 5. Age at menarche was recorded for females at year 7 and at year 18. Blood pressure was measured at baseline, year 1, year 3, and year 18.

Serum concentrations, measured at baseline, year 1, and year 3, consisted of albumin, zinc, copper, ferritin, red blood cell folate, retinol, tocopherol, carotenoids, vitamin E, and hemoglobin. Serum glutamic pyruvic transaminase, chemistry panel, fasting blood glucose, and fatty acid distribution in cholesterol esters were also measured at baseline and were scheduled to be measured at either 6 or 24 months; however, no results were reported past baseline. In addition, ferritin, folate, retinol, and zinc were measured at year 7 and blood glucose was measured at year 18.

Diet was assessed with three random, 24-hour dietary recalls at all time points through year 7 to estimate the intake of fats, cholesterol, protein, and carbohydrate. The intake of vitamins A, C, B6, E, and B12 and calcium, magnesium, phosphorous, thiamine, niacin, riboflavin, folate, iron, and zinc was monitored at these time points to warn of possible deficiencies.

Psychosocial assessments68 were done at year 3 and included: the Child Behavior Checklist (internalizing, externalizing, social competency, thought problems, anxiety/depression, and aggression/conduct subscales and total score), State-Trait Anxiety Inventory, Child Depression Inventory, Woodcock-Johnson Psychoeducational Battery (mathematics and reading achievement), and the Family Environment Scale (cohesion, conflict, intellectual/cultural orientation, moral religious orientation, and achievement orientation subscales). Medical history collected from parents at baseline and years 1 and 3 included questions about whether a doctor had told them in the past 12 months that their child had anorexia or bulimia and whether the child had expressed suicidal thoughts or behavior.

#### Quality

The DISC trial was rated as good quality. One trial of a dietary intervention was excluded for poor quality69 (Appendix C). Other trials were excluded because they were not RCTs.

#### Overall Results

The DISC trial revealed no harms of a modified NCEP Step II dietary intervention with behavioral counseling in children with multifactorial dyslipidemia. Details regarding the different types of harms assessed at the various time points are discussed below (Table 12).

#### Detailed Results

The DISC trial reported no harms of the dietary intervention at any time point. Growth and adiposity were similar in the two study groups at all times,62, 63, 67, 68 with the exception of a lower waist-to-hip ratio in the intervention group noted at year 1 only.62 Mean systolic and diastolic blood pressures did not differ between groups at years 1 and 3. Sexual maturation or age of menarche was also similar in both groups through year 7. Biochemical analyses, including blood micronutrients, did not differ between groups, with the exception of an unexpected benefit of higher mean retinol concentration in the intervention group at year 3 (0.4 μg/dL greater than control; p=0.04) and again at year 7 (2.4 μg/dL greater than control; p=0.02). The difference was not significant at year 1.^63^ The only significant difference between groups for nutrient intake was that mean daily zinc intake was lower in the intervention group (-0.5 vs. +0.6 mg; adjusted mean difference, -0.6 mg; p=0.03).62 The adjusted mean difference was no longer significant at year 3, and no other significant differences in intake of vitamins or nutrients were reported at any time period.

Psychosocial measures at 3 years were largely similar between groups.68 The proportions with elevated scores on the Child Behavior Checklist Internalizing and Externalizing subscales and on the Total Behavior Problem score were similar, as was the proportion with elevated anxiety scores on the State-Trait Anxiety Inventory and the proportion with low (≤25th percentile) scores on mathematics and reading performance on the Woodcock-Johnson Psychoeducational Battery. The only difference in psychosocial outcomes between groups was for depression, where the odds ratio of the treatment group was 0.24 (95% CI, 0.09 to 0.65) for scoring above the cut point, indicating depression on the Child Depression Inventory (p<0.005).

Means of all psychosocial measurements were also compared between groups using linear regression and adjusting for baseline values of age, sex, household income, and number of parents in the household. An interaction term for treatment group × sex was entered into separate models. Across a large number of comparisons, some statistically significant differences were found, some favoring the control group and some the intervention group. Individual differences between groups were not clinically significant.

At the year 18 followup (i.e., ages 25 to 29 years), the groups did not differ significantly in mean height, weight, BMI, adiposity, or reproductive characteristics among the women (the men were not included in this followup observational study).64 Frequency of metabolic syndrome did not differ between groups. However, both systolic blood pressure and fasting plasma glucose concentrations were significantly lower in the treatment group (mean systolic blood pressure, 107.7 vs. 110.0 mm Hg; p=0.03; fasting plasma glucose, 87.0 vs. 89.1 mg/dL; p=0.01). Substituting percent body fat (obtained by dual-energy X-ray absorptiometry from 215 participants) for BMI in models that included nondietary variables did not materially alter these results.

Three random, nonconsecutive, 24-hour dietary recall surveys were collected from each subject and analyzed for intake of sodium, calcium, potassium, and magnesium (in addition to analyses of fatty acid, fiber, and calorie intake); nutrient intake was not significantly different between groups, although intake of dietary fiber was higher in the intervention group and intake of saturated fatty acids was lower in the intervention group. Alcohol intake was significantly higher in the treatment group (4.0 vs. 2.5 drinks/week in controls; p=0.05). Leisure physical activity in the past year did not differ significantly between groups.

### KQ8 What Is the Association Between Intermediate Outcomes in Childhood and Adolescence and Future Incidence of MI and Stroke Events in Adults?

#### Included Studies

One good-quality study met the inclusion criteria for KQ8, although the sample included adults and children (age range, 12 to 39 years), and data were not reported by age subgroups.70 The aim of the study was to identify any associations between mortality before age 55 years and several cardiovascular risk factors: lipid and hemoglobin A1c (glycosylated hemoglobin) concentrations, smoking, adiposity, and blood pressure. We included this study for its potential to provide useful evidence about the association between elevated TC concentrations in adolescents and young adults and mortality before age 55 years in the absence of any other included evidence.

#### Included Population

This study identified a cohort of 9,245 NHANES participants between 1988 and 1994 who were ages 12 to 39 years at the time of the survey. Half the participants were female, mean age was 26.1 years (SE, 0.17 years), 77.2 percent were non-Hispanic white, 14.7 percent were non-Hispanic black, and 8.1 percent were Mexican American. Participants whose race/ethnicity was classified as something other than these three categories were excluded from analysis. Baseline mean TC concentration was 182.0 mg/dL (SE, 0.82 mg/dL), and 28.5 percent of participants had TC concentrations greater than 200 mg/dL, consisting of 20.9 percent with concentrations between 200 and 239 mg/dL and 7.6 percent with concentrations greater than 240 mg/dL.

#### Included Interventions

Lipid concentrations and baseline data were obtained as per NHANES procedures, outlined above as part of KQ3.

#### Included Outcomes

Outcomes of interest were death before age 55 years from all causes and death before age 55 years from endogenous causes only (i.e., from diseases and self-inflicted injury but not from accidents or homicides). Vital status was assessed using National Death Index data from 1988 through 2006. The followup period was 12 to 18 years.

#### Quality

Although the included study was of good quality, it was considered to provide fair-quality evidence for KQ8, primarily because its age range was broader than our a priori inclusion criteria and because it is the only included study for KQ8. No studies were excluded for poor quality.

#### Summary of Findings

At the end of the study, 283 participants (3.1%) had died. Leading causes of death for the 12- to 19-year-olds were accidents, self-inflicted injuries, circulatory diseases, and cancer. Proportional hazards models were adjusted for sex, race/ethnicity, and chronic disease status. Risk for death before age 55 years was associated with central obesity (relative hazard [RH], 2.39), smoking (RH, 1.86), and elevated hemoglobin A1c concentrations (RH, 3.81). Elevated TC concentrations were not significantly associated with an RH for death before age 55 years (all causes and endogenous causes) when both sexes were included in the same analysis. Secondary analyses by sex (Table 13) found that for females, only a very high TC concentration (≥240 mg/dL) was associated with a greater risk of death before age 55 years (RH, 2.58 [95% CI, 1.31 to 5.08]), although a moderately high TC concentration (200 to 239 mg/dL) did not confer risk (RH, 0.77 [95% CI, 0.36 to 1.62]). The authors urge caution in interpreting the finding because it is based on fewer than 90 deaths among female participants. There were no significant associations for males.