# Methods

## Overview

This systematic review was designed to complement the systematic review supporting the recommendation on screening for FH in children and adolescents. For this review, we adapted the analytic framework for dyslipidemia screening in children used by the 2007 USPSTF review to address the benefits and harms of primary care–relevant screening and treatment of children and adolescents with multifactorial dyslipidemia. Multifactorial dyslipidemia, as defined above, is an elevation in the concentrations of TC or LDL-C from causes other than FH.

## KQs and Analytic Framework

Using the USPSTF's methods (Appendix A), we developed an analytic framework (Figure 1) and eight KQs.

Figure 1 Analytic Framework

* Intermediate outcomes include lipid levels (total, LDL, HDL, and non-HDL cholesterol; triglycerides) and atherosclerosis markers (carotid intima-media thickness, calcium score, pathological findings).

Abbreviations: HDL=high-density lipoprotein; LDL=low-density lipoprotein; MI=myocardial infarction

Figure 1 is an analytic framework that depicts the eight Key Questions (KQ) described in the Methods section. In general, it illustrates the overarching question: whether screening for dyslipidemia in children leads to improved health outcomes in adulthood (KQ1). The analytic framework also illustrates intermediate steps and Key Questions, such as whether screening for dyslipidemia in children leads to improved intermediate outcomes (KQ2), the diagnostic yield of screening (KQ3), the harms of screening (KQ4), whether treatment for dyslipidemia leads to improved adult health outcomes (KQ5) or intermediate health outcomes (KQ6), the harms of treatment (KQ7), and the association between intermediate outcomes in childhood and adolescence and adult health outcomes (KQ8).

### Screening KQs

1. Does screening for multifactorial dyslipidemia in asymptomatic children and adolescents delay or reduce the incidence of MI or stroke in adulthood?
2. Does screening for multifactorial dyslipidemia in asymptomatic children and adolescents improve intermediate outcomes (i.e., improve lipid concentrations or reverse or slow the progression of atherosclerosis) in childhood and adolescence?
3. What is the diagnostic yield of screening for multifactorial dyslipidemia in children and adolescents?
4. What are the harms of screening for multifactorial dyslipidemia in children and adolescents?

### Treatment KQs

5 Does treatment of multifactorial dyslipidemia with lifestyle modifications and/or lipid-lowering medications in children and adolescents delay or reduce the incidence of adult MI and stroke events?
6 Does treatment of multifactorial dyslipidemia with lifestyle modifications and/or lipid-lowering medications in children and adolescents improve intermediate outcomes (i.e., reduce lipid concentrations or reverse or slow the progression of atherosclerosis) in childhood and adolescence?
7 What are the harms of treatment of multifactorial dyslipidemia with lifestyle modifications and/or lipid-lowering medications in children and adolescents?

### Outcomes KQ

8 What is the association between intermediate outcomes in childhood and adolescence and future incidence of MI and stroke events in adults?

Intermediate outcomes in childhood and adolescence include lipid concentrations (TC, LDL-C, HDL-C, and non–HDL-C, as well as triglycerides) and atherosclerosis markers (CIMT, calcium score, and pathological findings).

## Data Sources and Searches

We designed this review to extend the 2007 systematic review on lipid screening in children. We worked with a trained medical librarian to develop the appropriate search strategy (Appendix A). Our search included results from: AHRQ, BMJ Clinical Evidence, Canadian Agency for Drugs and Technologies in Health, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, Health Technology Assessment (Centre for Reviews and Dissemination), Institute for Clinical Systems Improvement, Institute of Medicine, MEDLINE and PubMed, and the National Institute for Health and Care Excellence. On February 12, 2014, we conducted our original search for this review. The search was updated on June 13, 2014, and bridge searches were conducted on December 16, 2014 and June 2, 2015.

For the literature published before September 2005, we searched all publications cited in the 2007 USPSTF review. Although that review did not specifically address diagnostic yield (KQ3 in this review), several of their KQs addressed various aspects of screening. We conducted a focused search of the studies cited in the 2007 USPSTF review to identify any that met our criteria for KQ3. Also, because the 2007 USPSTF review did not have a KQ on the association between screening and intermediate outcomes (KQ2 in this review) or on the association between intermediate outcomes in children and adolescents with multifactorial dyslipidemia and health outcomes in adulthood (KQ8 in this review), we supplemented our search of the 2007 USPSTF citations with a search of the 2011 NHLBI expert panel report39, 47 and publications from large published cohort studies with longitudinal data (Appendix D). To ensure comprehensiveness of our search strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify articles that were not identified in our literature searches. We also supplemented our database searches with suggestions from experts and searched Clinicaltrials.gov to identify relevant ongoing trials (Appendix B). A diagram illustrating our literature search is in Appendix A Figure 1.

## Study Selection

Two investigators independently reviewed the title and abstracts of all identified articles to determine whether the study met the inclusion and exclusion criteria for design, population, screening, intervention, and outcomes (Appendix A Table 1). Two reviewers then independently evaluated 509 full-text articles against the complete inclusion and exclusion criteria (Appendix A Table 2). We resolved discrepancies through discussion and consultation with a third reviewer. Excluded studies and their reason for exclusion are listed in Appendix C.

For screening studies (KQs 1–4), we included studies of asymptomatic persons ages 0 to 20 years at screening. Populations already being followed for dyslipidemia or diagnoses associated with secondary dyslipidemia were excluded. Eligible screening interventions were defined as a lipid panel (fasting or nonfasting lipid measurement, TC or LDL-C alone or in combination with HDL-C) delivered in a universal or selective screening strategy. For the diagnostic yield question (KQ3), we initially required screening studies to include confirmatory testing and subsequent confirmed dyslipidemia. However, because of sparse evidence, we included studies of large U.S. populations and used single-test prevalence to simulate diagnostic yield. We excluded screening studies with modalities not relevant to screening in primary care practice.

For treatment studies (KQs 5–7), we included interventions using lipid-lowering drugs or lifestyle interventions, including diet or exercise. We focused on interventions targeting persons ages 0 to 20 years with multifactorial dyslipidemia at the beginning of the intervention. We accepted any class of lipid-lowering drug, including, but not limited to, statins and bile-acid sequestrants. We excluded studies that focused on treating those with secondary dyslipidemia or monogenic dyslipidemia. We included all reported clinical and laboratory harms associated with all included interventions with evidence of benefit, as per KQ6. Harms associated with interventions for which there was no KQ6 evidence were excluded.

We included studies with dyslipidemic populations of different causes when outcome data for those with multifactorial dyslipidemia were presented separately. We limited studies of efficacy or effectiveness to fair- to good-quality studies that were conducted in countries with a United Nations Human Development Index score of 0.9 or greater.48 Included intervention trials had to compare an intervention against a usual care or control group.

Consistent with current USPSTF methods, health outcomes (KQ1, KQ5, and KQ8) were defined as those experienced by the patient. We considered the incidence of disease (i.e., atherosclerosis or elevated lipid concentrations) to be intermediate outcomes (KQ2 and KQ6). We included trials, cohort studies, and observational studies that reported clinical or laboratory harms but did not include case series or case reports.

## Quality Assessment and Data Abstraction

Two reviewers independently appraised all articles that met the inclusion criteria for this review. The appraisal criteria were adapted from the USPSTF's design-specific quality criteria (Appendix A Table 1). Topic-specific quality criteria were designed with the assistance of clinical experts. The final quality rating used in the evidence tables was based on quality guidelines from the procedure manual for USPSTF reviews. We rated studies as good, fair, or poor quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet, or did not clearly meet, at least one criterion but also had no known issue that would invalidate its results. A poor-quality study had limitations that made inferences on a population difficult or unwarranted, such as lack of random assignment with biased assignment, unclear diagnostic criteria, unclear classification procedures, or missing baseline characteristics. We excluded poor-quality studies from this review. Excluded studies and their reason for exclusion are listed in Appendix C.

One reviewer extracted data from all included studies rated as fair or good quality into a standard evidence table. A second reviewer checked the data for accuracy. The reviewers abstracted study characteristics (e.g., population, purpose, exposure, and outcomes of the study), study design elements (e.g., recruitment procedures, inclusion/exclusion criteria, duration of followup, and attrition), RCT characteristics (e.g., setting, blinding, methods of measuring outcomes and exposures, duration, and lipid concentrations), outcomes for screening studies (e.g., true positives, diagnostic yield, and PPV), intermediate outcomes (e.g., lipid concentrations and CIMT) and health outcomes (e.g., MI and stroke), and harms.

## Data Synthesis and Analysis

The findings are summarized in Tables 3–14. We used the PPV from a study included for KQ3 to simulate diagnostic yield in other studies that did not conduct confirmatory testing. For screening studies, data on all relevant subgroups are presented. For treatment studies, lipid concentrations were expressed as percent change from baseline or difference from baseline. We did not combine data across studies for KQ6 because no two included studies used the same treatment. None of the KQs had a sufficient number of included studies to permit meta-analysis.

Table 3 Included Screening Studies

Type of study | Study, year Quality Country | Number screened | Study design | Age, years Mean (SD) | Age range | % Female | Race/Ethnicity | Population and setting | Dates of data collection | Included for key question
Study with confirmatory testing | Garcia 1989^49^ Fair U.S. (OH) | 6,500 | Cross-sectional | 6.4 (NR) | 3–18 | NR | 100% white | White, middle-class children being seen for well-child visits at a large, pediatric group practice | 1986–1988 | 3
Study without confirmatory testing –NHANES | Kit 2015^8^ Good U.S. | 13,172 | Cross-sectional | NR | 8–17 | 47.6%–50.3% (range across time periods) | Sample weights were used to obtain prevalence estimates representative of the civilian noninstitutionalized U.S. population | Nationally representative U.S. sample (NHANES) | 1999–2012 | 3
Study without confirmatory testing –NHANES | Kit 2012^15^ Good U.S. | 16,116 | Cross-sectional | NR | 6–19 | 47.8%–51.3% (range across time periods) | Sample weights were used to obtain prevalence estimates representative of the civilian noninstitutionalized U.S. population | Nationally representative U.S. sample (NHANES) | 1988–1994, 1999–2002, 2007–2010 | 3
Study without confirmatory testing –NHANES | CDC 2010^56^ Good U.S. | 3,125 | Cross-sectional | NR | 12–19 | 48% | Sample weights were used to obtain prevalence estimates representative of the civilian noninstitutionalized U.S. population | Nationally representative U.S. sample (NHANES) | 1999–2006 | 3
Study without confirmatory testing –NHANES | Ford 2009^55^ Good U.S. | 9,868^*^ | Cross-sectional | NR | 6–17^*^ | 49.7%^*^ | Sample weights were used to obtain prevalence estimates representative of the civilian noninstitutionalized U.S. population | Nationally representative U.S. sample (NHANES) | 1999–2006 | 3
Studies without confirmatory testing – other large U.S. studies | Margolis 2014^58^ Fair U.S. | 29,360 | Cross-sectional | NR^†^ | 3–19 | 52.4% | Girls (n=15,404):; - White: 38.8%; - Asian: 6.5%; - Black: 9.9%; - Hispanic: 19.8%; - Other: 1.5%; - Missing: 23.5%; (male distribution comparable) | Children and adolescents with ≥1 visit during the study period in 3 large U.S. health systems | 2007–2010 | 3
Studies without confirmatory testing – other large U.S. studies | CARDIAC Ice 2011^7^ Ritchie 2010^57^ Fair U.S. (WV) | 23,263 | Cross-sectional | 10.84 (0.76) | NR | 53.2% | 93% Caucasian 2% Biracial 3% Black <1% each Asian, Hispanic, and other | Fifth-grade students in all 55 counties of West Virginia, CARDIAC Project | 2003– 2008 | 3

* Represents population for whom TC data were available. The article also includes LDL-C data on 2,724 adolescents ages 12–17 years (48.6% female).

† This study does not report mean age. The age distribution for the cohort is: 3–5 y: 2.7%; 6–8 y: 6.8%; 9–11 y: 15.4%; 12–16 y: 41.7%; 17–19 y: 33.4%.58

Abbreviations: SD=standard deviation, OH=Ohio, NR=not reported, NHANES=National Health and Nutrition Examination Survey; WV=West Virginia, CARDIAC=Coronary Artery Risk Detection in Appalachian Communities.

Table 4 Included Treatment Studies

Study, year Quality Country | N | Study design | Age, years Mean (SD) | Age range | % Female | Race | Population and setting | Dates of data collection | Included for key question(s)
Wong 2013^60^ Fair Canada | 32 | Randomized, controlled trial | IG: 13 (2) CG: 13 (3) | 8–18 | 46.9% | NR | Children receiving care at a specialty lipid clinic. Inclusion criteria: fasting serum LDL-C levels of 135–193 mg/dL, first-degree family history of hypercholesterolemia or premature atherosclerotic cardiovascular disease, and compliance with the National Cholesterol Education Program Step II diet. | 2009–2010 | 6
DISC 1993^61^ DISC 1995^62^ Obarzanek 1997^67^ Lavigne 1999^68^ Obarzanek 2001^63^ Dorgan 2011^64^ Good U.S. | 663 | Randomized, controlled trial | Boys: 9.7 Girls: 9.0 | 8–10 | 45.4% | White: 86.6%^*^ Black: 8.4%^*^ Other: 5.0%^*^ | Prepubertal boys and girls ages 8–10 years with LDL-C levels ≥80th percentile and <98th percentile for age and sex. Participants were recruited from public and private elementary schools, health plans, and physician offices. | 1987–2008 | 6^61-64^ 7^62-64, 67, 68^

* Values taken from population described in DISC 1993 article.61

Abbreviations: SD=standard deviation, IG=intervention group, CG=control group, NR=not reported, LDL-C=low-density lipoprotein cholesterol, DISC=Dietary Intervention Study in Children.

Table 5 Included Association Study

Author, Year Quality Country | N | % Female | Age Mean (SE) Age range | Race/Ethnicity % (SE) | Outcomes measured | Baseline lipid values Mean (SE) | Study design Followup period
Saydah 2013^70^ Good U.S. | 9,245 | 50.4% | 26.1 (0.17) 12–39 | Non-Hispanic white: 77.2% (1.19) Non-Hispanic black: 14.7% (0.98) Mexican American: 8.1% (0.76) | Death before age 55 years from all causes Death before age 55 years from endogenous causes | Total cholesterol: 182.0 (0.82) HDL cholesterol: 50.4 (0.37) Non-HDL cholesterol: 131.6 (0.90) | Prospective study of NHANES participants 12–18 years of followup (1988–1994 to 2006)

Abbreviations: SD=standard deviation, SE=standard error, NHANES=National Health and Nutrition Examination Survey.

Table 6 Screening Study of Screening for Dyslipidemia in Childhood and Adolescence That Includes Confirmatory Testing (KQ3)

Study, year Quality Country | Number screened Age range | Setting Race/ethnicity | Universal vs. selective | Cut point for screening test | Screen positive N % of screened | Cut point for confirmatory test | Returned for confirmatory test N % of screen positive | PPV^*^ | Diagnostic yield^†^
Garcia 1989^49^ Fair U.S. | 6,500 3–18 | Large pediatric group practice in Ohio Described as white, middle class | Universal | Non-fasting TC ≥200 mg/dL | 552 8.5% | Fasting LDL-C ≥130 mg/dL | 487 88% | 375 77% | 5.8%

* PPV = positive predictive value computed as true positives divided by number who returned for confirmatory test.

† Diagnostic yield = true positives divided by total screened.

Abbreviations: KQ=key question, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, PPV=positive predictive value.

Table 7 Weighted Prevalence of Elevated Total Cholesterol Concentration (≥200 mg/dL) by Sex, Age, Race/Ethnicity, BMI Category, and Family History Among Children and Adolescents in Large U.S. Studies (KQ3)

Type of study | Study, Cohort Quality | N | Age range (years) | Total % (95% CI or SE) | Sex % (95% CI or SE) | Age % (95% CI or SE) | Race/ethnicity % (95% CI or SE) | BMI percentile % (95% CI or SE)
NHANES Studies^*^ | Kit 2015^8^ 2011 to 2012 Good | 1,482 | 8–17 | 7.8 (5.7–10.4) | Boys: 6.6 (4.5–9.1) Girls: 9.0 (5.4–13.8) | 8–12 y: 7.0 (4.4–10.4) 13–17 y: 8.5 (5.2–12.9) | NH white: 7.0 (3.7–11.9) NH black: 10.0 (8.3–11.8) Hispanic: 8.6 (6.0–11.8) NH Asian: 7.5 (3.7–13.1) | 5th to <85th: 7.7 (5.3-10.8) 85th to <95th: 5.8 (2.7–10.9) ≥95th: 9.8 (5.9–15.1)
NHANES Studies^*^ | Kit 2012^15^ 2007 to 2010 Good | 4,205 | 6–19 | 8.1 (6.7–9.5) | Boys: 8.5 (6.7–10.3) Girls: 7.7 (5.9–9.5) | 6–8 y: 7.7 (5.5–9.9) 9–11 y: 9.4 (7.3–11.6) 12–15 y: 6.2 (4.4–8.0) 16–19 y: 9.4 (7–11.8) | NH white: 8.1 (5.9–10.3) NH black: 8.1 (6.2–10) Mexican American: 7.5 (5.1–9.9) | NR
NHANES Studies^*^ | Ford 2009^55^ 1999 to 2006 Good | 9,868 | 6–17 | 9.6 (0.5) | Boys: 8.9 (0.8) Girls: 10.3 (0.6) | 6–11 y: 10.6 (0.8) Boys: 9.3 (1.0) Girls: 12.0 (1.1) 12–17 y: 8.6 (0.5) Boys: 8.4 (0.9) Girls: 8.8 (0.7) | NH white: 9.3 (0.7) Boys: 8.1 (1.1) Girls: 10.6 (0.8) NH black: 11.9 (0.6) Boys: 12.1 (0.8) Girls: 11.7 (0.9) Mexican American: 8.4 (0.5) Boys: 8.7 (0.7) Girls: 8.1 (0.7) | NR
Other studies | Margolis 2014^58^ U.S. health systems 2007–2010 Fair | 29,360 | 3–19 | 8.6 (NR) | Boys: 8.5 (8.0–8.9) Girls: 8.8 (8.4–9.3) | 3–5 y: 5.8 (4.2–7.5) 6–8 y: 8.6 (7.4–9.8) 9–11 y: 10.6 (9.7–11.5) 12–16 y: 7.2 (6.7–7.6) 17–19 y: 9.8 (9.2–10.4) | White: 9.1 (8.6–9.7) Asian: 9.6 (8.4–10.8) Black: 7.6 (6.6–8.6) Hispanic: 8.2 (7.5–8.9) Other: 9.3 (6.6–12.0) Unknown: 8.3 (7.7–9.0) | <85th: 6.7 (6.2–7.1) 85 to <95th: 8.6 (7.8–9.4) ≥95th: 10.7 (10.2–11.3)
Other studies | CARDIAC Ice 2011^7^ WV screening 2003–2008 Fair | 23,263 | NR^†^ | 10.7 (NR) | NR | NR | NR | <85th: 7.5 (NR) 85 to <95th: 11.5 (NR) ≥95th: 16.0 (NR)

* The included publications used data from overlapping cohorts back to 1999. Shown in this table are data only from the nonoverlapping populations.

† This study did not report age range. The study population was fifth graders with a mean age of 10.84 years (standard deviation, 0.76 years).7

Abbreviations: TC=total cholesterol, BMI=body mass index, KQ=key question, NHANES=National Health and Nutrition Examination Survey, CI=confidence interval, SE=standard error, y=years, NH=Non-Hispanic, NR=not reported, CARDIAC=Coronary Artery Risk Detection in Appalachian Communities.

Table 8 Weighted Prevalence of Elevated Low-Density Lipoprotein Cholesterol Concentration (≥130 mg/dL) by Sex, Age, Race/Ethnicity, BMI Category, and Family History Among Children and Adolescents in U.S. Studies (KQ3)

Type of study | Study, Cohort | N^*^ | Age range (years) | Total (%) (95% CI or SE) | Sex (%) (95% CI or SE) | Age category (%) (95% CI or SE) | Race/ethnicity (%) (95% CI or SE) | Prevalence by subgroups: BMI percentile (%) Family history (95% CI or SE)
NHANES studies | Kit 2012^15^ NHANES 2007–2010 | 996 | 12–19 | 7.4 (5.4–9.4) | Boys: 7.3 (4.5–10.1) Girls: 7.6 (5.3–9.9) | 12–15 y: 5.6 (3.2–8.1) 16–19 y: 9.3 (6.4–12.1) | NH white: 7.8 (4.7–11) NH black: 9.2 (5.0–13.4) Mexican American: 5.3 (2.3–8.4) | NR
NHANES studies | CDC 2010^56^ NHANES 1999–2006 | 3,125 | 12-19 | 7.5 (NR) | Boys: 8.4 (6.4–11.0) Girls: 6.8 (5.1–9.0) | 12–13 y: 7.3 (5.0–10.6) 14–15 y: 6.9 (4.4–10.6) 16–17 y: 5.2 (3.4–8.0) 18–19 y: 11.4 (8.3–15.5) | NH white: 7.7 (5.9–10.0) NH black: 8.9 (7.3–10.8) Hispanic: 5.4 (4.1–7.0) | BMI: <5th to <85th: 5.8 (4.3–7.8) 85th to <95th: 8.4 (5.4–12.8) ≥95th: 14.2 (10.2–19.6)
NHANES studies | Ford 2009^55^ NHANES 1999–2006 | 2,724 | 12–17 | 6.6 (0.6) | Boys: 7.3 (1.1) Girls: 5.8 (0.8) | NR | NH white: 6.4 (1.0) Boys: 7.7 (1.7) Girls: 5.1 (1.3) NH black: 8.1 (1.0) Boys: 8.5 (1.1) Girls: 7.6 (1.5) Mexican American: 6.2 (0.9) Boys: 6.5 (1.1) Girls: 5.9 (1.1) | NR
Other studies | CARDIAC Ritchie 2010^57^ Ice 2011^7^ WV screening program 2003–2008 | 23,263 | NR^†^ | 8.7 (NR) | NR | NR | NR | BMI:^‡^; - <85th: 6.0 (NR); - 85 to <95th: 10.2 (NR); - ≥95th: 12.9 (NR); Family history:^§^; - Yes: 8.3 (NR); - No: 9.5 (NR)
Other studies | Margolis 2014^58^ U.S. health systems 2007–2010 | 9,750 | 3–19 | 8.0 | Boys: 7.8 (7.0–8.6) Girls: 8.2 (7.5–9.0) | 3–5 y: 6.8 (1.6–12.1) 6–8 y: 7.4 (4.8–9.9) 9–11 y: 8.1 (6.6–9.7) 12–16 y: 7.6 (6.7–8.4) 17–19 y: 8.5 (7.7–9.3) | White: 8.4 (7.7–9.2) Asian: 8.5 (5.7–11.3) Black: 6.9 (5.2–8.6) Hispanic: 6.8 (5.6–7.9) Other: 10.3 (5.8–14.8) Unknown: 8.5 (7.1–9.8) | BMI: <85th: 5.6 (5.0–6.3) 85 to <95th: 9.1 (7.7–10.6) ≥95th: 10.4 (9.4–11.4)

* N reflects people with fasting lipid levels; may differ from overall number of observations reported in Table 3 and Table 7.

† This study did not report age range. The study population was fifth graders with a mean age of 10.84 years (standard deviation, 0.76 years).7

‡ BMI data are reported in Ice 2011.

§ Family history data are reported in Ritchie 2010. Family history refers to first- or second-degree relative with premature cardiovascular or hypercholesterolemia.

Abbreviations: LDL-C=low-density lipoprotein cholesterol, BMI=body mass index, KQ=key question, NHANES=National Health and Nutrition Examination Survey, CI=confidence interval, SE=standard error, y=years, NH=Non-Hispanic, NR=not reported, CARDIAC=Coronary Artery Risk Detection in Appalachian Communities.

Table 9 Simulated Diagnostic Yield for Total Cholesterol as a Screening Test for Dyslipidemia in Children and Adolescents, by Subgroups Based on Age and BMI, Using Estimates From Two Large U.S. Studies (KQ3)

Study, Cohort | Age (years) and BMI subgroups | | Screen positive, single test (%) | 95% CI lower | 95% CI upper | Estimated diagnostic yield^*^at 77% PPV
Kit 2015^8^ NHANES 2011–2012 | 8–12 | | 7.0 | 4.4 | 10.4 | 5.4
Kit 2015^8^ NHANES 2011–2012 | 13–17 | | 8.5 | 5.2 | 12.9 | 6.5
Kit 2012^15^ NHANES 2007–2010 | 6–8 | | 7.7 | 5.5 | 9.9 | 5.9
Kit 2012^15^ NHANES 2007–2010 | 9–11 | | 9.4 | 7.3 | 11.6 | 7.2
Kit 2012^15^ NHANES 2007–2010 | 12–15 | | 6.2 | 4.4 | 8.0 | 4.8
Kit 2012^15^ NHANES 2007–2010 | 16–19 | | 9.4 | 7.0 | 11.8 | 7.2
Ice 2011^7^ West Virginia screening program CARDIAC 2003–2008 | NR^†^ | <85th percentile | 7.5 | NR | NR | 5.8
Ice 2011^7^ West Virginia screening program CARDIAC 2003–2008 | NR^†^ | 85th to <95th percentile | 11.5 | NR | NR | 8.9
Ice 2011^7^ West Virginia screening program CARDIAC 2003–2008 | NR^†^ | ≥95th percentile | 16.0 | NR | NR | 12.3

* Diagnostic yield calculated as true positives/number screened. True-positive rate was not available for these studies as no confirmatory tests were done, so this column represents an estimated diagnostic yield based on the one included study that included a confirmatory test and had a PPV of 77%.49

† This study did not report age range. The study population was fifth graders with a mean age of 10.84 years (standard deviation, 0.76 years).7

Abbreviations: NHANES=National Health and Nutrition Examination Survey, BMI=body mass index, CI=confidence interval, PPV=positive predictive value, CARDIAC=Coronary Artery Risk Detection in Appalachian Communities, NR=not reported.

Table 10 Effect of Dietary Intervention on Total and Low-Density Lipoprotein Cholesterol in Children and Adolescents: Results of the Dietary Intervention Study in Children (DISC) at Five Time Points (KQ6)^*^

Time point | Intervention in preceding time period | N^†^ | Age, years mean (SD) | Adherence (attendance at visits) | TC mean (SD) | TC adjusted mean difference^‡^ (95% CI) | LDL-C mean(SD) | LDL-C adjusted mean difference^‡^ (95% CI)
Baseline | -- | IG: 334 CG: 329 | IG: 9.5 (0.74) CG: 9.5 (0.70) | -- | IG: 200 (14.6) CG: 200 (14.6) | -- | IG: 130.6 (12.2) CG: 130.5 (11.6) | --
Year 1 | 0 to 6 months: 6 weekly, then 5 biweekly group sessions and 2 individual sessions with nutritionist 7 months to 1 year: 4 group and 2 individual sessions | IG: 315 CG: 303 | NR | 6 mo: 96% 12 mo: 91% | IG: 191.4 (20.9) CG: 197.4 (21.4) | -6.1 (-9.1 to 3.2) p<0.001 | IG: 122.6 (18.2) CG: 127.2 (19.4) | -4.8 (-7.4 to -2.2) p<0.001
Year 3 | Years 2 and 3: group and individual maintenance sessions 4 to 6 times per year, with monthly phone contact | IG: 320 CG: 303 | NR | 89% | IG: 183.3 (21.5) CG: 186.4 (22.3) | -3.3 (-6.4 to -0.2) p=0.04 | IG: 115.3 (18.7) CG: 118.8 (19.4) | -3.3 (-6.0 to -0.6) p=0.02
Year 5 | Years 4–7: 2 group events and 2 individual visits annually, phone contact as needed | IG: 268 CG: 254 | NR | 72% | IG: 175.6 (22.4) CG: 177.9 (25.7) | -2.6 (-6.3 to 1.2) p=0.18 | IG: 109.8 (NR) CG: 112.2 (NR) | -2.7 (NR) p=0.11
Year 7 | NR | IG: 283 CG: 265 | IG: 17.0 (0.88) CG: 17.0 (0.93) | 1.3 mean contacts per year | IG: 179.4 (24.1) CG: 180.1 (26.3) | -1.1 (-5.0 to 2.8) p=0.59 | IG: 114.1 (NR) CG: 115.9 (NR) | -2.0 (NR) p=0.25
Year 18 | none | 230 women^§^ IG: 118 CG: 112 | IG: 27.3 (1.0) CG: 27.2 (1.1) | N/A | NR | NR | IG: 119.9 (27.8) CG: 118.1 (24.3) | NR^**^

* Data in this table come from four articles about the DISC trial: DISC 1993,^61^ DISC 1995,^62^ Obarzanek 2001,^63^ and Dorgan 2011.^64^

† 663 children were randomized. All analyses through year 7 were conducted as intent-to-treat. Numbers of participants assessed at each time point are shown in this column.

‡ Year 1, 3, and 5 outcomes were adjusted for baseline value and sex. Outcomes at year 7 were adjusted for baseline value, sex, and age at year 7. Adjusted mean difference for TC and LDL-C were not reported at year 18.

§ 230 women who had participated in the DISC trial as children were recruited for a followup assessment 9 years after the termination of the DISC trial. 260 (86.4%) of the 301 females originally randomized were screened; 30 were excluded due to pregnancy or breastfeeding.

** Adjusted mean difference not reported. P-value testing difference between LDL-C means reported p=0.62 (not significant).

Abbreviations: DISC=Dietary Intervention Study in Children, KQ=key question, SD=standard deviation, TC=total cholesterol, CI=confidence interval, LDL-C=low- density lipoprotein cholesterol, IG=intervention group, CG=control group, mo=month, NR=not reported, N/A=not applicable.

Table 11 Effect of Dietary Supplement on Lipid Levels in Children and Adolescents (KQ6)

Author, Year Quality Country | N (IG/CG) % Female | Age (y), Mean (SD) Range | Treatment RCT duration | | TC | LDL-C | HDL-C | Triglycerides
Wong 2013^60^ Fair Canada | 32 (16/16) 46.9% | IG: 13 (2) CG: 13 (3) 8–18 | Flaxseed supplementation 4 weeks | Baseline lipid concentrations Mean (SD) | IG: 214 (25) CG:202 (34) | IG: 141 (22) CG: 134 (27) | IG: 53 (12) CG: 44 (12) | IG: 104 (39) CG: 119 (54)
Wong 2013^60^ Fair Canada | 32 (16/16) 46.9% | IG: 13 (2) CG: 13 (3) 8–18 | Flaxseed supplementation 4 weeks | Relative difference (% change) in intervention group compared to control group Mean (95% CI) P value | -4% (-10% to 2%) 0.20 | -5% (-12% to 2%) 0.15 | -15% (-24% to -6%) 0.001 | 26% (4% to 48%) 0.02

Abbreviations: KQ=key question, IG=intervention group, CG=control group, y=year, RCT=randomized, controlled trial, SD=standard deviation, TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, CI=confidence interval.

Table 12 Harms of Dietary Intervention on Total and Low-Density Lipoprotein Cholesterol in Children and Adolescents (KQ7)

Author, Year Quality | N IG/CG % Female | Adverse effects assessed systematically | Adverse effects reported | Unexpected benefits
DISC, 1995^62^ Obarzanek 1997^67^ Lavigne 1999^68^ Obarzanek 2001^63^ Dorgan 2011^64^ Good | 663 334/329 45.4% | All time points (baseline, years 1, 3, 5, and 7^*^):; - Anthropometric measures: height, weight, BMI; - Dietary assessment: 24-hour recall; Baseline, years 1, 3, and 7^*^ only:; - Laboratory studies: ferritin, retinol, zinc, red blood cell folate; Baseline, years 1, 3, and 5 only:; - Clinical: Tanner staging; Baseline, years 1 and 3 only:; - Laboratory studies: albumin, beta carotene, hemoglobin, vitamin E, copper, tocopherol; - Clinical: blood pressure; - Anthropometrics: skinfold thickness, waist circumference; Baseline and year 3 only:; - Psychosocial: various instruments^†^, history of anorexia, bulimia, suicidality; Year 5 and 7^*^ only: age at menarche | No significant differences between treatment groups reported | Compared to control group, intervention group had improved depression score at year 3 (lower adjusted mean score on Child Depression Inventory) p=0.31
DISC, 1995^62^ Obarzanek 1997^67^ Lavigne 1999^68^ Obarzanek 2001^63^ Dorgan 2011^64^ Good | 230 118/112 100% | Year 18^‡^ (posttrial year 9):; - Anthropometric measures: height, weight, BMI, waist circumference; - Clinical: blood pressure; - Laboratory studies: fasting glucose, adiposity (DXA scan); - Dietary assessment: 24-hour recall | No significant differences between treatment groups reported | Compared to control group, intervention group had:; - Lower mean systolic blood pressure (p=0.03); - Lower mean fasting plasma glucose (p=0.01); - Lower mean VLDL (p=0.07)

* “Year 7” refers to the final followup visit in the original study (1997); actual time since enrollment ranged from 7 to 9 years.

† Instruments include: Achenbach Child Behavior Checklist, Spielberger State-Trait Anxiety Inventory for Children, Kovacs Child Depression Inventory, Family Environment Scale (Moos), and Woodcock-Johnson Psycho-Educational Battery.

‡ “Year 18” refers to the followup study performed in 2006–2008 (approximately 18 years following original enrollment of study subjects in 1988–1990).

Abbreviations: TC=total cholesterol, LDL-C=low-density lipoprotein cholesterol, KQ=key question, DISC=Dietary Intervention Study in Children, IG=intervention group, CG=control group, BMI=body mass index, DXA=dual-energy x-ray absorptiometry, VLDL=very low-density lipoprotein cholesterol.

Table 13 Association^*^ Between Elevated Total and Non–High-Density Lipoprotein Cholesterol and Risk for Death Before Age 55 Years From All and Endogenous Causes Among Participants Ages 12 to 39 Years During NHANES III, With Followup From 1988–2006 (KQ8)70

| Males | | Females
| Risk of death before age 55 (all cause)^†^ RH (95% CI) | Risk of death before age 55 (endogenous causes)^†^ RH (95% CI) | Risk of death before age 55 (all cause)^†^ RH (95% CI) | Risk of death before age 55 (endogenous)^†^ RH (95% CI)
Total cholesterol ≥200 mg/dL | (reference) | (reference) | (reference) | (reference)
200–239 mg/dL | 0.75 (0.42–1.37) | 0.71 (0.34–1.51) | 1.39 (0.71–2.70) | 0.77 (0.36–1.62)
≥240 mg/dL | 0.83 (0.32–2.14) | 1.01 (0.36–2.85) | 2.46 (1.31–4.65) | 2.58 (1.31–5.08)
Non-HDL cholesterol ≥130 mg/dL | (reference) | (reference) | (reference) | (reference)
130–144 mg/dL | 2.03 (0.98–4.23) | 2.00 (0.81–4.92) | 0.72 (0.20–2.59) | 0.46 (0.10–2.14)
≥144 mg/dL | 1.10 (0.64–1.91) | 0.85 (0.42–1.71) | 2.00 (1.11–3.62) | 1.95 (0.97–3.90)

* Associations are expressed as relative hazards. Proportional hazards models for each variable separately with age as the time scale adjusted for race/ethnicity and history of chronic disease (self-report of cardiovascular disease, diabetes, and/or cancer).

† Other variables measured: blood pressure and cotinine levels. Variables with statistically significant relationships with all-cause death: males (none); females (blood pressure, hypertension, and cotinine levels 10–99 ng/mL and ≥100 ng/mL). Variables with statistically significant relationships with endogenous causes of death: males: (none); females (blood pressure, hypertension, and cotinine levels 10–99 ng/mL and ≥100 ng/mL).

Abbreviations: TC=total cholesterol, HDL-C=high-density lipoprotein cholesterol, NHANES=National Health and Nutrition Examination Survey, KQ=key question, RH=relative hazard, CI=confidence interval.

Table 14 Summary of Evidence Table

Key question | Studies (k), Observations (n) | Design | Major limitations | Consistency | Applicability | Overall quality | Summary of findings
KQ1 (screening & health outcomes) | No studies | N/A | N/A | N/A | N/A | N/A | N/A
KQ2 (screening & intermediate outcomes) | No studies | N/A | N/A | N/A | N/A | N/A | N/A
KQ3 (screening diagnostic yield) | k=4 (8 publications) n=78,792^*^ | Cross-sectional | In non-NHANES studies, populations were almost exclusively white. Only 1 study included confirmatory testing (n=6,500); all others used a single test so true diagnostic yield is not available | Taken together, the results are internally consistent. | All studies were conducted in U.S. settings. 2 were in U.S. primary care settings and are most directly applicable. 1 study was conducted in a school-based setting and is likely relevant to primary care. NHANES data may not have direct relevance to primary care. | Fair | The 1 study that included confirmatory testing found a diagnostic yield of 5.8%. Data from studies using a single test found simulated diagnostic yields of 4.8% to 12.3%.
KQ4 (screening harms) | No studies | N/A | N/A | N/A | N/A | N/A | N/A
KQ5 (treatment in childhood & health outcomes) | No studies | N/A | N/A | N/A | N/A | N/A | N/A
KQ6 (treatment in childhood & intermediate outcomes) | k=2 (5 publications) n=695 | RCT Longitudinal followup of 1 trial cohort to 18 years post-randomization | In the larger study (diet), the cutoffs used to define dyslipidemia were lower than our criteria. The smaller study (flaxseed) had a small sample size (n=32) and was limited to a high-risk population in a tertiary care setting. | N/A – different interventions | The diet study is likely applicable to a U.S. setting if the relatively high intensity of dietary counseling could be replicated in primary care. The flaxseed study has limited applicability to a primary care setting. | Fair | The diet study found lower LDL-C and TC levels at 1 and 3 year followup in the intervention group. On longitudinal followup of the trial cohort, the treatment effects were attenuated. The study of flaxseed supplementation found no effect at 4 weeks on lipid levels.
KQ7 (treatment harms) | k=1 (5 publications) n=663 | RCT Longitudinal followup of trial cohort to 18 years post-randomization | Cutoffs used to define dyslipidemia were lower than our criteria. | N/A – 1 study | The DISC study is likely applicable to a U.S. setting if the relatively high intensity of family counseling could be replicated in primary care. | Fair | No harms reported at any time point during the trial or on long-term followup for anthropometric, laboratory, psychosocial, or maturation measures.
KQ8 (association: childhood intermediate outcomes & adult health outcomes) | k=1 n=9,245 | Longitudinal analysis of NHANES data | Outcomes on children within the total study population (ages 12–39 years) were not reported separately. | N/A – 1 study | NHANES data may not have direct relevance to primary care. | Fair | At followup, 283 people were deceased before age 55 years. Leading causes of death for people ages 12–19 years at baseline were accident, self-inflicted injury, circulatory causes, and cancer. In multivariate models, neither very high cholesterol (TC ≥240 mg/dL) nor moderately increased TC (200–239 mg/dL) was independently associated with death, when both sexes were combined. For females only, very high cholesterol was associated with greater risk of death before age 55 years (RH, 2.58 [95% CI, 1.31 to 5.08]).

* N=78,792 is an estimate, as the four NHANES publications included for KQ3 have overlapping populations.

Abbreviations: KQ=key question, N/A=not applicable, NHANES=National Health and Nutrition Examination Survey, RCT=randomized, controlled trial, LDL-C=low-density lipoprotein cholesterol, TC=total cholesterol, DISC=Dietary Intervention Study in Children, RH=relative hazard, CI=confidence interval.

## Expert Review and Public Comment

A draft research plan that included the analytic framework, KQs, and inclusion/exclusion criteria was available for public comment from January 23, 2014 to February 19, 2014. This draft research plan was broadly focused on dyslipidemia in childhood and adolescence, not specifically on FH. As a result of public comment, we decided to conduct two complementary reviews: screening for FH and screening for multifactorial dyslipidemia in children and adolescents. The final version of the research plan was posted in January 2015. The draft version of this report was reviewed by four invited content experts, as well as federal partners from the Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, National Institutes of Health, Veteran's Health Administration, and the Military Health Service. We compiled and addressed comments received during this time, as appropriate. Additionally, a draft of the full report was posted on the USPSTF's Web site from December 22, 2015 to January 25, 2016. A few comments were received during this public comment period; there were no changes made to the report based on these comments.

## USPSTF Involvement

The authors worked with USPSTF liaisons to refine the inclusion criteria, address methodological decisions on applicable evidence, and resolve issues around scope for the final evidence synthesis. AHRQ funded this research under a contract to support the work of the USPSTF. AHRQ staff oversaw the project and assisted in external review of the draft evidence report. AHRQ was not involved in study selection, quality assessment, or synthesis.