# Excluded Studies

Code^*^ | Reason for Exclusion
E1 | Not English
E2 | Not original research in a peer-reviewed journal
E4 | Ineligible SETTING (a) non-generalizable to primary care; (b) low HDI country
E5 | Ineligible POPULATION
E6 | Ineligible OUTCOMES
E7 | Ineligible screening strategy
E8 | Ineligible treatment
E9 | Ineligible study design
E10 | Study rated as poor quality
E11 | Overlapping study population
E12 | N/A

* The exclusion code E3 was not used.

Abbreviations: HDI=Human Development Index, N/A=not applicable.

1 Abe Y, Okada T, Sugiura R, et al. Reference ranges for the non-high-density lipoprotein cholesterol levels in Japanese children and adolescents. J Atheroscler Thromb. 2015;22(7):669-75. KQ3E6. [pmid: 25739922].
2 Abello F, Cagliero P, Giorgis M, et al. Lycopene supplementation in children affected by primary dyslipidaemia: Effects on lipid profile and oxidative stress. High Blood Press Cardiovasc Prev. 2012;2:94. KQ6E13, KQ7E13.
3 Agirbasli M, Agaoglu NB, Orak N, et al. Sex hormones, insulin resistance and high-density lipoprotein cholesterol levels in children. Horm Res Paediatr. 2010;73(3):166-74. KQ3E4, KQ4E4. [pmid: 20197668].
4 Akdim F, Tribble DL, Flaim JD, et al. Efficacy of apolipoprotein B synthesis inhibition in subjects with mild-to-moderate hyperlipidaemia. Eur Heart J. 2011;(21):2650-9. KQ6E5, KQ7E5. [pmid: 21593041].
5 Akyurek N, Atabek ME, Eklioglu BS, et al. Is there a relationship between cardiovascular risk factors and dehydroepiandrosterone sulfate levels in childhood obesity?. J Pediatr Endocrinol Metab. 2014;28(42130):545-50. KQ1E13, KQ2E13, KQ3E5, KQ4E5, KQ5E13. [pmid: 25381943].
6 Alavian SM, Motlagh ME, Ardalan G, et al. Hypertriglyceridemic waist phenotype and associated lifestyle factors in a national population of youths: CASPIAN Study. J Trop Pediatr. 2008;54(3):169-77. KQ3E4. [pmid: 18156644].
7 Ali MK, Bullard KM, Beckles GL, et al. Household income and cardiovascular disease risks in U.S. children and young adults: analyses from NHANES 1999-2008. Diabetes Care. 2011;34(9):1998-2004. KQ3E6. [pmid: 21868776].
8 Amundsen AL, Ose L, Nenseter MS, et al. Plant sterol ester-enriched spread lowers plasma total and LDL cholesterol in children with familial hypercholesterolemia. Am J Clin Nutr. 2002;(2). KQ1E5, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 12145004].
9 Andersen GE, Brokhattingen K, Lous P. Familial hypobetalipoproteinaemia in 9 children diagnosed as the result of cord blood screening for hypolipoproteinaemia in 10,000 Danish newborns. Arch Dis Child. 1979;54(9):691-4. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 229774].
10 Andersen GE, Lous P, Friis-Hansen B. Screening for hyperlipoproteinemia in 10,000 Danish newborns. Follow-up studies in 522 children with elevated cord serum VLDL-LDL-cholesterol. Acta Paediatr Scand. 1979;68(4):541-5. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 223372].
11 Andersen GE, Nielsen HG. Neonatal screening for hyperlipoproteinemia. Methods for direct estimation of cord serum VLDL + LDL. Clin Chim Acta. 1976;66(1):29-41. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 177231].
12 Andersen LB, Riddoch C, Kriemler S, et al. Physical activity and cardiovascular risk factors in children. Br J Sports Med. 2011;45(11):871-6. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21791456].
13 Andersen LB, Wedderkopp N, Hansen HS, et al. Biological cardiovascular risk factors cluster in Danish children and adolescents: the European Youth Heart Study. Prev Med. 2003;37(4):363-7. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 14507494].
14 Andrade S, Borges N. Effect of fermented milk containing Lactobacillus acidophilus and Bifidobacterium longum on plasma lipids of women with normal or moderately elevated cholesterol. J Dairy Res. 2009;76(4):469-74. KQ6E5, KQ7E5. [pmid: 19825213].
15 Arca M, Cambuli VM, Montali A, et al. Serum adiponectin is decreased in patients with familial combined hyperlipidemia and normolipaemic relatives and is influenced by lipid-lowering treatment. Nutr Metab Cardiovasc Dis. 2009;19(9):660-6. KQ6E5, KQ7E5. [pmid: 19632099].
16 Asgary S, Kelishadi R, Rafieian-Kopaei M, et al. Investigation of the lipid-modifying and antiinflammatory effects of Cornus mas L. supplementation on dyslipidemic children and adolescents. Pediatr Cardiol. 2013;34(7):1729-35. KQ6E4, KQ7E4. [pmid: 23625305].
17 Avis HJ, Vissers MN, Wijburg FA, et al. The use of lipid-lowering drug therapy in children and adolescents. Curr Opin Investig Drugs. 2009;10(3):224-31. KQ6E9, KQ7E9. [pmid: 19333879].
18 Bachman RP, Schoen EJ, Stembridge A, et al. Compliance with childhood cholesterol screening among members of a prepaid health plan. Am J Dis Child. 1993;147(4):382-5. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 8456792].
19 Backes JM, Gibson CA, Ruisinger JF, Moriarty PM. The high-dose rosuvastatin once weekly study (the HD-ROWS). J Clin Lipidol. 2012;6(4):362-7. KQ6E5, KQ7E5. [pmid: 22836073].
20 Ballantyne CM, Miller M, Niesor EJ, et al. Effect of dalcetrapib plus pravastatin on lipoprotein metabolism and high-density lipoprotein composition and function in dyslipidemic patients: results of a phase IIb dose-ranging study. Am Heart J. 2012;163(3):515-21. 521 e1. 3. KQ6E5, KQ7E5. [pmid: 22424025].
21 Ballantyne C, Gleim G, Liu N, et al. Effects of coadministered extended-release niacin/laropiprant and simvastatin on lipoprotein subclasses in patients with dyslipidemia. J Clin Lipidol. 2012;6(3):235-43. KQ6E5, KQ7E5. [pmid: 22658147].
22 Baloch S, Devrajani B, Baloch M, et al. Lipid profile in children with coronary artery disease in Sindh, Pakistan. World J Cardiol. 2014;6(7):671-4. KQ8E4. [pmid: 25068027].
23 Bangert SK, Eldridge PH, Peters TJ. Neonatal screening for familial hypercholesterolaemia by immunoturbidimetric assay of apolipoprotein B in dried blood spots. Clin Chim Acta. 1992;213(42007):95-101. KQ3E13. [pmid: 1477991].
24 Barra S, Cuomo V, Silvestri N, et al. Lipoprotein(a) concentration does not differ between sexes in healthy offspring of patients with premature myocardial infarction. J Cardiovasc Med (Hagerstown). 2011;12(7):482-6. KQ3E5, KQ4E5. [pmid: 21519277].
25 Bassols J, Prats-Puig A, Gispert-Sauch M, et al. Increased serum IgG and IgA in overweight children relate to a less favourable metabolic phenotype. Pediatr Obes. 2013;9(3):232-8. KQ3E6. [pmid: 23554403].
26 Bastida S, Perea S, Sanchez-Muniz FJ. Do neonates with high serum cholesterol levels have a different high density lipoprotein composition?. Eur J Pediatr. 1998;157(1):66-70. KQ3E13. [pmid: 9461367].
27 Bastida S, Sanchez-Muniz FJ, Cuena R, et al. High density lipoprotein-cholesterol changes in children with high cholesterol levels at birth. Eur J Pediatr. 2002;161(2):94-8. KQ3E13. [pmid: 11954759].
28 Bays HE, Chapman RH, Grandy S, et al. The relationship of body mass index to diabetes mellitus, hypertension and dyslipidaemia: comparison of data from two national surveys. Int J Clin Pract. 2007;61(5):737-47. KQ3E7. [pmid: 17493087].
29 Bays HE, Maki KC, Doyle RT, Stein E. The effect of prescription omega-3 fatty acids on body weight after 8 to 16 weeks of treatment for very high triglyceride levels. Postgrad Med. 2009;121(5):145-50. KQ6E5, KQ7E5. [pmid: 19820283].
30 Bays HE, Maki KC, McKenney J, et al. Long-term up to 24-month efficacy and safety of concomitant prescription omega-3-acid ethyl esters and simvastatin in hypertriglyceridemic patients. Curr Med Res Opin. 2010;26(4):907-15. KQ6E5, KQ7E5. [pmid: 20156032].
31 Bays HE, Shah A, Lin J, et al. Efficacy and tolerability of extended-release niacin/laropiprant in dyslipidemic patients with metabolic syndrome. J Clin Lipidol. 2010;4(6):515-21. KQ6E5, KQ7E5. [pmid: 21122699].
32 Bays HE, Shah A, Macdonell G, et al. Effects of coadministered ezetimibe plus fenofibrate in mixed dyslipidemic patients with metabolic syndrome. Metab Syndr Relat Disord. 2011;9(2):135-42. KQ6E5, KQ7E5. [pmid: 21117970].
33 Bazzano LA, Thompson AM, Tees MT, et al. Non-soy legume consumption lowers cholesterol levels: a meta-analysis of randomized controlled trials. Nutr Metab Cardiovasc Dis. 2011;21(2):94-103. KQ6E5, KQ7E5. [pmid: 19939654].
34 Becker DJ, French B, Morris PB, et al. Phytosterols, red yeast rice, and lifestyle changes instead of statins: a randomized, double-blinded, placebo-controlled trial. Am Heart J. 2013;166(1):187-96. KQ6E5, KQ7E5. [pmid: 23816039].
35 Becker DJ, Gordon RY, Morris PB, et al. Simvastatin vs therapeutic lifestyle changes and supplements: randomized primary prevention trial. Mayo Clin Proc. 2008;83(7):758-64. KQ6E5, KQ7E5. [pmid: 18613992].
36 Becker M, Staab D, Von Bergmann K. Treatment of severe familial hypercholesterolemia in childhood with sitosterol and sitostanol. J Pediatr. 1993;122(2):292-6. KQ3E13. [pmid: 8429449].
37 Beeso J, Wong N, Ayling R, et al. Screening for hypercholesterolaemia in 10,000 neonates in a multi-ethnic population. Eur J Pediatr. 1999;158(10):833-7. KQ3E13. [pmid: 10486088].
38 Bekkers MB, Brunekreef B, Koppelman GH, et al. BMI and waist circumference; cross-sectional and prospective associations with blood pressure and cholesterol in 12-year-olds. PLoS ONE. 2012;7(12):e51801. KQ3E6. [pmid: 23251628].
39 Belay B, Racine AD, Belamarich PF. For the patient. Disparities in statin trials for children. Ethnicity & Disease. 2009;19(2):218. KQ6E2, KQ7E2. [pmid: 19537236].
40 Bell DA, Hooper AJ, Bender R, et al. Screening for lipid disorders. Pathology. 2012;44(2):115-21. KQ1E13. [pmid: 22198257].
41 Bell L, Davis E, Knuiman M, et al. Lipids in Australian children: cause for concern? 2005-2007 Busselton Health Study. J Paediatr Child Health. 2012;48(10):E172-7. KQ3E7. [pmid: 22998088].
42 Bell L, Hung J, Knuiman M, et al. Body mass index and waist circumference: relationship to cardiometabolic risk factors in children--Busselton Health Study 2005-2007. J Paediatr Child Health. 2013;49(11):955-62. KQ3E6. [pmid: 23802746].
43 Bell MM, Joseph S. Screening 1140 fifth graders for hypercholesterolemia: family history inadequate to predict results. J Am Board Fam Pract. 1990;3(4):259-63. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 2248092].
44 Berenson GS, Srinivasan SR, Frerichs RR, Webber LS. Serum high density lipoprotein and its relationship to cardiovascular disease risk factor variables in children--the Bogalusa heart study. Lipids. 1979;14(1):91-8. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 218070].
45 Bergmann GG, Gaya A, Halpern R, et al. Waist circumference as screening instrument for cardiovascular disease risk factors in schoolchildren. J Pediatr (Rio J). 2010;86(5):411-6. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1. [pmid: 20938592].
46 Bergstrom E, Hernell O, Persson LA. Endurance running performance in relation to cardiovascular risk indicators in adolescents. Int J Sports Med. 1997;18(4):300-7. KQ3E13. [pmid: 9231849].
47 Bibiloni MM, Salas R, Pons A, Tur JA. Prevalence of dyslipidaemia and associated risk factors among Balearic Islands adolescents, a Mediterranean region. Eur J Clin Nutr. 2014;69(6):722-8. KQ3E7, KQ4E6. [pmid: 25351644].
48 Bielemann RM, Ramires VV, Gigante DP, et al. Longitudinal and cross-sectional associations of physical activity with triglyceride and HDLc levels in young male adults. J Phys Act Health. 2013;11(4):784-9. KQ1E13, KQ2E13, KQ3E4, KQ4E13, KQ5E13. [pmid: 23574796].
49 Blades BL, Dudman NP, Wilcken DE. Screening for familial hypercholesterolemia in 5000 neonates: a recall study. Pediatr Res. 1988;(5). KQ3E13. [pmid: 3387172].
50 Bogsrud MP, Ose L, Langslet G, et al. HypoCol (red yeast rice) lowers plasma cholesterol - a randomized placebo controlled study. Scand Cardiovasc J. 2010;44(4):197-200. KQ6E5, KQ7E5. [pmid: 20636227].
51 Boreham CA, Wallace WF, Nevill A. Training effects of accumulated daily stair-climbing exercise in previously sedentary young women. Prev Med. 2000;(4). KQ3E13. [pmid: 10731455].
52 Boulton TJ. The validity of screening for hypercholesterolaemia at different ages from 2 to 17 years. Aust N Z J Med. 1979;9(5):542-6. KQ3E13. [pmid: 231425].
53 Bradlee ML, Singer MR, Moore LL. Lean red meat consumption and lipid profiles in adolescent girls. J Hum Nutr Diet. 2013;(0):292-300. KQ3E13. [pmid: 23663235].
54 Braga MF, Grace MG, Lenis J, et al. Efficacy and safety of ursodeoxycholic acid in primary, type IIa or IIb hypercholesterolemia: a multicenter, randomized, double-blind clinical trial. Atherosclerosis. 2009;(2):479-82. KQ6E5, KQ7E5. [pmid: 18801487].
55 Brewster TG, Waite DJ, Hudson GA. Quantitation of beta-lipoprotein in cord serum by rate nephelometric immunoassay: a potential screening test for familial hypercholesterolemia. Clin Chem. 1982;(5). KQ3E13. [pmid: 7074903].
56 Brogan K, Danford C, Yeh Y, et al. Cardiovascular disease risk factors are elevated in urban minority children enrolled in head start. Childhood Obes. 2014;10(3):207-13. KQ3E7, KQ4E6. [pmid: 24829071].
57 Browne B, Vasquez S. Pediatric dyslipidemias: prescription medication efficacy and safety. J Clin Lipidol. 2008;2(3):189-201. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21291737].
58 Bundy R, Walker AF, Middleton RW, et al. Artichoke leaf extract (Cynara scolymus) reduces plasma cholesterol in otherwise healthy hypercholesterolemic adults: a randomized, double blind placebo controlled trial. Phytomedicine. 2008;(9):668-75. KQ6E5, KQ7E5. [pmid: 18424099].
59 Burgos MS, Burgos LT, Camargo MD, et al. Relationship between anthropometric measures and cardiovascular risk factors in children and adolescents. Arq Bras Cardiol. 2013;101(4):288-96. KQ3E6. [pmid: 23979777].
60 Burke JD, Reilly RA, Morrell JS, et al. The University of New Hampshire's Young Adult Health Risk Screening Initiative. J Am Diet Assoc. 2009;109(10):1751-8. KQ3E5. [pmid: 19782175].
61 Burns TL, Letuchy EM, Paulos R, et al. Childhood predictors of the metabolic syndrome in middle-aged adults: the Muscatine study. J Pediatr. 2009;155(3):S5 e17-26. KQ8E6. [pmid: 19732563].
62 Burr JF, Jamnik V, Gledhill N, et al. A cross-sectional examination of the physical fitness and selected health attributes of recreational all-terrain vehicle riders and off-road motorcyclists. J Sports Sci. 2010;28(13):1423-33. KQ3E6, KQ4E6. [pmid: 20845220].
63 Caballero AE, Bousquet-Santos K, Robles-Osorio L, et al. Overweight Latino children and adolescents have marked endothelial dysfunction and subclinical vascular inflammation in association with excess body fat and insulin resistance. Diabetes Care. 2008;31(3):576-82. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 18083792].
64 Cagliero P, Abello F, Guardamagna O. Effects of bifidobacterium supplementation on plasma lipid profile in dyslipidemic children. High Blood Press Cardiovasc Prev. 2013;20(2):93-114. KQ6E13, KQ7E13.
65 Cagliero P, Marini E, Cena C, et al. The effects of probiotics supplementation on antioxidant activity in children affected by primary hyperlipidemia. High Blood Press Cardiovasc Prev. 2014;21(2):151-169. KQ6E13, KQ7E13.
66 Cai L, Wu Y, Cheskin LJ, et al. Effect of childhood obesity prevention programmes on blood lipids: a systematic review and meta-analysis. Obes Rev. 2014;15(12):933-44. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13, KQ6E6. [pmid: 25263653].
67 Camhi SM, Kuo J, Young DR, et al. Identifying adolescent metabolic syndrome using body mass index and waist circumference. Prev Chronic Dis. 2008;5(4):A115. KQ3E6. [pmid: 18793503].
68 Carson V, Ridgers ND, Howard BJ, et al. Light-intensity physical activity and cardiometabolic biomarkers in US adolescents. PLoS ONE. 2013;8(8):e71417. KQ6E9, KQ7E9. [pmid: 23951157].
69 Carter SJ, Roberts MB, Salter J, et al. Relationship between Mediterranean Diet Score and atherothrombotic risk: findings from the Third National Health and Nutrition Examination Survey (NHANES III), 1988-1994. Atherosclerosis. 2010;210(2):630-6. KQ3E5. [pmid: 20138282].
70 Caserta CA, Pendino GM, Alicante S, et al. Body mass index, cardiovascular risk factors, and carotid intima-media thickness in a pediatric population in southern Italy. J Pediatr Gastroenterol Nutr. 2010;51(2):216-20. KQ2E13, KQ3E7, KQ4E13. [pmid: 20512056].
71 Castro IA, Monteiro VC, Barroso LP, et al. Effect of eicosapentaenoic/docosahexaenoic fatty acids and soluble fibers on blood lipids of individuals classified into different levels of lipidemia. Nutrition. 2007;(2):127-37. KQ6E5, KQ7E5. [pmid: 17234506].
72 Castro JJ, Dias T, Chambel P, et al. A randomized double-blind study comparing the efficacy and safety of orlistat versus placebo in obese patients with mild to moderate hypercholesterolemia. Rev Port Cardiol. 2009;(12):1361-74. KQ6E5, KQ7E5. [pmid: 20301983].
73 Castro PS, Oliveira FL. Prevention of atherosclerosis and drug treatment of high-risk lipid abnormalities in children and adolescents. J Pediatr (Rio J). 2009;85(1). 14-Jun. KQ6E1, KQ7E13. [pmid: 19198733].
74 Cesa CC, Barbiero SM, Petkowicz Rde O, et al. Effectiveness of physical exercise to reduce cardiovascular risk factors in youths: a randomized clinical trial. J Clin Med Res. 2015;7(5):348-55. KQ6E6, KQ7E6. [pmid: 25780484].
75 Cesar TB, Aptekmann NP, Araujo MP, et al. Orange juice decreases low-density lipoprotein cholesterol in hypercholesterolemic subjects and improves lipid transfer to high-density lipoprotein in normal and hypercholesterolemic subjects. Nutr Res. 2010;30(10):689-94. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 21056284].
76 Chahal N, Manlhiot C, Wong H, et al. Effectiveness of Omega-3 Polysaturated Fatty Acids (Fish Oil) Supplementation for Treating Hypertriglyceridemia in Children and Adolescents. Clin Pediatr (Phila). 2014;53(7):645-651. KQ6E5, KQ7E6. [pmid: 24647701].
77 Chahal N, McCrindle B, Manlhiot C, et al. A 4-week randomized clinical trial of flaxseed supplementation in children with hypercholesterolemia. Can J Cardiol. 2011;(5):S339. CN-01003383. KQ6E13, KQ7E13.
78 Chahal N, Wong H, Manlhiot C, et al. Education for lifestyle-based management of hyperlipidemia in children enhanced by a collaborative approach. J Clin Lipidol. 2014;8(2):187-93. KQ6E9, KQ7E6. [pmid: 24636178].
79 Chait R, Ramineni R, Fender EA. Precocious virulent coronary atherosclerosis in the very young. Cardiol Young. 2012;22(2):184-7. KQ8E9. [pmid: 21878143].
80 Chaiton M, O'Loughlin J, Karp I, et al. Depressive symptoms and C-reactive protein are not associated in a population-based sample of adolescents. Int J Behav Med. 2010;17(3):216-22. KQ3E6, KQ4E6. [pmid: 20180088].
81 Chauhan A, Paunikar P. Update on pediatric hyperlipidemia. Curr Opin Pediatr. 2014;26(2):252-8. KQ1E2. [pmid: 24553633].
82 Chen YQ, Zhao SP, Chen JZ, et al. The effects of coenzyme A on serum lipids in patients with hyperlipidemia: results of a multicenter clinical trial. J Clin Endocrinol Metab. 2013;98(2):E275-8. KQ6E5, KQ7E5. [pmid: 23293333].
83 Chikanna S, Upadhyay A, Aneja GK. Lipid profile in high risk children aged 2-10 years. Indian Pediatr. 2010;47(7):630-1. KQ3E9. [pmid: 20683118].
84 Cho SM, Lee SG, Kim HS, et al. Establishing pediatric reference intervals for 13 biochemical analytes derived from normal subjects in a pediatric endocrinology clinic in Korea. Clin Biochem. 2014;47(18):268-71. KQ3E6. [pmid: 25241678].
85 Ciftdogan DY, Coskun S, Ulman C, et al. The association of apolipoprotein E polymorphism and lipid levels in children with a family history of premature coronary artery disease. J Clin Lipidol. 2012;6(1):81-7. KQ3E5, KQ4E5. [pmid: 22264578].
86 Clark J. Does the type intervention method really matter for combating childhood obesity? A systematic review and meta-analysis. J Sports Med Phys Fitness. 2014;(0). KQ6E2. [pmid: 25303076].
87 Clarke JT, Cullen-Dean G, Regelink E, et al. Increased incidence of epistaxis in adolescents with familial hypercholesterolemia treated with fish oil. J Pediatr. 1990;116(1):139-41. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 2295954].
88 Clarke WR, Schrott HG, Leaverton PE, et al. Tracking of blood lipids and blood pressures in school age children: the Muscatine study. Circulation. 1978;58(4):626-34. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 688572].
89 Clauss SB, Holmes KW, Hopkins P, et al. Efficacy and safety of lovastatin therapy in adolescent girls with heterozygous familial hypercholesterolemia. Pediatrics. 2005;(3). KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E5. [pmid: 16140708].
90 Cleanthous X, Noakes M, Brinkworth GD, et al. A pilot comprehensive lifestyle intervention program (CLIP)--comparison with qualitative lifestyle advice and simvastatin on cardiovascular risk factors in overweight hypercholesterolaemic individuals. Nutr Metab Cardiovasc Dis. 2011;21(3):165-72. KQ6E5, KQ7E5. [pmid: 20110160].
91 Clifton PM, Mano M, Duchateau GS, et al. Dose-response effects of different plant sterol sources in fat spreads on serum lipids and C-reactive protein and on the kinetic behavior of serum plant sterols. Eur J Clin Nutr. 2008;62(8):968-77. KQ6E5, KQ7E5. [pmid: 17538539].
92 Colletti RB, Neufeld EJ, Roff NK, et al. Niacin treatment of hypercholesterolemia in children. Pediatrics. 1993;92(1):78-82. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 8516088].
93 Comerford KB, Artiss JD, Jen KL, et al. The beneficial effects of alpha-cyclodextrin on blood lipids and weight loss in healthy humans. Obesity (Silver Spring). 2011;19(6):1200-4. KQ1E5. [pmid: 21127475].
94 Conceicao-Machado ME, Silva LR, Santana ML, et al. Hypertriglyceridemic waist phenotype: association with metabolic abnormalities in adolescents. J Pediatr (Rio J). 2013;89(1):56-63. KQ3E4. [pmid: 23544811].
95 Cook S, Kavey RE. Dyslipidemia and pediatric obesity. Pediatr Clin North Am. 2011;58(6):1363-73. ix. KQ1E13, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 22093856].
96 Corley J, Starr JM, Deary IJ. Serum cholesterol and cognitive functions: the Lothian Birth Cohort 1936. Int Psychogeriatr. 2015. 15-Jan. KQ7E6. [pmid: 25023928].
97 Cottrell L, John C, Murphy E, et al. Individual-, family-, community-, and policy-level impact of a school-based cardiovascular risk detection screening program for children in underserved, rural areas: the CARDIAC Project. J Obes. 2013;2013(0). KQ3E13. [pmid: 23840946].
98 Croyle RT, Sun YC, Louie DH. Psychological minimization of cholesterol test results: moderators of appraisal in college students and community residents. Health Psychol. 1993;12(6):503-7. KQ3E13. [pmid: 8293735].
99 Cunningham TE, Sayers SM, Singh GR, et al. Lipoprotein(a) identifies cardiovascular risk in childhood: the Australian Aboriginal Birth Cohort Study. J Paediatr Child Health. 2011;47(5):257-61. KQ1E13, KQ2E6, KQ3E6, KQ4E6, KQ5E13. [pmid: 21244559].
100 da Luz Giroldo M, Villela Baroncini LA, Champoski AF, et al. Household cardiovascular screening in adolescents from high-risk families. Atherosclerosis. 2013;226(1):286-90. KQ3E4. [pmid: 23195519].
101 D'Adamo E, Guardamagna O, Chiarelli F, et al. Atherogenic dyslipidemia and cardiovascular risk factors in obese children. Int J Endocrinol. 2015;2015(5):912047. KQ1E13, KQ2E2, KQ3E13, KQ4E13, KQ5E13. [pmid: 25663838].
102 Dai S, Eissa MA, Steffen LM, et al. Associations of BMI and its fat-free and fat components with blood lipids in children: Project HeartBeat!. Clin Lipidol. 2011;6(2):235-244. KQ3E6. [pmid: 21818183].
103 Darmady JM, Fosbrooke AS, Lloyd JK. Prospective study of serum cholesterol levels during first year of life. Br Med J. 1972;2(5815):685-8. KQ1E13, KQ2E13, KQ3E7, KQ4E13, KQ5E13. [pmid: 5067674].
104 Davidson DM, Bradley BJ, Landry SM, et al. School-based blood cholesterol screening. J Pediatr Health Care. 1989;3(1). KQ1E13, KQ2E13, KQ3E9, KQ4E13, KQ5E13. [pmid: 2492600].
105 Davidson DM, Van Camp J, Iftner CA, et al. Family history fails to detect the majority of children with high capillary blood total cholesterol. J Sch Health. 1991;61(2):75-80. KQ3E13. [pmid: 2016863].
106 Davidson MH, Dugan LD, Burns JH, et al. A psyllium-enriched cereal for the treatment of hypercholesterolemia in children: a controlled, double-blind, crossover study. Am J Clin Nutr. 1996;63(1):96-102. KQ3E13. [pmid: 8604676].
107 Davison N, Fanolua S, Rosaine M, et al. Assessing overweight and obesity in American Samoan adolescents. Pac Health Dialog. 2007;14(2):55-61. KQ3E4. [pmid: 19588607].
108 de Almeida CA, Pinho AP, Ricco RG, et al. Abdominal circumference as an indicator of clinical and laboratory parameters associated with obesity in children and adolescents: comparison between two reference tables. J Pediatr (Rio J). 2007;83(2):181-5. KQ3E6. [pmid: 17426873].
109 de Freitas RW, de Araujo MF, Lima AC, et al. Study of lipid profile in a population of university students. Rev Lat Am Enfermagem. 2013;21(5):1151-8. KQ3E5, KQ4E5. [pmid: 24142225].
110 De Henauw S, Michels N, Vyncke K, et al. Blood lipids among young children in Europe: results from the European IDEFICS study. Int J Obes (Lond). 2014;(0):S67-75. KQ3E9, KQ4E13, KQ3E6. [pmid: 25219412].
111 de Jongh S, Kerckhoffs MC, Grootenhuis MA, et al. Quality of life. Acta Paediatr. 2003;92(9):1096-101. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 14599077].
112 de Jongh S, Lilien MR, op't Roodt J, et al. Early statin therapy restores endothelial function in children with familial hypercholesterolemia. J Am Coll Cardiol. 2002;40(12):2117-21. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 12505222].
113 de Jongh S, Ose L, Szamosi T, et al. Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized, double-blind, placebo-controlled trial with simvastatin. Circulation. 2002;106(17):2231-7. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 12390953].
114 de Jongh S, Vissers MN, Rol P, et al. Plant sterols lower LDL cholesterol without improving endothelial function in prepubertal children with familial hypercholesterolaemia. J Inherit Metab Dis. 2003;26(4):343-51. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 12971422].
115 de Kroon ML, Renders CM, van Wouwe JP, et al. The Terneuzen Birth Cohort: BMI change between 2 and 6 years is most predictive of adult cardiometabolic risk. PLoS ONE. 2010;5(11):e13966. KQ3E6, KQ4E6. [pmid: 21103047].
116 De Rosa G, Bonaventura A, Bianchi L, et al. A randomized, placebo-controlled study on the effects of a nutraceutical combination of red yeast rice, silybum marianum and octasonol on lipid profile, endothelial and inflammatory parameters. J Biol Regul Homeost Agents. 2014;28(2):317-24. KQ6E5, KQ7E5. [pmid: 25001663].
117 de Ferranti S, Shapiro D, Markowitz R, et al. Nonfasting low-density lipoprotein testing: utility for cholesterol screening in pediatric primary care. Clin Pediatr (Phila). 2007;46(5):441-5. KQ1E6, KQ2E6, KQ3E9, KQ4E13. [pmid: 17556742].
118 Deerochanawong C, Buranakitjaroen P, Nitiyanant W, et al. The Atorvastatin Goal Achievement Across Risk Levels: (ATGOAL) study in Thailand. J Med Assoc Thai. 2007;90(1):72-81. KQ6E5, KQ7E5. [pmid: 17621736].
119 Demerath E, Muratova V, Spangler E, et al. School-based obesity screening in rural Appalachia. Prev Med. 2003;37(6 Pt 1):553-60. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 14636788].
120 Dennison BA, Kikuchi DA, Srinivasan SR, et al. Serum total cholesterol screening for the detection of elevated low-density lipoprotein in children and adolescents: the Bogalusa Heart Study. Pediatrics. 1990;85(4):472-9. KQ1E13, KQ2E13, KQ3E10, KQ4E6, KQ5E13. [pmid: 2314959].
121 Dennison BA, Levine DM. Randomized, double-blind, placebo-controlled, two-period crossover clinical trial of psyllium fiber in children with hypercholesterolemia. J Pediatr. 1993;123(1):24-9. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 8391569].
122 DeStefano F, Berg RL, Griese GG Jr. Determinants of serum lipid and lipoprotein concentrations in children. Epidemiology. 1995;6(4):446-9. KQ3E13. [pmid: 7548360].
123 Di Bonito P, Moio N, Sibilio G, et al. Cardiometabolic phenotype in children with obesity. J Pediatr. 2014;165(6):1184-9. KQ3E5. [pmid: 25241175].
124 Diaz-Rios LK, Chapman-Novakofski K, Malacara JM, et al. Metabolic and nutritional profile differences among Mexican, Mexican-American and Non-Hispanic White children. Rev Invest Clin. 2014;66(1):31-44. KQ3E5, KQ4E4. [pmid: 24762725].
125 Donin AS, Nightingale CM, Owen CG, et al. Ethnic differences in blood lipids and dietary intake between UK children of black African, black Caribbean, South Asian, and white European origin: the Child Heart and Health Study in England (CHASE). Am J Clin Nutr. 2010;92(4):776-83. KQ3E6, KQ4E13. [pmid: 20739425].
126 Doshi N, Perrin EM, Lazorick S, et al. Short-term change in body mass index in overweight adolescents following cholesterol screening. Arch Pediatr Adolesc Med. 2009;163(9):812-7. KQ1E13, KQ2E6, KQ3E6, KQ4E13, KQ5E13. [pmid: 19736334].
127 Douglas MB, Birrer RB, Medidi S, et al. Obese children should be screened for hypercholesterolemia. J Health Care Poor Underserved. 1996;7(1):24-35. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 8645782].
128 Duck MM, Hoffman RP. Impaired endothelial function in healthy African-American adolescents compared with Caucasians. J Pediatr. 2007;150(4):400-6. KQ3E6, KQ4E6. [pmid: 17382119].
129 Dulay D, LaHaye SA, Lahey KA, Day AG. Efficacy of alternate day versus daily dosing of rosuvastatin. Can J Cardiol. 2009;25(2):e28-31. KQ6E5, KQ7E5. [pmid: 19214297].
130 Eiland LS, Luttrell PK. Use of statins for dyslipidemia in the pediatric population. J Pediatr Pharmacol Ther. 2010;15(3):160-72. KQ6E2, KQ7E2. [pmid: 22477808].
131 Eisenmann JC, Laurson KR, DuBose KD, et al. Construct validity of a continuous metabolic syndrome score in children. Diabetol Metab Syndr. 2010;2(0). KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 20181030].
132 Eisenmann JC, Malina RM. Age-related changes in subcutaneous adipose tissue of adolescent distance runners and association with blood lipoproteins. Ann Hum Biol. 2002;29(4):389-97. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 12160472].
133 Eisenmann JC, Welk GJ, Wickel EE, et al. Combined influence of cardiorespiratory fitness and body mass index on cardiovascular disease risk factors among 8-18 year old youth: The Aerobics Center Longitudinal Study. Int J Pediatr Obes. 2007;2(2):66-72. KQ6E5, KQ7E5. [pmid: 17763013].
134 Eisenmann JC, Welk GJ, Wickel EE, et al. Stability of variables associated with the metabolic syndrome from adolescence to adulthood: the Aerobics Center Longitudinal Study. Am J Hum Biol. 2004;16(6):690-6. KQ3E13. [pmid: 15495227].
135 Eissa MA, Wen E, Mihalopoulos NL, et al. Evaluation of AAP guidelines for cholesterol screening in youth: Project HeartBeat!. Am J Prev Med. 2009;37(1 Suppl):S71-7. KQ3E7. [pmid: 19524159].
136 Ekelund U, Luan J, Sherar LB, et al. Moderate to vigorous physical activity and sedentary time and cardiometabolic risk factors in children and adolescents. JAMA. 2012;307(7):704-12. KQ1E13, KQ2E13, KQ3E9, KQ4E13, KQ5E13. [pmid: 22337681].
137 Enger C, Gately R, Ming EE, et al. Pharmacoepidemiology safety study of fibrate and statin concomitant therapy. Am J Cardiol. 2010;(11):1594-601. KQ7E5. [pmid: 21094360].
138 Escalante Y, Saavedra JM, Garcia-Hermoso A, et al. Improvement of the lipid profile with exercise in obese children: a systematic review. Prev Med. 2012;54(5):293-301. KQ6E5, KQ7E5. [pmid: 22387009].
139 European Association for Cardiovascular Prevention & Rehabilitation, Reiner Z, Catapano AL, et al. ESC/EAS Guidelines for the management of dyslipidaemias: the Task Force for the management of dyslipidaemias of the European Society of Cardiology (ESC) and the European Atherosclerosis Society (EAS). Eur Heart J. 2011;32(14):1769-818. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21712404].
140 Faigel HC. Screening college students for hypercholesterolemia. J Am Coll Health. 1992;40(6):272-5. KQ1E13, KQ2E13, KQ3E10, KQ4E13, KQ5E13. [pmid: 1602094].
141 Fazio S, Guyton JR, Polis AB, et al. Long-term safety and efficacy of triple combination ezetimibe/simvastatin plus extended-release niacin in patients with hyperlipidemia. Am J Cardiol. 2010;(4):487-94. KQ6E5, KQ7E5. [pmid: 20152243].
142 Feeman WE Jr. Screening lipids in children. J Clin Lipidol. 2014;8(2):233-4. KQ1E2. [pmid: 24636185].
143 Feldman RD, Flack J, Howes L, et al. Impact of age and gender on blood pressure and low-density lipoprotein cholesterol reduction: results of a pooled analysis. Curr Med Res Opin. 2012;28(9):1421-33. KQ3E5, KQ4E5. [pmid: 22809114].
144 Felszeghy E, Kaposzta R, Juhasz E, et al. Alterations of carbohydrate and lipoprotein metabolism in childhood obesity--impact of insulin resistance and acanthosis nigricans. J Pediatr Endocrinol Metab. 2009;22(12):1117-26. KQ1E5, KQ2E5, KQ3E6, KQ4E5, KQ5E5. [pmid: 20333871].
145 Feoli-Fonseca JC, Levy E, Godard M, et al. Familial lipoprotein lipase deficiency in infancy: clinical, biochemical, and molecular study. J Pediatr. 1998;133(3):417-23. KQ3E13. [pmid: 9738727].
146 Ferguson MA, Gutin B, Le NA, et al. Effects of exercise training and its cessation on components of the insulin resistance syndrome in obese children. Int J Obes Relat Metab Disord. 1999;23(8):889-95. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 10490792].
147 Fernandes J, Lofgren IE. Prevalence of metabolic syndrome and individual criteria in college students. J Am Coll Health. 2011;59(4):313-21. KQ3E6, KQ4E6. [pmid: 21308592].
148 Ferreira WP, Bertolami MC, Santos SN, et al. One-month therapy with simvastatin restores endothelial function in hypercholesterolemic children and adolescents. Pediatr Cardiol. 2007;28(1). 13-Aug. KQ6E4, KQ7E4. [pmid: 17318708].
149 Finucane FM, Teong L, Pittock S, et al. Adverse metabolic profiles in a cohort of obese Irish children. Ann Clin Biochem. 2008;45(Pt 2):206-9. KQ3E13, KQ4E13. [pmid: 18325187].
150 Fisher-Hoch SP, Vatcheva KP, Laing ST, et al. Missed opportunities for diagnosis and treatment of diabetes, hypertension, and hypercholesterolemia in a Mexican American population, Cameron County Hispanic Cohort, 2003-2008. Prev Chronic Dis. 2012;9(0). KQ3E5, KQ4E13. [pmid: 22863308].
151 Flechtner-Mors M, Wiegand S, Gellhaus I, et al. Screening for co-morbidity in 65,397 obese pediatric patients from Germany, Austria and Switzerland: adherence to guidelines improved from the year 2000 to 2010. Obes Facts. 2013;6(4):360-8. KQ2E6. [pmid: 23970145].
152 Flouris AD, Bouziotas C, Christodoulos AD, et al. Longitudinal preventive-screening cutoffs for metabolic syndrome in adolescents. Int J Obes (Lond). 2008;32(10):1506-12. KQ3E6. [pmid: 18698315].
153 Flynn J, Zhang Y, Solar-Yohay S, et al. Clinical and demographic characteristics of children with hypertension. Hypertension. 2012;60(4):1047-54. KQ3E9. [pmid: 22892814].
154 Flynn SE, Gurm R, DuRussel-Weston J, et al. High-density lipoprotein cholesterol levels in middle-school children: association with cardiovascular risk factors and lifestyle behaviors. Pediatr Cardiol. 2013;35(3):507-13. KQ3E6, KQ6E5, KQ7E5. [pmid: 24132620].
155 Flynn SE, Gurm R, DuRussel-Weston J, et al. High-density lipoprotein cholesterol levels in middle-school children: association with cardiovascular risk factors and lifestyle behaviors. Pediatr Cardiol. 2014;35(3):507-13. KQ3E6, KQ4E6. [pmid: 24132620].
156 Foster M, Petocz P, Samman S. Effects of zinc on plasma lipoprotein cholesterol concentrations in humans: a meta-analysis of randomised controlled trials. Atherosclerosis. 2010;210(2):344-52. KQ6E13, KQ7E13. [pmid: 20034629].
157 Franceschini G, Favari E, Calabresi L, et al. Differential effects of fenofibrate and extended-release niacin on high-density lipoprotein particle size distribution and cholesterol efflux capacity in dyslipidemic patients. J Clin Lipidol. 2013;7(5):414-22. KQ5E5, KQ6E5, KQ7E13. [pmid: 24079282].
158 Freedman DS, Kahn HS, Mei Z, et al. Relation of body mass index and waist-to-height ratio to cardiovascular disease risk factors in children and adolescents: the Bogalusa Heart Study. Am J Clin Nutr. 2007;86(1):33-40. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 17616760].
159 Freedman DS, Mei Z, Srinivasan SR, et al. Cardiovascular risk factors and excess adiposity among overweight children and adolescents: the Bogalusa Heart Study. J Pediatr. 2007;150(1):12-17 e2. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 17188605].
160 Frontini MG, Srinivasan SR, Xu J, et al. Usefulness of childhood non-high density lipoprotein cholesterol levels versus other lipoprotein measures in predicting adult subclinical atherosclerosis: the Bogalusa Heart Study. Pediatrics. 2008;121(5):924-9. KQ8E6. [pmid: 18450895].
161 Fuentes MC, Lajo T, Carrion JM, et al. Cholesterol-lowering efficacy of Lactobacillus plantarum CECT 7527, 7528 and 7529 in hypercholesterolaemic adults. Br J Nutr. 2013;(10):1866-72. KQ6E5, KQ7E5. [pmid: 23017585].
162 Gagliano NJ, Emans SJ, Woods ER. Cholesterol screening in the adolescent. J Adolesc Health. 1993;14(2):104-8. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 8476872].
163 Gagne C, Kusters M, Caceres M, et al. Efficacy and safety of ezetimibe monotherapy in 6-10 year old children with heterozygous familial or nonfamilial hypercholesterolemia. J Clin Lipidol. 2013;7(3):257-258. KQ6E6, KQ7E6.
164 Garaiova I, Muchova J, Nagyova Z, et al. Effect of a plant sterol, fish oil and B vitamin combination on cardiovascular risk factors in hypercholesterolemic children and adolescents: a pilot study. Nutr J. 2013;12(0):7. KQ6E9, KQ7E9. [pmid: 23297818].
165 Garcia-Hermoso A, Carmona-Lopez MI, Saavedra JM, et al. Physical exercise, detraining and lipid profile in obese children: a systematic review. Arch Argent Pediatr. 2014;112(6):519-525. KQ6E13, KQ7E13. [pmid: 25362910].
166 Garoufi A, Vorre S, Soldatou A, et al. Plant sterols-enriched diet decreases small, dense LDL-cholesterol levels in children with hypercholesterolemia: a prospective study. Ital J of Pediatr. 2014;40:42. KQ6E9, KQ7E6. [pmid: 24887013].
167 Gauer R. Hyperlipidemia treatment in children: the younger, the better. Am Fam Physician. 2010;82(5). KQ1E13, KQ2E2, KQ3E13, KQ4E13, KQ5E13. [pmid: 20822078].
168 Gebbers JO. Atherosclerosis, cholesterol, nutrition, and statins--a critical review. Ger Med Sci. 2007;5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 19675712].
169 Gelissen IC, Nguyen HL, Tiao DK, et al. Statin use in Australian children: a retrospective audit of four pediatric hospitals. Paediatr Drugs. 2014;16(5):417-23. KQ6E9, KQ7E6. [pmid: 25164329].
170 Giannini C, Diesse L, D'Adamo E, et al. Influence of the Mediterranean diet on carotid intima-media thickness in hypercholesterolaemic children: a 12-month intervention study. Nutr Metab Cardiovasc Dis. 2013;24(1):75-82. KQ6E9, KQ7E6. [pmid: 23809150].
171 Gidding SS, Prospero C, Hossain J, et al. A double-blind randomized trial of fish oil to lower triglycerides and improve cardiometabolic risk in adolescents. J Pediatr. 2014;165(3):497-503 e2. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 25008950].
172 Gilardini L, Pasqualinotto L, Di Matteo S, et al. Factors associated with early atherosclerosis and arterial calcifications in young subjects with a benign phenotype of obesity. Obesity (Silver Spring). 2011;19(8):1684-9. KQ1E13, KQ2E5, KQ3E13, KQ4E13, KQ5E13. [pmid: 21273999].
173 Gillman MW, Cupples LA, Moore LL, et al. Impact of within-person variability on identifying children with hypercholesterolemia: Framingham Children's Study. J Pediatr. 1992;121(3):342-7. KQ3E13. [pmid: 1517906].
174 Giordano P, Del Vecchio GC, Cecinati V, et al. Metabolic, inflammatory, endothelial and haemostatic markers in a group of Italian obese children and adolescents. Eur J Pediatr. 2011;170(7):845-50. KQ3E6. [pmid: 21210148].
175 Giugliano RP, Desai NR, Kohli P, et al. Efficacy, safety, and tolerability of a monoclonal antibody to proprotein convertase subtilisin/kexin type 9 in combination with a statin in patients with hypercholesterolaemia (LAPLACE-TIMI 57): a randomised, placebo-controlled, dose-ranging, phase 2 study. Lancet. 2012;(9858):2007-17. KQ6E5, KQ7E5. [pmid: 23141813].
176 Glueck CJ, Fallat R, Tsang R. Pediatric familial type II hyperlipoproteinemia: therapy with diet and cholestyramine resin. Pediatrics. 1973;52(5):669-79. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 4355362].
177 Glueck CJ, Mellies MJ, Dine M, et al. Safety and efficacy of long-term diet and diet plus bile acid-binding resin cholesterol-lowering therapy in 73 children heterozygous for familial hypercholesterolemia. Pediatrics. 1986;78(2):338-48. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 3526270].
178 Glueck CJ, Tsang RC, Fallat RW, et al. Plasma vitamin A and E levels in children with familial type II hyperlipoproteinemia during therapy with diet and cholestyramine resin. Pediatrics. 1974;54(1):51-5. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 4365953].
179 Goff DC Jr, Donker GA, Ragan JD Jr, et al. Cholesterol screening in pediatric practice. Pediatrics. 1991;88(2):250-8. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 1861922].
180 Goldstein JL, Albers JJ, Schrott HG, et al. Plasma lipid levels and coronary heart disease in adult relatives of newborns with normal and elevated cord blood lipids. Am J Hum Genet. 1974;26(6):727-35. KQ1E5, KQ2E5, KQ3E7, KQ4E5, KQ5E5. [pmid: 4440681].
181 Graves L, Garnett SP, Cowell CT, et al. Waist-to-height ratio and cardiometabolic risk factors in adolescence: findings from a prospective birth cohort. Pediatr Obes. 2014;9(5):327-38. KQ1E13, KQ2E13, KQ3E5, KQ4E6, KQ5E13. [pmid: 23894119].
182 Griffin TC, Christoffel KK, Binns HJ, et al. Family history evaluation as a predictive screen for childhood hypercholesterolemia. Pediatric Practice Research Group. Pediatrics. 1989;84(2):365-73. KQ1E13, KQ2E13, KQ3E7, KQ4E13, KQ5E13. [pmid: 2748269].
183 Grontved A, Ried-Larsen M, Moller NC, et al. Muscle strength in youth and cardiovascular risk in young adulthood (the European Youth Heart Study). Br J Sports Med. 2013;49(2):90-4. KQ3E6. [pmid: 23525553].
184 Groot PH, Dijkhuis-Stoffelsma R, Grose WF, et al. The effects of colestipol hydrochloride on serum lipoprotein lipid and apolipoprotein B and A-I concentrations in children heterozygous for familial hypercholesterolemia. Acta Paediatr Scand. 1983;72(1):81-5. KQ3E13. [pmid: 6407278].
185 Guardamagna O, Abello F, Baracco V, et al. Primary hyperlipidemias in children: effect of plant sterol supplementation on plasma lipids and markers of cholesterol synthesis and absorption. Acta Diabetol. 2011;48(2):127-33. KQ6E9, KQ7E9. [pmid: 21057823].
186 Guardamagna O, Abello F, Baracco V, et al. The treatment of hypercholesterolemic children: efficacy and safety of a combination of red yeast rice extract and policosanols. Nutr Metab Cardiovasc Dis. 2011;21(6):424-9. KQ6E5, KQ7E5. [pmid: 20153154].
187 Guardamagna O, Abello F, Cagliero P, et al. Could dyslipidemic children benefit from glucomannan intake. Nutrition. 2013;(42193):1060-1065. KQ6E5, KQ7E5. [pmid: 23759268].
188 Guardamagna O, Abello F, Saracco P, et al. Endothelial activation, inflammation and premature atherosclerosis in children with familial dyslipidemia. Atherosclerosis. 2009;207(2):471-5. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 19560772].
189 Guardamagna O, Amaretti A, Puddu PE, et al. Bifidobacteria supplementation: effects on plasma lipid profiles in dyslipidemic children. Nutrition. 2014;30(42193):831-6. KQ6E10, KQ7E10. [pmid: 24985000].
190 Gultom LC, Sjarif DR, Sudoyo HA, et al. The role of apolipoprotein E polymorphism in improving dyslipidemia in obese adolescents following physical exercise and National Cholesterol Education Program Step II intervention. J Pediatr Endocrinol Metab. 2015;28(42130):597-603. KQ6E9. [pmid: 25870958].
191 Guo S, Beckett L, Chumlea WC, et al. Serial analysis of plasma lipids and lipoproteins from individuals 9-21 y of age. Am J Clin Nutr. 1993;58(1):61-7. KQ3E13. [pmid: 8317391].
192 Guven A, Sanisoglu SY. Pubertal progression and serum lipid profile in obese children. J Pediatr Endocrinol Metab. 2008;21(2):135-46. KQ3E5, KQ4E5. [pmid: 18422026].
193 Guyton JR, Brown BG, Fazio S, et al. Lipid-altering efficacy and safety of ezetimibe/simvastatin coadministered with extended-release niacin in patients with type IIa or type IIb hyperlipidemia. J Am Coll Cardiol. 2008;(16):1564-72. KQ6E5, KQ7E5. [pmid: 18420099].
194 Gylling H, Hallikainen M, Nissinen MJ, et al. The effect of a very high daily plant stanol ester intake on serum lipids, carotenoids, and fat-soluble vitamins. Clin Nutr. 2010;(1):112-8. KQ6E5, KQ7E5. [pmid: 19709787].
195 Gylling H, Plat J, Turley S, et al. Plant sterols and plant stanols in the management of dyslipidaemia and prevention of cardiovascular disease. Atherosclerosis. 2014;232(2):346-60. KQ6E9, KQ7E9. [pmid: 24468148].
196 Haas GM, Bertsch T, Schwandt P. Prehypertension and cardiovascular risk factors in children and adolescents participating in the community-based prevention education program family heart study. Int J Prev Med. 2014;5(Suppl 1):S50-6. KQ3E7, KQ4E6. [pmid: 24791192].
197 Hammond J, Chinn S, Richardson H, et al. Response to venepuncture for monitoring in primary schools. Arch Dis Child. 1994;(5). KQ1E13, KQ2E13, KQ3E13, KQ4E6, KQ5E13. [pmid: 8017955].
198 Hanlin ER, Hendricks B, Jenkins K, et al. Cardiovascular risk profile: comparison between white and Southeast Asian youth in Wausau SCHOOL Project. WMJ. 2009;108(4):189-93. KQ3E7. [pmid: 19753824].
199 Hardy OT, Wiecha J, Kim A, et al. Effects of a multicomponent wellness intervention on dyslipidemia among overweight adolescents. J Pediatr Endocrinol Metab. 2012;25(42006):79-82. KQ6E5, KQ7E5. [pmid: 22570954].
200 Harel Z, Riggs S, Vaz R, et al. Isolated low HDL cholesterol emerges as the most common lipid abnormality among obese adolescents. Clin Pediatr (Phila). 2010;49(1):29-34. KQ3E7, KQ4E7. [pmid: 19628760].
201 Hauenschild A, Ewald N, Schnell-Kretschmer H, et al. Successful long-term treatment of severe hypertriglyceridemia by feedback control with lipid self-monitoring. Ann Nutr Metab. 2008;52(3):215-20. KQ5E13, KQ6E5, KQ7E5. [pmid: 18544976].
202 Haymond S, Mohanty N. Pediatric lipid screening rates in the us are low: what can labs do to help?. Clin Chem. 2015;61(8):1019-21. KQ3E6. [pmid: 25724661].
203 Heintjes EM, Penning-van Beest FJ, Johansson S, et al. Comparison of incidences of cardiovascular events among new users of different statins: a retrospective observational cohort study. Curr Med Res Opin. 2009;25(11):2621-9. KQ7E5. [pmid: 19743959].
204 Hernandez-Mijares A, Banuls C, Rocha M, et al. Effects of phytosterol ester-enriched low-fat milk on serum lipoprotein profile in mildly hypercholesterolaemic patients are not related to dietary cholesterol or saturated fat intake. Br J Nutr. 2010;(7):1018-25. KQ6E5, KQ7E5. [pmid: 20456813].
205 Higashikawa F, Noda M, Awaya T, et al. Reduction of serum lipids by the intake of the extract of garlic fermented with Monascus pilosus: a randomized, double-blind, placebo-controlled clinical trial. Clin Nutr. 2012;31(2):261-6. KQ6E5, KQ7E5. [pmid: 22041543].
206 Hirschler V, Maccallini G, Calcagno M, et al. Waist circumference identifies primary school children with metabolic syndrome abnormalities. Diabetes Technol Ther. 2007;9(2):149-57. KQ3E6, KQ4E6. [pmid: 17425440].
207 Hirschler V, Maccallini G, Sanchez M, et al. Association between triglyceride to HDL-C ratio and insulin resistance in indigenous Argentinean children. Pediatr Diabetes. 2014;(0). KQ3E4, KQ4E6. [pmid: 25303644].
208 Hirschler V, Molinari C, Maccallini G, et al. Comparison of different anthropometric indices for identifying dyslipidemia in school children. Clin Biochem. 2011;44(42225):659-64. KQ3E4, KQ4E4. [pmid: 21349259].
209 Ho M, Garnett SP, Baur LA, et al. Impact of dietary and exercise interventions on weight change and metabolic outcomes in obese children and adolescents: a systematic review and meta-analysis of randomized trials. JAMA Pediatrics. 2013;167(8):759-68. KQ6E2, KQ7E13. [pmid: 23778747].
210 Ho M, Garnett SP, Baur L, et al. Effectiveness of lifestyle interventions in child obesity: systematic review with meta-analysis. Pediatrics. 2012;130(6):e1647-71. KQ6E5, KQ7E5. [pmid: 23166346].
211 Holl RW, Hoffmeister U, Thamm M, et al. Does obesity lead to a specific lipid disorder? Analysis from the German/Austrian/Swiss APV registry. Int J Pediatr Obes. 2011;(0):53-8. KQ1E13, KQ2E13, KQ3E11, KQ4E6, KQ5E13. [pmid: 21905817].
212 Homma S, Troxclair DA, Zieske AW, et al. Histological changes and risk factor associations in type 2 atherosclerotic lesions (fatty streaks) in young adults. Atherosclerosis. 2011;219(1):184-90. KQ8E9. [pmid: 21831377].
213 House BT, Shearrer GE, Miller SJ, et al. Increased eating frequency linked to decreased obesity and improved metabolic outcomes. Int J Obes (Lond). 2014;(0). KQ6E5, KQ7E5. [pmid: 24840081].
214 Howard JK, Bindler RM, Dimico GS, et al. Cardiovascular risk factors in children: a Bloomsday research report. J Pediatr Nurs. 1991;6(4):222-9. KQ3E13. [pmid: 1865311].
215 Hrafnkelsson H, Magnusson KT, Thorsdottir I, et al. Result of school-based intervention on cardiovascular risk factors. Scand J Prim Health Care. 2014;32(4):149-155. KQ6E5, KQ7E5. [pmid: 25424464].
216 Hsia DS, Gwilliam NR, Ferrell LB, et al. Morbidly obese paediatric patients are not adequately screened for comorbidities. Clin Obes. 2013;3(42006). 11-Jul. KQ4E6. [pmid: 25586387].
217 Hu T, Mills KT, Yao L, et al. Effects of low-carbohydrate diets versus low-fat diets on metabolic risk factors: a meta-analysis of randomized controlled clinical trials. Am J Epidemiol. 2012;176(0):S44-54. KQ6E5, KQ7E5. [pmid: 23035144].
218 Huang CJ, Kwok CF, Chou CH, et al. The effect of exercise on lipid profiles and inflammatory markers in lean male adolescents: a prospective interventional study. J Investig Med. 2014;63(1):29-34. KQ6E5, KQ7E5. [pmid: 25415059].
219 Huang RC, de Klerk N, Mori TA, et al. Differential relationships between anthropometry measures and cardiovascular risk factors in boys and girls. Int J Pediatr Obes. 2011;6(42037):e271-82. KQ3E6, KQ4E13. [pmid: 20815762].
220 Huijgen R, Vissers MN, Kindt I, et al. Assessment of carotid atherosclerosis in normocholesterolemic individuals with proven mutations in the low-density lipoprotein receptor or apolipoprotein B genes. Circ Cardiovasc Genet. 2011;4(4):413-7. KQ6E5, KQ7E5. [pmid: 21642693].
221 Hussein O, Minasian L, Itzkovich Y, et al. Ezetimibe's effect on platelet aggregation and LDL tendency to peroxidation in hypercholesterolaemia as monotherapy or in addition to simvastatin. Br J Clin Pharmacol. 2008;65(5):637-45. KQ6E5, KQ7E5. [pmid: 18241285].
222 I'Allemand D, Wiegand S, Reinehr T, et al. Cardiovascular risk in 26,008 European overweight children as established by a multicenter database. Obesity (Silver Spring). 2008;16(7):1672-9. KQ3E11. [pmid: 18451769].
223 Iannuzzi A, Licenziati MR, Acampora C, et al. Increased carotid intima-media thickness and stiffness in obese children. Diabetes Care. 2004;27(10):2506-8. KQ1E13, KQ2E6, KQ3E13, KQ4E13, KQ5E13. [pmid: 15451928].
224 Imamura H, Nagata A, Oshikata R, et al. High-density lipoprotein cholesterol subfractions and lecithin: cholesterol acyltransferase activity in collegiate soccer players. Int J Sports Med. 2013;34(5):398-401. KQ6E5, KQ7E5. [pmid: 23152129].
225 Inoue DS, De Mello MT, Foschini D, et al. Linear and undulating periodized strength plus aerobic training promote similar benefits and lead to improvement of insulin resistance on obese adolescents. J Diabetes Complications. 2015;29(2):258-64. KQ6E5, KQ7E5. [pmid: 25441178].
226 Iughetti L. Drugs for children with hypercholesterolemia: be cautious. J Pediatr Endocrinol Metab. 2009;22(6):483-5. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 19694194].
227 Izzo R, Simone G, Giudice R, et al. Effects of nutraceuticals on prevalence of metabolic syndrome and on calculated Framingham Risk Score in individuals with dyslipidemia. J Hypertens. 2010;28(7):1482-7. KQ6E5, KQ7E5. [pmid: 20498621].
228 Jago R, Drews KL, McMurray RG, et al. Fatness, fitness, and cardiometabolic risk factors among sixth-grade youth. Med Sci Sports Exerc. 2010;42(8):1502-10. KQ3E6, KQ4E13. [pmid: 20139783].
229 Jellinger PS, Smith DA, Mehta AE, et al. American Association of Clinical Endocrinologists' Guidelines for Management of Dyslipidemia and Prevention of Atherosclerosis. Endocr Pract. 2012;18(Suppl 1):1-78. KQ6E9, KQ7E9. [pmid: 22522068].
230 Jenssen BP, Jacobson MS. Screening adolescents for lipid disorders: what is the best approach?. Adolesc Med State Art Rev. 2008;19(3):507-20. KQ1E13. [pmid: 19227389].
231 Jiang X, Srinivasan SR, Webber LS, et al. Association of fasting insulin level with serum lipid and lipoprotein levels in children. Arch Intern Med. 1995;155(2):190-6. KQ3E13. [pmid: 7811129].
232 Jones PH, Goldberg AC, Knapp HR, et al. Efficacy and safety of fenofibric acid in combination with atorvastatin and ezetimibe in patients with mixed dyslipidemia. Am Heart J. 2010;160(4):759-66. KQ6E5, KQ7E5. [pmid: 20934572].
233 Joseph SV, Jacques H, Plourde M, et al. Conjugated linoleic acid supplementation for 8 weeks does not affect body composition, lipid profile, or safety biomarkers in overweight, hyperlipidemic men. J Nutr. 2011;(7):1286-91. KQ6E5, KQ7E5. [pmid: 21593349].
234 Juhola J, Magnussen CG, Viikari JS, et al. Tracking of serum lipid levels, blood pressure, and body mass index from childhood to adulthood: the Cardiovascular Risk in Young Finns Study. J Pediatr. 2011;159(4):584-90. KQ8E6. [pmid: 21514597].
235 Juonala M, Viikari JS, Kahonen M, et al. Childhood levels of serum apolipoproteins B and A-I predict carotid intima-media thickness and brachial endothelial function in adulthood: the cardiovascular risk in young Finns study. J Am Coll Cardiol. 2008;52(4):293-9. KQ1E13, KQ2E9, KQ3E13, KQ4E13, KQ5E13. [pmid: 18634985].
236 Kaistha A, Deckelbaum RJ, Starc TJ, et al. Overrestriction of dietary fat intake before formal nutritional counseling in children with hyperlipidemia. Arch Pediatr Adolesc Med. 2001;155(11):1225-30. KQ3E13. [pmid: 11695931].
237 Kallio MJ, Salmenpera L, Siimes MA, et al. Tracking of serum cholesterol and lipoprotein levels from the first year of life. Pediatrics. 1993;91(5):949-54. KQ3E13. [pmid: 8474815].
238 Kapur NK. Rosuvastatin: a highly potent statin for the prevention and management of coronary artery disease. Expert Rev Cardiovasc Ther. 2007;5(2):161-75. KQ6E2, KQ7E2. [pmid: 17338662].
239 Kastelein JJP, Kusters M, Caceres M, et al. Efficacy and safety of ezetimibe monotherapy in children six to ten years of age with heterozygous familial or non-familial hypercholesterolemia. J Am Coll Cardiol. 2013;(10):E1466. KQ6E6, KQ7E6.
240 Katzmarzyk PT, Perusse L, Malina RM, et al. Stability of indicators of the metabolic syndrome from childhood and adolescence to young adulthood: the Quebec Family Study. J Clin Epidemiol. 2001;54(2):190-5. KQ3E13. [pmid: 11166535].
241 Kavey RE, Allada V, Daniels SR, et al. Cardiovascular risk reduction in high-risk pediatric patients: a scientific statement from the American Heart Association Expert Panel on Population and Prevention Science; the Councils on Cardiovascular Disease in the Young, Epidemiology and Prevention, Nutrition, Physical Activity and Metabolism, High Blood Pressure Research, Cardiovascular Nursing, and the Kidney in Heart Disease; and the Interdisciplinary Working Group on Quality of Care and Outcomes Research. J Cardiovasc Nurs. 2007;22(3):218-53. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17545824].
242 Kelder SH, Osganian SK, Feldman HA, et al. Tracking of physical and physiological risk variables among ethnic subgroups from third to eighth grade: the Child and Adolescent Trial for Cardiovascular Health cohort study. Prev Med. 2002;(3). KQ3E13. [pmid: 11902849].
243 Kelishadi R, Hashemipour M, Sheikh-Heidar A, et al. Changes in serum lipid profile of obese or overweight children and adolescents following a lifestyle modification course. Arya Atherosclerosis. 2012;8(3):143-8. KQ6E9. [pmid: 23359278].
244 Kelishadi R, Razaghi EM, Gouya MM, et al. Association of physical activity and the metabolic syndrome in children and adolescents: CASPIAN Study. Horm Res. 2007;67(1):46-52. KQ1E4, KQ2E4, KQ3E4, KQ4E4, KQ5E4. [pmid: 17035710].
245 Kelley GA, Kelley KS. Aerobic exercise and lipids and lipoproteins in children and adolescents: a meta-analysis of randomized controlled trials. Atherosclerosis. 2007;191(2):447-53. KQ6E5, KQ7E5. [pmid: 16806228].
246 Kelley GA, Kelley KS. Impact of progressive resistance training on lipids and lipoproteins in adults: a meta-analysis of randomized controlled trials. Prev Med. 2009;48(1). KQ6E5, KQ7E5. [pmid: 19013187].
247 Kelley GA, Kelley KS. Effects of aerobic exercise on non-high-density lipoprotein cholesterol in children and adolescents: a meta-analysis of randomized controlled trials. Prog Cardiovasc Nurs. 2008;23(3):128-32. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 19039893].
248 Kelly AS, Steinberger J, Jacobs DR, et al. Predicting cardiovascular risk in young adulthood from the metabolic syndrome, its component risk factors, and a cluster score in childhood. Int J Pediatr Obes. 2011;6(42037):e283-9. KQ8E6. [pmid: 21070100].
249 Kenny D, Ward OC, Mulhern B, et al. Failure of cord serum cholesterol and betalipoprotein as screening tests for familial hyperlipoproteinaemia. Ir J Med Sci. 1984;(3). KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 6724853].
250 Keska A, Lutoslawska G, Czajkowska A, et al. Variability in HOMA-IR, lipoprotein profile and selected hormones in young active men. ScientificWorldJournal. 2013;2013. KQ3E4. [pmid: 24348155].
251 Khalil A, Aggarwal A, Arora S, et al. Lipoprotein (a)--lipid profile and apolipoprotein B in children of young parents with coronary artery disease. Indian Heart J. 2011;63(5):450-3. KQ3E4. [pmid: 23550425].
252 Kianbakht S, Abasi B, Perham M, et al. Antihyperlipidemic effects of Salvia officinalis L. leaf extract in patients with hyperlipidemia: a randomized double-blind placebo-controlled clinical trial. Phytother Res. 2011;25(12):1849-53. KQ6E13, KQ7E13. [pmid: 21506190].
253 Kim IK, Lee HJ, Kang JH, et al. Relationship of serum retinol-binding protein 4 with weight status and lipid profile among Korean children and adults. Eur J Clin Nutr. 2011;65(2):226-33. KQ3E6, KQ4E6. [pmid: 21102613].
254 Kim J, Bhattacharjee R, Kheirandish-Gozal L, et al. Insulin sensitivity, serum lipids, and systemic inflammatory markers in school-aged obese and nonobese children. Int J Pediatr. 2010. KQ3E6, KQ4E6. [pmid: 21274450].
255 Klakk H, Andersen LB, Heidemann M, et al. Six physical education lessons a week can reduce cardiovascular risk in school children aged 6-13 years: A longitudinal study. Scand J Public Health. 2013. KQ5E5, KQ6E6, KQ7E13. [pmid: 24055828].
256 Kleiser C, Schienkiewitz A, Schaffrath Rosario A, et al. Indicators of overweight and cardiovascular disease risk factors among 11- to 17-year-old boys and girls in Germany. Obes Facts. 2011;4(5):379-85. KQ3E11, KQ4E6. [pmid: 22166758].
257 Koren MJ, Scott R, Kim JB, et al. Efficacy, safety, and tolerability of a monoclonal antibody to proprotein convertase subtilisin/kexin type 9 as monotherapy in patients with hypercholesterolaemia (MENDEL): a randomised, double-blind, placebo-controlled, phase 2 study. Lancet. 2012;(9858):1995-2006. KQ6E5, KQ7E5. [pmid: 23141812].
258 Koren MJ, Lundqvist P, Bolognese M, et al. Anti-PCSK9 monotherapy for hypercholesterolemia: the MENDEL-2 randomized, controlled phase III clinical trial of evolocumab. J Am Coll Cardiol. 2014;63(23):2531-40. KQ6E5, KQ7E5. [pmid: 24691094].
259 Koskinen J, Kahonen M, Viikari JS, et al. Conventional cardiovascular risk factors and metabolic syndrome in predicting carotid intima-media thickness progression in young adults: the cardiovascular risk in young Finns study. Circulation. 2009;120(3):229-36. KQ1E13, KQ2E5, KQ3E13, KQ4E13, KQ5E13. [pmid: 19581494].
260 Kostapanos MS, Milionis HJ, Agouridis AD, et al. Rosuvastatin treatment is associated with an increase in insulin resistance in hyperlipidaemic patients with impaired fasting glucose. Int J Clin Pract. 2009;63(9):1308-13. KQ6E5, KQ7E5. [pmid: 19691613].
261 Kouda K, Nakamura H, Nishio N, et al. Trends in body mass index, blood pressure, and serum lipids in Japanese children: Iwata population-based annual screening (1993-2008). J Epidemiol. 2010;20(3):212-8. KQ3E6, KQ4E13. [pmid: 20208399].
262 Koulouridis E, Georgalidis K, Kostimpa I, et al. Metabolic syndrome risk factors and estimated glomerular filtration rate among children and adolescents. Pediatr Nephrol. 2010;25(3):491-8. KQ3E6, KQ4E13. [pmid: 20012104].
263 Krishna R, Anderson MS, Bergman AJ, et al. Effect of the cholesteryl ester transfer protein inhibitor, anacetrapib, on lipoproteins in patients with dyslipidaemia and on 24-h ambulatory blood pressure in healthy individuals: two double-blind, randomised placebo-controlled phase I studies. Lancet. 2007;(9603):1907-14. KQ6E5, KQ7E5. [pmid: 18068514].
264 Krysiak R, Zmuda W, Okopien B. The effect of ezetimibe and simvastatin on hemostasis in patients with isolated hypercholesterolemia. Fundam Clin Pharmacol. 2012;26(3):424-31. KQ6E5, KQ7E5. [pmid: 21392096].
265 Kuehl KS, Cockerham JT, Hitchings M, et al. Effective control of hypercholesterolemia in children with dietary interventions based in pediatric practice. Prev Med. 1993;22(2):154-66. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 8483855].
266 Kumar SS, Lahey KA, Day A, et al. Comparison of the efficacy of administering a combination of ezetimibe plus fenofibrate versus atorvastatin monotherapy in the treatment of dyslipidemia. Lipids Health Dis. 2009;56. KQ6E5, KQ7E5. [pmid: 20017910].
267 Kunz F, Pechlaner C, Hortnagl H, et al. The smoker's paradox and the real risk of smoking. Eur J Epidemiol. 2005;20(2):161-7. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 15792283].
268 Kuo P, Syu JT, Tzou IL, et al. Prevalence and trend of dyslipidaemia from 1996 to 2006 among normal and overweight adolescents in Taiwan. BMJ Open. 2014;4(2):e003800. KQ3E4, KQ4E4. [pmid: 24578534].
269 Kurabayashi M, Sakuma I, Kawamori R, et al. Can intensive lipid-lowering therapy with statins ameliorate atherosclerosis in Japanese patients? Rationale and design of the JART study. J Atheroscler Thromb. 2010;17(4):416-22. KQ6E2, KQ7E2. [pmid: 20215710].
270 Kusunoki T, Morimoto T, Sakuma M, et al. Total and low-density lipoprotein cholesterol levels are associated with atopy in schoolchildren. J Pediatr. 2011;158(2):334-6. KQ3E7, KQ4E6. [pmid: 21146186].
271 Kwiterovich PO Jr, Barton BA, McMahon RP, et al. Effects of diet and sexual maturation on low-density lipoprotein cholesterol during puberty: the Dietary Intervention Study in Children (DISC). Circulation. 96(8):2526-33. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 9355889].
272 Kwiterovich PO Jr, Heiss G, Johnson N, et al. Assessment of plasma total cholesterol as a test to detect elevated low density (beta) lipoprotein cholesterol levels (type IIa hyperlipoproteinemia) in young subjects from a population-based sample. Am J Epidemiol. 115(2):192-204. KQ1E13, KQ2E13, KQ3E9, KQ4E13, KQ5E13. [pmid: 7058778].
273 Kwiterovich PO Jr. Recognition and management of dyslipidemia in children and adolescents. J Clin Endocrinol Metab. 2008;93(11):4200-9. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 18697860].
274 Kwiterovich PO. Cut points for lipids and lipoproteins in children and adolescents: should they be reassessed?. Clin Chem. 2008;54(7):1113-5. KQ3E2. [pmid: 18593961].
275 Lamaida N, Capuano E, Pinto L, et al. The safety of statins in children. Acta Paediatr. 2013;102(9):857-62. KQ7E5. [pmid: 23631461].
276 Lamb MM, Ogden CL, Carroll MD, et al. Association of body fat percentage with lipid concentrations in children and adolescents: United States, 1999-2004. Am J Clin Nutr. 2011;94(3):877-83. KQ3E6. [pmid: 21775565].
277 Lambert M, Lupien PJ, Gagne C, et al. Treatment of familial hypercholesterolemia in children and adolescents: effect of lovastatin. Canadian Lovastatin in Children Study Group. Pediatrics. 1996;97(5):619-28. KQ3E13. [pmid: 8628597].
278 Lansing AM, Barbie RN, Shaheen KA. Regional cholesterol screening: problems and potentials. J Ky Med Assoc. 1990;88(4):170-4. KQ3E13. [pmid: 2110237].
279 Lapinleimu J, Lapinleimu H, Nuotio IO, et al. Expression of common familial dyslipidemias in early childhood. Atherosclerosis. 2009;204(2):573-9. KQ1E13, KQ2E13, KQ3E7, KQ4E13, KQ5E13. [pmid: 19026413].
280 Larsson B, Vaara I. Cholesterol screening of seven-year-old children. How to identify children at risk. Acta Paediatr. 1992;(4). KQ3E13. [pmid: 1606391].
281 Lazarou C, Matalas AL. Breakfast intake is associated with nutritional status, Mediterranean diet adherence, serum iron and fasting glucose: the CYFamilies study. Public Health Nutr. 2014;18(7):1308-16. KQ3E4, KQ4E4. [pmid: 25287356].
282 Lee CW, Baek SH, Hong TJ, et al. A multicenter, eight-week treatment, single-step titration, open-label study assessing the percentage of Korean dyslipidemic patients achieving LDL cholesterol target with atorvastatin starting doses of 10 mg, 20 mg and 40 mg. Cardiovasc Drugs Ther. 2010;24(2):181-8. KQ6E5, KQ7E5. [pmid: 20383571].
283 Lee JM, Gebremariam A, Card-Higginson P, et al. Poor performance of body mass index as a marker for hypercholesterolemia in children and adolescents. Arch Pediatr Adolesc Med. 2009;163(8):716-23. KQ3E11. [pmid: 19652103].
284 Lee SH, Park S, Kang SM, et al. Effect of atorvastatin monotherapy and low-dose atorvastatin/ezetimibe combination on fasting and postprandial triglycerides in combined hyperlipedemia. J Cardiovasc Pharmacol Ther. 2012;17(1):65-71. KQ6E5, KQ7E5. [pmid: 21386036].
285 Lee S, Bacha F, Gungor N, et al. Comparison of different definitions of pediatric metabolic syndrome: relation to abdominal adiposity, insulin resistance, adiponectin, and inflammatory biomarkers. J Pediatr. 2008;152(2):177-84. KQ3E6, KQ4E6. [pmid: 18206686].
286 Lee S, Burns SF, White D, et al. Effects of acute exercise on postprandial triglyceride response after a high-fat meal in overweight black and white adolescents. Int J Obes (Lond). 2013;37(7):966-71. KQ6E5, KQ7E5. [pmid: 23507997].
287 LeFevre M. Screening for hyperlipidemia in children: primum non nocere. Am Fam Physician. 2010;82(5). KQ1E13, KQ2E2, KQ3E13, KQ4E13, KQ5E13. [pmid: 20822079].
288 Lenicek Krleza J, Ethuranovic V, Bronic A, et al. Multiple presence of prothrombotic risk factors in Croatian children with arterial ischemic stroke and transient ischemic attack. Croat Med J. 2013;54(4):346-54. KQ8E9. [pmid: 23986275].
289 Li C, Ford ES, McBride PE, et al. Non-high-density lipoprotein cholesterol concentration is associated with the metabolic syndrome among US youth aged 12-19 years. J Pediatr. 2011;158(2):201-7. KQ3E6, KQ4E6. [pmid: 20828715].
290 Li J, Motsko SP, Goehring EL, et al. Longitudinal study on pediatric dyslipidemia in population-based claims database. Pharmacoepidemiol Drug Saf. 2010;19(1):90-8. KQ3E9, KQ4E6, KQ6E9, KQ7E6. [pmid: 20035528].
291 Liacouras CA, Coates PM, Gallagher PR, et al. Use of cholestyramine in the treatment of children with familial combined hyperlipidemia. The Journal of pediatrics. 1993;122(3):477-82. KQ3E13. [pmid: 8441109].
292 Lilly CL, Gebremariam YD, Cottrell L, et al. Trends in serum lipids among 5th grade CARDIAC participants, 2002-2012. J Epidemiol Community Health. 2014;68(3):218-23. KQ3E11, KQ4E13. [pmid: 24218074].
293 Lim J. The current state of dyslipidemia in Korean children and adolescents and its management in clinical practice. Ann Pediatr Endocrinol Metab. 2013;18(1). 8-Jan. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 24904843].
294 Lin X, Racette SB, Lefevre M, et al. Combined effects of ezetimibe and phytosterols on cholesterol metabolism: a randomized, controlled feeding study in humans. Circulation. 2011;124(5):596-601. KQ6E5, KQ7E5. [pmid: 21768544].
295 Liu J, Wade TJ, Tan H, et al. Cardiovascular risk factors and anthropometric measurements of adolescent body composition: a cross-sectional analysis of the Third National Health and Nutrition Examination Survey. Int J Obes (Lond). 2007;31(1):59-64. KQ3E6. [pmid: 16652133].
296 Liu Y, Wang J, Zhang R, et al. A good response to oil with medium- and long-chain fatty acids in body fat and blood lipid profiles of male hypertriglyceridemic subjects. Asia Pac J Clin Nutr. 2009;18(3):351-8. KQ6E5, KQ7E5. [pmid: 19786383].
297 Llorente-Cantarero FJ, Perez-Navero JL, Benitez-Sillero Jde D, et al. Evaluation of metabolic risk in prepubertal girls versus boys in relation to fitness and physical activity. Gend Med. 2012;9(6):436-44. KQ3E6. [pmid: 23102933].
298 Loprinzi PD, Lee IM, Andersen RE, et al. Association of concurrent healthy eating and regular physical activity with cardiovascular disease risk factors in U.S. youth. Am J Health Promot. 2014;30(1). KQ3E6, KQ4E6. [pmid: 25372232].
299 Love-Osborne KA, Nadeau KJ, Sheeder J, et al. Presence of the metabolic syndrome in obese adolescents predicts impaired glucose tolerance and nonalcoholic fatty liver disease. J Adolesc Health. 2008;42(6):543-8. KQ3E5. [pmid: 18486862].
300 Luke JN, Brown AD, Brazionis L, et al. Exploring clinical predictors of cardiovascular disease in a central Australian Aboriginal cohort. Eur J Prev Cardiol. 2013;20(2):246-53. KQ3E5. [pmid: 22345691].
301 Luong DQ, Oster R, Ashraf AP. Metformin treatment improves weight and dyslipidemia in children with metabolic syndrome. J Pediatr Endocrinol Metab. 2014;(0). KQ6E9, KQ7E6. [pmid: 25210757].
302 Maccubbin D, Bays HE, Olsson AG, et al. Lipid-modifying efficacy and tolerability of extended-release niacin/laropiprant in patients with primary hypercholesterolaemia or mixed dyslipidaemia. Int J Clin Pract. 2008;(12):1959-70. KQ6E5, KQ7E5. [pmid: 19166443].
303 Machado RB, Bernardes CR, de Souza IM, et al. Is lipid profile determination necessary in women wishing to use oral contraceptives?. Contraception. 2013;87(6):801-5. KQ3E5. [pmid: 23312931].
304 Macias Saint-Gerons D, de la Fuente Honrubia C, Montero Corominas D, et al. Standard and intensive lipid-lowering therapy with statins for the primary prevention of vascular diseases: a population-based study. Eur J Clin Pharmacol. 2014;70(1):99-108. KQ8E6. [pmid: 24062166].
305 Macknin M, Kong T, Weier A, et al. Plant-based, no-added-fat or American Heart Association diets: impact on cardiovascular risk in obese children with hypercholesterolemia and their parents. J Pediatr. 2015;166(4):953-9 e1-3. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E5. [pmid: 25684089].
306 Maggio AB, Martin XE, Saunders Gasser C, et al. Medical and non-medical complications among children and adolescents with excessive body weight. BMC Pediatr. 2014;14. KQ3E5, KQ4E5. [pmid: 25220473].
307 Magnussen CG, Raitakari OT, Thomson R, et al. Utility of currently recommended pediatric dyslipidemia classifications in predicting dyslipidemia in adulthood: evidence from the Childhood Determinants of Adult Health (CDAH) study, Cardiovascular Risk in Young Finns Study, and Bogalusa Heart Study. Circulation. 2008;117(1):32-42. KQ1E9, KQ2E6, KQ3E9, KQ4E13, KQ5E13. [pmid: 18071074].
308 Magnussen CG, Venn A, Thomson R, et al. The association of pediatric low- and high-density lipoprotein cholesterol dyslipidemia classifications and change in dyslipidemia status with carotid intima-media thickness in adulthood evidence from the cardiovascular risk in Young Finns study, the Bogalusa Heart study, and the CDAH (Childhood Determinants of Adult Health) study. J Am Coll Cardiol. 2009;53(10):860-9. KQ1E6, KQ2E9, KQ3E9, KQ4E9, KQ5E13. [pmid: 19264243].
309 Maki KC, Bays HE, Dicklin MR, et al. Effects of prescription omega-3-acid ethyl esters, coadministered with atorvastatin, on circulating levels of lipoprotein particles, apolipoprotein CIII, and lipoprotein-associated phospholipase A2 mass in men and women with mixed dyslipidemia. J Clin Lipidol. 2011;(6):483-92. KQ6E5, KQ7E5. [pmid: 22108152].
310 Maki KC, Butteiger DN, Rains TM, et al. Effects of soy protein on lipoprotein lipids and fecal bile acid excretion in men and women with moderate hypercholesterolemia. J Clin Lipidol. 2010;(6):531-42. KQ6E5, KQ7E5. [pmid: 21122701].
311 Malinowski JM, Gehret MM. Phytosterols for dyslipidemia. Am J Health Syst Pharm. 2010;67(14):1165-73. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 20592321].
312 Malve H, Kerkar P, Mishra N, et al. LDL-cholesterol lowering activity of a blend of rice bran oil and safflower oil (8:2) in patients with hyperlipidaemia: a proof of concept, double blind, controlled, randomised parallel group study. J Indian Med Assoc. 2010;108(11):785-8. KQ6E4, KQ7E4. [pmid: 21510583].
313 Manchester RA, McDuffie C, Diamond E. Screening for hypercholesterolemia in college students. J Am Coll Health. 1989;37(4):149-53. KQ3E9. [pmid: 2926025].
314 Marti B, Vartiainen E. Relation between leisure time exercise and cardiovascular risk factors among 15-year-olds in eastern Finland. J Epidemiol Community Health. 1989;43(3):228-33. KQ3E13. [pmid: 2607300].
315 Martin L, Oepen J, Reinehr T, et al. Ethnicity and cardiovascular risk factors: evaluation of 40,921 normal-weight, overweight or obese children and adolescents living in Central Europe. Int J Obes (Lond). 2014;39(1):45-51. KQ3E7, KQ4E6. [pmid: 25214149].
316 Martin SS, Blaha MJ, Toth PP, et al. Very large database of lipids: rationale and design. Clin Cardiol. 2013;36(11):641-8. KQ3E9. [pmid: 24122913].
317 Martinez-Gomez D, Eisenmann JC, Gomez-Martinez S, et al. Sedentary behavior, adiposity and cardiovascular risk factors in adolescents. The AFINOS study. Rev Esp Cardiol. 2010;63(3):277-85. KQ3E6, KQ4E6. [pmid: 20196988].
318 Martinez-Lopez S, Sarria B, Sierra-Cinos JL, et al. Realistic intake of a flavanol-rich soluble cocoa product increases HDL-cholesterol without inducing anthropometric changes in healthy and moderately hypercholesterolemic subjects. Food Funct. 2014;5(2):364-74. KQ6E5, KQ7E5. [pmid: 24394704].
319 Martinez-Vizcaino V, Martinez MS, Aguilar FS, et al. Validity of a single-factor model underlying the metabolic syndrome in children: a confirmatory factor analysis. Diabetes Care. 2010;33(6):1370-2. KQ3E6. [pmid: 20299487].
320 Martino F, Puddu PE, Pannarale G, et al. Low dose chromium-polynicotinate or policosanol is effective in hypercholesterolemic children only in combination with glucomannan. Atherosclerosis. 2013;(1):198-202. KQ6E13, KQ7E13. [pmid: 23453352].
321 Matsuyama T, Shoji K, Takase H, et al. Effects of phytosterols in diacylglycerol as part of diet therapy on hyperlipidemia in children. Asia Pac J Clin Nutr. 2007;16(1):40-8. KQ6E9, KQ7E9. [pmid: 17215179].
322 McCourt HJ, Hunter SJ, Cardwell CR, et al. Adiponectin multimers, body weight and markers of cardiovascular risk in adolescence: Northern Ireland Young Hearts Project. Int J Obes (Lond). 2013;37(9):1247-53. KQ3E6. [pmid: 23318722].
323 McCrindle BW, American Heart Association Writing Group, Urbina EM, et al. Summary of the American Heart Association's scientific statement on drug therapy of high-risk lipid abnormalities in children and adolescents. Arterioscler Thromb Vasc Biol. 2007;27(5):982-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17442893].
324 McCrindle BW, Helden E, Cullen-Dean G, et al. A randomized crossover trial of combination pharmacologic therapy in children with familial hyperlipidemia. Pediatr Res. 2002;51(6):715-21. KQ3E13. [pmid: 12032266].
325 McCrindle BW, Manlhiot C, Millar K, et al. Population trends toward increasing cardiovascular risk factors in Canadian adolescents. J Pediatr. 2010;157(5):837-43. KQ3E7, KQ4E13. [pmid: 20955854].
326 McCrindle BW, Urbina EM, Dennison BA, et al. Drug therapy of high-risk lipid abnormalities in children and adolescents: a scientific statement from the American Heart Association Atherosclerosis, Hypertension, and Obesity in Youth Committee, Council of Cardiovascular Disease in the Young, with the Council on Cardiovascular Nursing. Circulation. 2007;115(14):1948-67. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17377073].
327 Mendelson M, Michallet AS, Monneret D, et al. Impact of exercise training without caloric restriction on inflammation, insulin resistance and visceral fat mass in obese adolescents. Pediatr Obes. 2014. KQ6E5, KQ7E5. [pmid: 25088157].
328 Menees S, Zhang D, Le J, et al. Variations in carotid artery intima-media thickness during the cardiac cycle in children. J Am Soc Echocardiogr. 2010;23(1):58-63. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 19962856].
329 Messiah SE, Arheart KL, Lipshultz SE, et al. Body mass index, waist circumference, and cardiovascular risk factors in adolescents. J Pediatr. 2008;153(6):845-50. KQ1E13, KQ2E13, KQ3E7, KQ4E13, KQ5E13. [pmid: 18675434].
330 Messiah SE, Vidot DC, Gurnurkar S, et al. Obesity is significantly associated with cardiovascular disease risk factors in 2- to 9-year-olds. J Clin Hypertens (Greenwich). 2014;16(12):889-94. KQ3E6, KQ4E6. [pmid: 25307314].
331 Miazgowski T, Safranow K, Krzyzanowska-Swiniarska B, et al. Adiponectin, visfatin and regional fat depots in normal weight obese premenopausal women. Eur J Clin Invest. 2013;43(8):783-90. KQ3E5. [pmid: 23650969].
332 Michels N, De Henauw S, Breidenassel C, et al. European adolescent ready-to-eat-cereal (RTEC) consumers have a healthier dietary intake and body composition compared with non-RTEC consumers. Eur J Nutr. 2014;54(4):653-64. KQ3E5, KQ4E13. [pmid: 25403942].
333 Miettinen TA, Gylling H, Viikari J, et al. Synthesis and absorption of cholesterol in Finnish boys by serum non-cholesterol sterols: the cardiovascular risk in Young Finns Study. Atherosclerosis. 2008;200(1):177-83. KQ3E6, KQ4E6. [pmid: 18178213].
334 Mietus-Snyder M, Drews KL, Otvos JD, et al. Low-density lipoprotein cholesterol versus particle number in middle school children. J Pediatr. 2013;163(2):355-62. KQ3E6. [pmid: 23415622].
335 Mietus-Snyder M, Krauss RM. Lipid metabolism in children and adolescents: Impact on vascular biology. J Clin Lipidol. 2008;2(3):127-37. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 21291731].
336 Mitka M. Screening misses high LDL in many youths. JAMA. 2010;304(9):952-3. KQ3E2, KQ4E2. [pmid: 20810367].
337 Mittelman SD, Gilsanz P, Mo AO, et al. Adiposity predicts carotid intima-media thickness in healthy children and adolescents. J Pediatr. 2010;156(4):592-7 e2. KQ1E13, KQ2E13, KQ3E7, KQ4E13, KQ5E13. [pmid: 20004913].
338 Mizuno K, Nakaya N, Teramoto T, et al. Usefulness of LDL-C-related parameters to predict cardiovascular risk and effect of pravastatin in mild-to-moderate hypercholesterolemia. J Atheroscler Thromb. 2012;19(2):176-85. KQ6E5, KQ7E5. [pmid: 22129522].
339 Mohammadi A, Sahebkar A, Iranshahi M, et al. Effects of supplementation with curcuminoids on dyslipidemia in obese patients: a randomized crossover trial. Phytother Res. 2013;(3):374-9. KQ6E6, KQ7E6. [pmid: 22610853].
340 Mohiuddin SM, Pepine CJ, Kelly MT, et al. Efficacy and safety of ABT-335 (fenofibric acid) in combination with simvastatin in patients with mixed dyslipidemia: a phase 3, randomized, controlled study. Am Heart J. 2009;157(1):195-203. KQ6E5, KQ7E5. [pmid: 19081418].
341 Mohler B, Ackermann-Liebrich U, Steffen T, Staehelin HB. Cholesterol screening in childhood: results of a 9-year follow-up study in Swiss and Italian children in Switzerland. Soz Praventivmed. 1996;41(6):333-40. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 9008838].
342 Moller NC, Grontved A, Wedderkopp N, et al. Cardiovascular disease risk factors and blood pressure response during exercise in healthy children and adolescents: the European Youth Heart Study. J Appl Physiol (1985). 2010;109(4):1125-32. KQ3E6, KQ4E6. [pmid: 20634358].
343 Moodie D. Cholesterol screening in children. Congenit Heart Dis. 2012;7(1). KQ1E13. [pmid: 22276662].
344 Moran A, Jacobs DR Jr, et al. Changes in insulin resistance and cardiovascular risk during adolescence: establishment of differential risk in males and females. Circulation. 2008;117(18):2361-8. KQ3E6. [pmid: 18427135].
345 Moreno LA, Sarria A, Lazaro A, et al. Lymphocyte T subset counts in children with hypercholesterolemia receiving dietary therapy. Ann Nutr Metab. 1998;42(5):261-5. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 9812016].
346 Morrison JA, Friedman LA, Gray-McGuire C, et al. Metabolic syndrome in childhood predicts adult cardiovascular disease 25 years later: the Princeton Lipid Research Clinics Follow-up Study. Pediatrics. 2007;120(2):340-5. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 17671060].
347 Morrison JA, Glueck CJ, Daniels SR, et al. High-sensitivity C reactive protein: associations with cardiovascular risk factors and tracking in female adolescents and young adults. ISRN Pediatr. 2011;2011. KQ3E6, KQ4E6. [pmid: 22482065].
348 Morrison JA, Glueck CJ, Daniels S, et al. Paradoxically high adiponectin in obese 16-year-old girls protects against appearance of the metabolic syndrome and its components seven years later. J Pediatr. 2011;158(2):208-14 e1. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 20869727].
349 Morrison JA, Glueck CJ, Horn PS, et al. Childhood predictors of adult type 2 diabetes at 9- and 26-year follow-ups. Arch Pediatr Adolesc Med. 2010;164(1):53-60. KQ2E6. [pmid: 20048242].
350 Morrison KM, Dyal L, Conner W, et al. Cardiovascular risk factors and non-invasive assessment of subclinical atherosclerosis in youth. Atherosclerosis. 2010;208(2):501-5. KQ1E13, KQ2E9, KQ3E13, KQ4E13, KQ5E13. [pmid: 19699477].
351 Morrison KM, Xu L, Tarnopolsky M, et al. Screening for dysglycemia in overweight youth presenting for weight management. Diabetes Care. 2012;35(4):711-6. KQ3E6. [pmid: 22271926].
352 Moschonis G, Mavrogianni C, Karatzi K, et al. Increased physical activity combined with more eating occasions is beneficial against dyslipidemias in children. The Healthy Growth Study. Eur J Nutr. 2013;52(3):1135-44. KQ3E6, KQ6E9, KQ7E9. [pmid: 22868822].
353 Muhonen LE, Burns TL, Nelson RP, et al. Coronary risk factors in adolescents related to their knowledge of familial coronary heart disease and hypercholesterolemia: the Muscatine Study. Pediatrics. 1994;93(3):444-51. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 8115204].
354 Muros JJ, Zabala M, Oliveras-Lopez MJ, et al. Effect of physical activity, nutritional education, and consumption of evoo on lipid, physiological, and anthropometric profiles in a pediatric population. J Phys Act Health. 2014. KQ6E5, KQ7E5. [pmid: 25409189].
355 Muros JJ, Zabala M, Oliveras-Lopez MJ, et al. Results of a 7-week school-based physical activity and nutrition pilot program on health-related parameters in primary school children in southern Spain. Pediatr Exerc Sci. 2013;25(2):248-61. KQ6E5, KQ7E5. [pmid: 23504925].
356 Musso C, Graffigna M, Soutelo J, et al. Cardiometabolic risk factors as apolipoprotein B, triglyceride/HDL-cholesterol ratio and C-reactive protein, in adolescents with and without obesity: cross-sectional study in middle class suburban children. Pediatr Diabetes. 2011;12(3 Pt 2):229-34. KQ1E13, KQ2E4, KQ3E4, KQ4E4, KQ5E13. [pmid: 21518411].
357 Nambiar S, Hughes I, Davies PS. Developing waist-to-height ratio cut-offs to define overweight and obesity in children and adolescents. Public Health Nutr. 2010;13(10):1566-74. KQ3E6. [pmid: 20100388].
358 Nenseter MS, Bogsrud MP, Graesdal A, et al. LDL-apheresis affects markers of endothelial function in patients with homozygous familial hypercholesterolemia. Thromb Res. 2012;130(5):823-5. KQ1E13, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 22728023].
359 Neovius M, Rossner SM, Vagstrand K, et al. Adiposity measures as indicators of metabolic risk factors in adolescents. Obes Facts. 2009;2(5):294-301. KQ3E6. [pmid: 20057196].
360 Newman WP 3rd, Freedman DS, Voors AW, et al. Relation of serum lipoprotein levels and systolic blood pressure to early atherosclerosis. The Bogalusa Heart Study. N Engl J Med. 1986;314(3):138-44. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 3455748].
361 Nielsen TR, Gamborg M, Fonvig CE, et al. Changes in lipidemia during chronic care treatment of childhood obesity. Child Obes. 2012;8(6):533-41. KQ6E5, KQ7E13. [pmid: 23181919].
362 Niinikoski H, Pahkala K, Ala-Korpela M, et al. Effect of repeated dietary counseling on serum lipoproteins from infancy to adulthood. Pediatrics. 2012;(3):e704-13. KQ6E5, KQ7E5. [pmid: 22331346].
363 Noto D, Cefalu AB, Barraco G, et al. Plasma non-cholesterol sterols: a useful diagnostic tool in pediatric hypercholesterolemia. Pediatr Res. 2010;67(2):200-4. KQ1E13. [pmid: 20091938].
364 Oda E, Kawai R, Aizawa Y. Lymphocyte count was significantly associated with hyper-LDL cholesterolemia independently of high-sensitivity C-reactive protein in apparently healthy Japanese. Heart Vessels. 2012;27(4):377-83. KQ3E6, KQ4E6. [pmid: 21655904].
365 O'Grady MJ, Brown AM, O'Neill MB. Cholesterol screening in an at-risk pediatric population. Pediatr Cardiol. 2008;29(3):609-13. KQ3E9, KQ4E6. [pmid: 18094916].
366 Oh ES, Lee SH, Park MS, et al. Modeling of the LDL cholesterol-lowering effect of atorvastatin in Korean dyslipidemic patients and non-patient volunteers. Int J Clin Pharmacol Ther. 2012;50(9):647-56. KQ6E5, KQ7E5. [pmid: 22981146].
367 Okosun IS, Lyn R, Davis-Smith M, et al. Validity of a continuous metabolic risk score as an index for modeling metabolic syndrome in adolescents. Ann Epidemiol. 2010;20(11):843-51. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 20933191].
368 Okuda M, Sugiyama S, Kunitsugu I, et al. Use of body mass index and percentage overweight cutoffs to screen Japanese children and adolescents for obesity-related risk factors. J Epidemiol. 2010;20(1):46-53. KQ3E7, KQ4E6. [pmid: 19855138].
369 O'Loughlin J, Lauzon B, Paradis G, et al. Usefulness of the American Academy of Pediatrics recommendations for identifying youths with hypercholesterolemia. Pediatrics. 2004;113(6):1723-7. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 15173497].
370 Olson K, Hendricks B, Murdock DK, et al. The triglyceride to HDL ratio and its relationship to insulin resistance in pre- and postpubertal children: observation from the Wausau School Project. Cholesterol. 2012;2012. KQ3E6, KQ4E6. [pmid: 22811895].
371 Ondrak KS, McMurray RG, Bangdiwala SI, et al. Influence of aerobic power and percent body fat on cardiovascular disease risk in youth. J Adolesc Health. 2007;41(2):146-52. KQ6E5, KQ7E5. [pmid: 17659218].
372 Orchard TJ, Donahue RP, Kuller LH, et al. Cholesterol screening in childhood: does it predict adult hypercholesterolemia? The Beaver County experience. J Pediatr. 1983;103(5):687-91. KQ1E13, KQ2E13, KQ3E9, KQ4E6, KQ5E13. [pmid: 6631595].
373 Pacifico L, Bonci E, Andreoli G, et al. Association of serum triglyceride-to-HDL cholesterol ratio with carotid artery intima-media thickness, insulin resistance and nonalcoholic fatty liver disease in children and adolescents. Nutr Metab Cardiovasc Dis. 2014;24(7):737-43. KQ2E9. [pmid: 24656140].
374 Parker BA, Gregory SM, Lorson L, et al. A randomized trial of coenzyme Q10 in patients with statin myopathy: rationale and study design. J Clin Lipidol. 2013;7(3):187-93. KQ7E5. [pmid: 23725917].
375 Pasiakos SM, Karl JP, Lutz LJ, et al. Cardiometabolic risk in US Army recruits and the effects of basic combat training. PLoS ONE. 2012;7(2):e31222. KQ6E5, KQ7E5. [pmid: 22384004].
376 Patel DA, Srinivasan SR, Chen W, et al. Serum alanine aminotransferase and its association with metabolic syndrome in children: the Bogalusa Heart Study. Metab Syndr Relat Disord. 2011;9(3):211-6. KQ1E13, KQ2E13, KQ3E6, KQ4E6, KQ5E13. [pmid: 21476865].
377 Pedrosa C, Oliveira BM, Albuquerque I, et al. Obesity and metabolic syndrome in 7-9 years-old Portuguese schoolchildren. Diabetol Metab Syndr. 2010;2(1). KQ3E6, KQ4E6. [pmid: 20537155].
378 Perez CM, Ortiz AP, Fuentes-Mattei E, et al. High prevalence of cardiometabolic risk factors in Hispanic adolescents: correlations with adipocytokines and markers of inflammation. J Immigr Minor Health. 2014;16(5):865-73. KQ3E9, KQ4E6. [pmid: 23828626].
379 Petkeviciene J, Klumbiene J, Kriaucioniene V, et al. Anthropometric measurements in childhood and prediction of cardiovascular risk factors in adulthood: Kaunas cardiovascular risk cohort study. BMC Public Health. 2015;15(9):218. KQ6E6. [pmid: 25880559].
380 Pinto Pereira SM, Power C. Life course body mass index, birthweight and lipid levels in mid-adulthood: a nationwide birth cohort study. Eur Heart J. 2013;34(16):1215-24. KQ8E6. [pmid: 23234645].
381 Plachta-Danielzik S, Landsberg B, Johannsen M, et al. Association of different obesity indices with blood pressure and blood lipids in children and adolescents. Br J Nutr. 2008;100(1):208-18. KQ3E6. [pmid: 18346303].
382 Plana N, Nicolle C, Ferre R, et al. Plant sterol-enriched fermented milk enhances the attainment of LDL-cholesterol goal in hypercholesterolemic subjects. Eur J Nutr. 2008;(1):32-9. KQ6E5, KQ7E5. [pmid: 18193377].
383 Pletcher MJ, Bibbins-Domingo K, Liu K, et al. Nonoptimal lipids commonly present in young adults and coronary calcium later in life: the CARDIA (Coronary Artery Risk Development in Young Adults) study. Ann Intern Med. 2010;153(3):137-46. KQ2E13, KQ3E13, KQ4E13. [pmid: 20679558].
384 Poisson SN, Schardt TQ, Dingman A, et al. Etiology and treatment of arterial ischemic stroke in children and young adults. Curr Treat Options Neurol. 2014;16(10):315. KQ8E2. [pmid: 25227455].
385 Polonsky SM, Bellet PS, Sprecher DL. Primary hyperlipidemia in a pediatric population: classification and effect of dietary treatment. Pediatrics. 1993;91(1):92-6. KQ1E13, KQ2E13, KQ3E9, KQ4E13, KQ5E13. [pmid: 8416512].
386 Porkka KV, Viikari JS, Akerblom HK. Tracking of serum HDL-cholesterol and other lipids in children and adolescents: the Cardiovascular Risk in Young Finns Study. Prev Med. 1991;20(6):713-24. KQ3E13. [pmid: 1766943].
387 Porkka KV, Viikari JS, Taimela S, et al. Tracking and predictiveness of serum lipid and lipoprotein measurements in childhood: a 12-year follow-up. The Cardiovascular Risk in Young Finns study. Am J Epidemiol. 1994;140(12):1096-110. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 7998592].
388 Pratt RE, Kavey RE, Quinzi D. Combined dyslipidemia in obese children: response to a focused lifestyle approach. J Clin Lipidol. 2014;8(2):181-6. KQ6E9, KQ7E9. [pmid: 24636177].
389 Prentice D, Kilty HL, Stearne K, et al. Prevalence of cardiovascular risk factors in grade nine students. Can J Cardiovasc Nurs. 2008;18(3):12-6. KQ3E11. [pmid: 18727282].
390 Primrose ED, Savage JM, Boreham CA, et al. Cholesterol screening and family history of vascular disease. Arch Dis Child. 1994;71(3):239-42. KQ1E13, KQ2E13, KQ3E9, KQ4E13, KQ5E13. [pmid: 7979498].
391 Puccetti L, Scarpini F, Auteri A, et al. Genetics of the coenzyme Q10 pathway and rosuvastatin-induced muscle effects. J Pediatr. 2011;158(3):520-1. KQ7E2. [pmid: 21276592].
392 Putaala J, Haapaniemi E, Kaste M, et al. Statins after ischemic stroke of undetermined etiology in young adults. Neurology. 2011;77(5):426-30. KQ8E6. [pmid: 21810695].
393 Qorbani M, Kelishadi R, Farrokhi-Khajeh-Pasha Y, et al. Association of anthropometric measures with cardiovascular risk factors and metabolic syndrome in normal-weight children and adolescents: the CASPIAN III study. Obes Facts. 2013;6(5):483-92. KQ3E4. [pmid: 24157679].
394 Quijada Z, Paoli M, Zerpa Y, et al. The triglyceride/HDL-cholesterol ratio as a marker of cardiovascular risk in obese children; association with traditional and emergent risk factors. Pediatr Diabetes. 2008;9(5):464-71. KQ3E5. [pmid: 18507788].
395 Racil G, Ben Ounis O, Hammouda O, et al. Effects of high vs. moderate exercise intensity during interval training on lipids and adiponectin levels in obese young females. Eur J Appl Physiol. 2013;113(10):2531-40. KQ6E5, KQ7E13. [pmid: 23824463].
396 Rajaram S, Haddad EH, Mejia A, et al. Walnuts and fatty fish influence different serum lipid fractions in normal to mildly hyperlipidemic individuals: a randomized controlled study. Am J Clin Nutr. 2009;89(5):1657S-1663S. KQ6E5, KQ7E5. [pmid: 19339404].
397 Ramachandran S, Abbas A, Saraf S, et al. Significant increase in high-density lipoprotein cholesterol with fibrates is associated with low pretreatment high-density lipoprotein cholesterol: findings from an outpatient clinic setting. Metab Syndr Relat Disord. 2012;10(3):189-94. KQ6E5, KQ7E5. [pmid: 22283634].
398 Raman A, Sharma S, Fitch MD, et al. Anthropometric correlates of lipoprotein profile and blood pressure in high BMI African American children. Acta Paediatr. 2010;99(6):912-9. KQ3E6, KQ4E13. [pmid: 20064141].
399 Raynor LA, Schreiner PJ, Loria CM, et al. Associations of retrospective and concurrent lipid levels with subclinical atherosclerosis prediction after 20 years of follow-up: the Coronary Artery Risk Development in Young Adults (CARDIA) study. Ann Epidemiol. 2013;23(8):492-7. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 23889858].
400 Redondo O, Villamor E, Valdes J, et al. Validation of a BMI cut-off point to predict an adverse cardiometabolic profile with adiposity measurements by dual-energy X-ray absorptiometry in Guatemalan children. Public Health Nutr. 2014;(0). 8-Jan. KQ3E13. [pmid: 24955816].
401 Reeves MJ, Gargano JW, Luo Z, et al. Effect of pretreatment with statins on ischemic stroke outcomes. Stroke. 2008;39(6):1779-85. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5. [pmid: 18369173].
402 Ribas SA, Cunha DB, Sichieri R, et al. Effects of psyllium on LDL-cholesterol concentrations in Brazilian children and adolescents: a randomised, placebo-controlled, parallel clinical trial. Br J Nutr. 2014;(0). 8-Jan. KQ6E4, KQ7E4. [pmid: 25391814].
403 Richard Hobbs FD, Gensini G, John Mancini GB, et al. International open-label studies to assess the efficacy and safety of single-pill amlodipine/atorvastatin in attaining blood pressure and lipid targets recommended by country-specific guidelines: the JEWEL programme. Eur J Cardiovasc Prev Rehabil. 2009;16(4):472-80. KQ6E5, KQ7E5. [pmid: 19407658].
404 Ried-Larsen M, Grontved A, Moller NC, et al. Associations between objectively measured physical activity intensity in childhood and measures of subclinical cardiovascular disease in adolescence: prospective observations from the European Youth Heart Study. Br J Sports Med. 2013;(0). KQ6E8, KQ7E8. [pmid: 23584828].
405 Rifai N, Neufeld E, Ahlstrom P, et al. Failure of current guidelines for cholesterol screening in urban African-American adolescents. Pediatrics. 1996;98(3 Pt 1):383-8. KQ3E7. [pmid: 8784361].
406 Riggio S, Mandraffino G, Sardo MA, et al. Pulse wave velocity and augmentation index, but not intima-media thickness, are early indicators of vascular damage in hypercholesterolemic children. Eur J Clin Invest. 2010;40(3):250-7. KQ6E13. [pmid: 20415700].
407 Robinson JG, Ballantyne CM, Hsueh WA, et al. Age, abdominal obesity, and baseline high-sensitivity C-reactive protein are associated with low-density lipoprotein cholesterol, non-high-density lipoprotein cholesterol, and apolipoprotein B responses to ezetimibe/simvastatin and atorvastatin in patients with metabolic syndrome. J Clin Lipidol. 2013;(4):292-303. KQ6E5, KQ7E5. [pmid: 23890516].
408 Robinson JG, Ballantyne CM, Hsueh W, et al. Achievement of specified low-density lipoprotein cholesterol, non-high-density lipoprotein cholesterol apolipoprotein B, and high-sensitivity C-reactive protein levels with ezetimibe/simvastatin or atorvastatin in metabolic syndrome patients with and without atherosclerotic vascular disease (from the VYMET study). J Clin Lipidol. 2011;(6):474-82. KQ6E5, KQ7E5. [pmid: 22108151].
409 Rodriguez-Rodriguez E, Ortega RM, Gonzalez-Rodriguez LG, et al. Vitamin D deficiency is an independent predictor of elevated triglycerides in Spanish school children. Eur J Nutr. 2011;50(5):373-8. KQ3E6. [pmid: 21103884].
410 Rohatgi A. Cholesterol screening in children: makes sense but what is the impact?. Future Cardiol. 2010;6(3):275-80. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20462333].
411 Romero JB, Briones E, Palacios GC, et al. Subclinical metabolic abnormalities associated with obesity in prepubertal Mexican schoolchildren. J Pediatr Endocrinol Metab. 2010;23(6):589-96. KQ3E9, KQ4E6. [pmid: 20662332].
412 Rosenberg E, Lamping DL, Joseph L, et al. Cholesterol screening of children at high risk: behavioural and psychological effects. CMAJ. 1997;(4). KQ1E13, KQ2E13, KQ3E13, KQ4E5, KQ5E13. [pmid: 9054818].
413 Roseneu M, Van Biervliet JP. Screening and follow-up of infants with dyslipoproteinemia. Prog Clin Biol Res. 1985. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 3933016].
414 Rowan C, Brinker AD, Nourjah P, et al. Rhabdomyolysis reports show interaction between simvastatin and CYP3A4 inhibitors. Pharmacoepidemiol Drug Saf. 2009;18(4):301-9. KQ7E5. [pmid: 19206087].
415 Ruano G, Windemuth A, Wu AH, et al. Mechanisms of statin-induced myalgia assessed by physiogenomic associations. Atherosclerosis. 2011;218(2):451-6. KQ7E5. [pmid: 21868014].
416 Rubba F, Gentile M, Iannuzzi A, et al. Vascular preventive measures: the progression from asymptomatic to symptomatic atherosclerosis management. Evidence on usefulness of early diagnosis in women and children. Future Cardiol. 2010;6(2):211-20. KQ8E2. [pmid: 20230262].
417 Ruiz N, Rangel A, Rodriguez C, et al. Relationship among nocturnal sleep deficit, excess weight and metabolic alterations in adolescents. Arch Argent Pediatr. 2014;112(6):511-8. KQ3E13, KQ4E13. [pmid: 25362909].
418 Rytter D, Bech BH, Halldorsson T, et al. No association between the intake of marine n-3 PUFA during the second trimester of pregnancy and factors associated with cardiometabolic risk in the 20-year-old offspring. Br J Nutr. 2013;110(11):2037-46. KQ3E9. [pmid: 23680230].
419 Sabin MA, Magnussen CG, Juonala M, et al. The role of pharmacotherapy in the prevention and treatment of paediatric metabolic syndrome--Implications for long-term health: part of a series on Pediatric Pharmacology, guest edited by Gianvincenzo Zuccotti, Emilio Clementi, and Massimo Molteni. Pharmacol Res. 2012;65(4):397-401. KQ6E2, KQ7E2. [pmid: 22037094].
420 Sabzghabaee AM, Ataei E, Kelishadi R, et al. Effect of hibiscus sabdariffa calices on dyslipidemia in obese adolescents: a triple-masked randomized controlled trial. Mater Sociomed. 2013;25(2):76-9. KQ6E13. [pmid: 24082826].
421 Sabzghabaee AM, Khayam I, Kelishadi R, et al. Effect of Zizyphus jujuba fruits on dyslipidemia in obese adolescents: a triple-masked randomized controlled clinical trial. Med Arch. 2013;67(3):156-9. KQ6E4, KQ7E4. [pmid: 23848030].
422 Sabzghabaee A, Kelishadi R, Jelokhanian H, et al. Clinical effects of Portulaca oleracea seeds on dyslipidemia in obese adolescents: a triple-blinded randomized controlled trial. Med Arch. 2014;68(3):195-9. KQ6E13, KQ7E13. [pmid: 25568533].
423 Safavi M, Farajian S, Kelishadi R, et al. The effects of synbiotic supplementation on some cardio-metabolic risk factors in overweight and obese children: a randomized triple-masked controlled trial. Int J Food Sci Nutr. 2013;64(6):687-93. KQ6E4, KQ7E4. [pmid: 23477506].
424 Salawi HA, Ambler KA, Padwal RS, et al. Characterizing severe obesity in children and youth referred for weight management. BMC Pediatr. 2014;14(0). KQ3E9, KQ4E6. [pmid: 24947311].
425 Salazar MR, Carbajal HA, Espeche WG, et al. Relation among the plasma triglyceride/high-density lipoprotein cholesterol concentration ratio, insulin resistance, and associated cardio-metabolic risk factors in men and women. Am J Cardiol. 2012;109(12):1749-53. KQ3E4. [pmid: 22449634].
426 Sanchez Bayle M, Gonzalez Vergaz A, Garcia Cuatero B, et al. Is a parental history of coronary arterial disease in children as discriminating as their lipoprotein profile? Nino Jesus Group. Int J Cardiol. 1992;36(3):267-71. KQ3E6. [pmid: 1428260].
427 Sanchez-Bayle M, Gonzalez-Requejo A, Pelaez MJ, et al. A cross-sectional study of dietary habits and lipid profiles. The Rivas-Vaciamadrid study. Eur J Pediatr. 2008;167(2):149-54. KQ3E6, KQ6E5, KQ7E5. [pmid: 17333272].
428 Savitha M, Sandeep B. The study of lipid profile, diet and other cardiovascular risk factors in children born to parents having premature ischemic heart disease. Indian J Community Med. 2011;36(4):291-5. KQ3E4, KQ4E4. [pmid: 22279260].
429 Schwandt P, Bertsch T, Haas GM. Anthropometric screening for silent cardiovascular risk factors in adolescents: The PEP Family Heart Study. Atherosclerosis. 2010;211(2):667-71. KQ3E7, KQ4E13. [pmid: 20417933].
430 Seo H, Jeon BD, Ryu S. Persimmon vinegar ripening with the mountain-cultivated ginseng ingestion reduces blood lipids and lowers inflammatory cytokines in obese adolescents. J Exerc Nutrition Biochem. 2015;19(1). 10-Jan. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E5. [pmid: 25960949].
431 Shah S, Ceska R, Gil-Extremera B, et al. Efficacy and safety of extended-release niacin/laropiprant plus statin vs. doubling the dose of statin in patients with primary hypercholesterolaemia or mixed dyslipidaemia. Int J Clin Pract. 2010;64(6):727-38. KQ6E5, KQ7E5. [pmid: 20518948].
432 Shannon BM, Tershakovec AM, Martel JK, et al. Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94(6 Pt 1):923-7. KQ3E13. [pmid: 7971012].
433 Shashaj B, Bedogni G, Graziani MP, et al. Origin of cardiovascular risk in overweight preschool children: a cohort study of cardiometabolic risk factors at the onset of obesity. JAMA Pediatrics. 2014;168(10):917-24. KQ2E13, KQ3E5, KQ4E13. [pmid: 25111132].
434 Shea S, Basch CE, Irigoyen M, et al. Failure of family history to predict high blood cholesterol among hispanic preschool children. Prev Med. 1990;19(4):443-55. KQ3E13. [pmid: 2204914].
435 Shepherd J, Vidt DG, Miller E, et al. Safety of rosuvastatin: update on 16,876 rosuvastatin-treated patients in a multinational clinical trial program. Cardiology. 2007;107(4):433-43. KQ6E5, KQ7E5. [pmid: 17363845].
436 Shirasawa T, Ochiai H, Ohtsu T, et al. LDL-cholesterol and body mass index among Japanese schoolchildren: a population-based cross-sectional study. Lipids Health Dis. 2013;12. KQ3E6. [pmid: 23705977].
437 Silva IT, Mello AP, Sanches LB, et al. Is plasma alpha-tocopherol associated with electronegative LDL in obese adolescents?. J Nutr Sci Vitaminol (Tokyo). 2013;59(2):100-7. KQ3E4. [pmid: 23727639].
438 Skinner AC, Steiner MJ, Chung AE, et al. Cholesterol curves to identify population norms by age and sex in healthy weight children. Clin Pediatr (Phila). 2012;51(3):233-7. KQ3E9. [pmid: 22157422].
439 Skovby F, Micic S, Jepsen B, et al. Screening for familial hypercholesterolaemia by measurement of apolipoproteins in capillary blood. Arch Dis Child. 1991;66(7):844-7. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 1863097].
440 Smith MEB, Lee NJ, Haney E, et al. Drug Class Review: HMG-CoA Reductase Inhibitors (Statins) and Fixed-dose Combination Products Containing a Statin: Final Report Update 5. 2009. [pmid: 21089253]. KQ6E6, KQ7E6.
441 Sniderman AD, Hogue JC, Bergeron J, et al. Non-HDL cholesterol and apoB in dyslipidaemia. Clin Sci (Lond). 2008;114(2):149-55. KQ1E13, KQ2E13, KQ3E5, KQ4E13, KQ5E13. [pmid: 17868037].
442 Soerensen KV, Thorning TK, Astrup A, et al. Effect of dairy calcium from cheese and milk on fecal fat excretion, blood lipids, and appetite in young men. Am J Clin Nutr. 2014;99(5):984-91. KQ6E5, KQ7E5. [pmid: 24622806].
443 Spinneker A, Egert S, Gonzalez-Gross M, et al. Lipid, lipoprotein and apolipoprotein profiles in European adolescents and its associations with gender, biological maturity and body fat--the HELENA Study. Eur J Clin Nutr. 2012;66(6):727-35. KQ3E6. [pmid: 22252104].
444 Stakos DA, Papaioannou HI, Angelidou I, et al. Plasma leptin and adiponectin concentrations correlate with cardiometabolic risk and systemic inflammation in healthy, non-obese children. J Pediatr Endocrinol Metab. 2014;27(42067):221-8. KQ3E6, KQ4E6. [pmid: 24150199].
445 Stefanutti C, Vivenzio A, Di Giacomo S, et al. Aorta and coronary angiographic follow-up of children with severe hypercholesterolemia treated with low-density lipoprotein apheresis. Transfusion. 2009;49(7):1461-70. KQ6E5, KQ7E5. [pmid: 19389031].
446 Stein EA. Statins and children: whom do we treat and when?. Circulation. 2007;116(6):594-5. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 17679628].
447 Steiner NJ, Neinstein LS, Pennbridge J. Hypercholesterolemia in adolescents: effectiveness of screening strategies based on selected risk factors. Pediatrics. 1991;88(2):269-75. KQ1E13, KQ2E13, KQ3E10, KQ4E13, KQ5E13. [pmid: 1861925].
448 Stephens MB, Reamy BV, Primary Care Education Research Learning Network, et al. A novel approach using an electronic medical record to identify children and adolescents at risk for dyslipidemia: a study from the Primary Care Education and Research Learning (PEARL) network. J Am Board Fam Med. 2008;21(4):356-7. KQ3E6. [pmid: 18612063].
449 Stock J. Controversies in dyslipidaemia management. Atherosclerosis. 2012;221(2):321-4. KQ6E2, KQ7E2. [pmid: 22305261].
450 Stoedefalke K. Effects of exercise training on blood lipids and lipoproteins in children and adolescents. J Sports Sci Med. 2007;6(3):313-318. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E5, KQ6E2, KQ7E2. [pmid: 24149417].
451 Stuhldreher WL, Orchard TJ, Donahue RP, et al. Cholesterol screening in childhood: sixteen-year Beaver County Lipid Study experience. J Pediatr. 1991;119(4):551-6. KQ3E13. [pmid: 1919885].
452 Sudhop T, Reber M, Tribble D, et al. Changes in cholesterol absorption and cholesterol synthesis caused by ezetimibe and/or simvastatin in men. J Lipid Res. 2009;50(10):2117-23. KQ6E5, KQ7E5. [pmid: 19380898].
453 Sultan SM, Schupf N, Dowling MM, et al. Review of lipid and lipoprotein(a) abnormalities in childhood arterial ischemic stroke. Int J Stroke. 2014;9(1):79-87. KQ8E2. [pmid: 24148253].
454 Sun C, Pezic A, Tikellis G, et al. Effects of school-based interventions for direct delivery of physical activity on fitness and cardiometabolic markers in children and adolescents: a systematic review of randomized controlled trials. Obesity Rev. 2013;14(10):818-38. KQ6E5, KQ7E5.
455 Sundaram ME, Berg RL, Economos C, et al. The relationship between childhood BMI and adult serum cholesterol, LDL, and ankle brachial index. Clin Med Res. 2014;12(42006):33-9. KQ8E5. [pmid: 24415747].
456 Superko HR, Garrett BC, King SB, et al. Effect of combination nicotinic acid and gemfibrozil treatment on intermediate density lipoprotein, and subclasses of low density lipoprotein and high density lipoprotein in patients with combined hyperlipidemia. Am J Cardiol. 2009;(3):387-92. KQ6E5, KQ7E5. [pmid: 19166694].
457 Sveger T, Flodmark CE, Nordborg K, et al. Hereditary dyslipidemias and combined risk factors in children with a family history of premature coronary artery disease. Arch Dis Child. 2000;82(4):292-6. KQ3E13. [pmid: 10735834].
458 Tan AT, Low LP, Lim CH, et al. Effects of rosuvastatin on low-density lipoprotein cholesterol and plasma lipids in Asian patients with hypercholesterolemia. J Atheroscler Thromb. 2009;16(4):509-16. KQ6E5, KQ7E5. [pmid: 19729865].
459 Tapola NS, Lyyra ML, Kolehmainen RM, et al. Safety aspects and cholesterol-lowering efficacy of chitosan tablets. J Am Coll Nutr. 2008;27(1):22-30. KQ6E5, KQ7E5. [pmid: 18460478].
460 Task Force for the management of dyslipidaemias of the European Society of Cardiology and the European Atherosclerosis Society, Catapano AL, Reiner Z, et al. ESC/EAS Guidelines for the management of dyslipidaemias: the Task Force for the management of dyslipidaemias of the European Society of Cardiology (ESC) and the European Atherosclerosis Society (EAS). Atherosclerosis. 2011;(1):S1-44. KQ6E2, KQ7E2. [pmid: 21723445].
461 Teber S, Deda G, Akar N, et al. Lipoprotein (a) levels in childhood arterial ischemic stroke. Clin Appl Thromb Hemost. 2010;16(2):214-7. KQ8E13. [pmid: 19752039].
462 Tekin N, Ersoy B, Coskun S, et al. Ambulatory blood pressure parameters in office normotensive obese and non-obese children: relationship with insulin resistance and atherosclerotic markers. Med Princ Pract. 2014;23(2):154-9. KQ3E6, KQ4E6. [pmid: 24247272].
463 Telford RD, Cunningham RB, Waring P, et al. Physical education and blood lipid concentrations in children: the LOOK randomized cluster trial. PLoS ONE. 2013;(10). KQ6E5, KQ7E5. [pmid: 24204594].
464 Terai N, Spoerl E, Fischer S, et al. Statins affect ocular microcirculation in patients with hypercholesterolaemia. Acta Ophthalmol. 2011;89(6):e500-4. KQ7E5. [pmid: 21457486].
465 Teramoto T, Shirakawa M, Kikuchi M, et al. Efficacy and safety of the cholesteryl ester transfer protein inhibitor anacetrapib in Japanese patients with dyslipidemia. Atherosclerosis. 2013;230(1):52-60. KQ6E5, KQ7E5. [pmid: 23958252].
466 Tershakovec AM, Jawad AF, Stallings VA, et al. Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention. J Pediatr. 1998;133(1):28-34. KQ3E13. [pmid: 9672506].
467 Theuwissen E, Mensink RP. Simultaneous intake of beta-glucan and plant stanol esters affects lipid metabolism in slightly hypercholesterolemic subjects. J Nutr. 2007;(3):583-8. KQ6E5, KQ7E5. [pmid: 17311944].
468 Thomas NE, Davies B, Baker JS, et al. Lipoprotein(a) in healthy Welsh schoolchildren aged 12-13 years. Arch Dis Child. 2009;94(12):998-9. KQ1E13, KQ2E13, KQ3E7, KQ4E13, KQ5E13. [pmid: 19933615].
469 Thomas NE, Jasper M, Williams DR, et al. Secular trends in established and novel cardiovascular risk factors in Welsh 12-13 year olds: a comparison between 2002 and 2007. Ann Hum Biol. 2011;38(1):22-7. KQ3E9, KQ4E13. [pmid: 20450386].
470 Thompson GR, Catapano A, Saheb S, et al. Severe hypercholesterolaemia: therapeutic goals and eligibility criteria for LDL apheresis in Europe. Curr Opin Lipidol. 2010;21(6):492-8. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 20935563].
471 Thorp AA, Howe PR, Mori TA, et al. Soy food consumption does not lower LDL cholesterol in either equol or nonequol producers. Am J Clin Nutr. 2008;(2):298-304. KQ6E5, KQ7E5. [pmid: 18689364].
472 Tobisch B, Blatniczky L, Barkai L. Cardiometabolic risk factors and insulin resistance in obese children and adolescents: relation to puberty. Pediatr Obes. 2013;10(1):37-44. KQ3E4. [pmid: 24227418].
473 Todd DM, Walsh R, Tran M, et al. Cardiovascular risk factors in suburban American late-adolescents: a cross-sectional, community-based study. Ann Clin Lab Sci. 2012;42(4):375-83. KQ3E6. [pmid: 23090733].
474 Togashi K, Masuda H, Iguchi K. Effect of diet and exercise treatment for obese Japanese children on abdominal fat distribution. Res Sports Med. 2010;18(1):62-70. KQ6E5, KQ7E5. [pmid: 20391247].
475 Tokarev SA, Buganov AA. Evaluation and prognosis of non-infectious risk in children in dependence on age and period of living in the Far North. Alaska Med. 2007;49(2 Suppl):142-4. KQ3E4, KQ4E6. [pmid: 17929624].
476 Torres MD, Tormo MA, Campillo C, et al. Etiologic and cardiovascular risk factors in obese children from Extremadura in Spain. Their relationship with insulin resistance and plasma adipocytokine levels. Rev Esp Cardiol. 2008;61(9):923-9. KQ3E6. [pmid: 18775233].
477 Toth PP, Ballantyne CM, Davidson MH, et al. Changes in prescription patterns before and after reporting of the Ezetimibe and Simvastatin in Hypercholesterolemia Enhances Atherosclerosis Regression trial (ENHANCE) results and expected effects on low-density lipoprotein-cholesterol reduction. J Clin Lipidol. 2012;6(2):180-91. KQ6E5, KQ7E5. [pmid: 22385552].
478 Tresaco B, Moreno LA, Ruiz JR, et al. Truncal and abdominal fat as determinants of high triglycerides and low HDL-cholesterol in adolescents. Obesity (Silver Spring). 2009;17(5):1086-91. KQ3E6. [pmid: 19180070].
479 Tribble DL, Farnier M, Macdonell G, et al. Effects of fenofibrate and ezetimibe, both as monotherapy and in coadministration, on cholesterol mass within lipoprotein subfractions and low-density lipoprotein peak particle size in patients with mixed hyperlipidemia. Metabolism. 2008;(6):796-801. KQ6E5, KQ7E5. [pmid: 18502262].
480 Tseng ML, Ho CC, Chen SC, et al. A simple method for increasing levels of high-density lipoprotein cholesterol: a pilot study of combination aerobic- and resistance-exercise training. Int J Sport Nutr Exerc Metab. 2013;23(3):271-81. KQ6E5, KQ7E5. [pmid: 23166203].
481 Twisk JW, Kemper HC, Mellenbergh GJ, et al. Relation between the longitudinal development of lipoprotein levels and lifestyle parameters during adolescence and young adulthood. Ann Epidemiol. 1996;6(3):246-56. KQ3E13. [pmid: 8827160].
482 Twisk JW, Kemper HC, van Mechelen W, et al. Tracking of risk factors for coronary heart disease over a 14-year period: a comparison between lifestyle and biologic risk factors with data from the Amsterdam Growth and Health Study. Am J Epidemiol. 1997;145(10):888-98. KQ3E13. [pmid: 9149660].
483 Twisk JW, Kemper HC, Van Mechelen W, et al. Clustering of risk factors for coronary heart disease. The longitudinal relationship with lifestyle. Ann Epidemiol. 2001;11(3):157-65. KQ3E13. [pmid: 11248580].
484 Tzeng TB, Schneck DW, Birmingham BK, et al. Population pharmacokinetics of rosuvastatin: implications of renal impairment, race, and dyslipidaemia. Curr Med Res Opin. 2008;24(9):2575-85. KQ6E5, KQ7E5. [pmid: 18674408].
485 Upadhyay UD, Waddell EN, Young S, et al. Prevalence, awareness, treatment, and control of high LDL cholesterol in New York City, 2004. Prev Chronic Dis. 2010;7(3):A61. KQ3E5, KQ4E5. [pmid: 20394700].
486 Urbina EM, Khoury PR, McCoy CE, et al. Triglyceride to HDL-C ratio and increased arterial stiffness in children, adolescents, and young adults. Pediatrics. 2013;131(4):e1082-90. KQ3E9. [pmid: 23460684].
487 Van Biervliet JP, Vercaemst R, De Keersgieter W, et al. Evolution of lipoprotein patterns in newborns. Acta Paediatr Scand. 1980;69(5):593-6. KQ3E13. [pmid: 7234379].
488 Van Biervliet JP, Vinaimont N, Caster H, et al. A screening procedure for dyslipoproteinemia in the newborn. Apoprotein quantitation on dried blood spots. Clin Chim Acta. 1982;120(2):191-200. KQ3E13. [pmid: 7067144].
489 van Stiphout WA, Hofman A, de Bruijn AM, et al. Distributions and determinants of total and high-density lipoprotein cholesterol in Dutch children and young adults. Prev Med. 1985;14(2):169-80. KQ1E13, KQ2E13, KQ3E7, KQ4E7, KQ5E13. [pmid: 4048079].
490 Verduci E, Agostoni C, Radaelli G, et al. Blood lipids profile in hyperlipidemic children undergoing different dietary long chain polyunsaturated supplementations: a preliminary clinical trial. Int J Food Sci Nutr. 2013;(0). KQ6E5, KQ7E5. [pmid: 24228803].
491 Vieira Cunha Lima SC, Oliveira Lyra C, Galvao Bacurau Pinheiro L, et al. Association between dyslipidemia and anthropometric indicators in adolescents. Nutr Hosp. 2011;26(2):304-10. KQ1E13, KQ2E4, KQ3E4, KQ4E4, KQ5E13. [pmid: 21666967].
492 Viggiano D, De Filippo G, Rendina D, et al. Screening of metabolic syndrome in obese children: a primary care concern. J Pediatr Gastroenterol Nutr. 2009;49(3):329-34. KQ3E6. [pmid: 19590449].
493 Vinci SR, Rifas-Shiman SL, Cheng JK, et al. Cholesterol testing among children and adolescents during health visits. JAMA. 2014;311(17):1804-7. KQ3E6. [pmid: 24794376].
494 Vizcaino VM, Aguilar FS, Martinez MS, et al. Association of adiposity measures with blood lipids and blood pressure in children aged 8-11 years. Acta Paediatr. 2007;96(9):1338-42. KQ3E6. [pmid: 17718788].
495 Vobecky JS, David P, Vobecky J. Dietary habits in relation to tracking of cholesterol level in young adolescents: a nine-year follow-up. Ann Nutr Metab. 1988;32(42130):312-23. KQ3E13. [pmid: 3254688].
496 Volek JS, Phinney SD, Forsythe CE, et al. Carbohydrate restriction has a more favorable impact on the metabolic syndrome than a low fat diet. Lipids. 2009;(4):297-309. KQ6E5, KQ7E5. [pmid: 19082851].
497 Vrablik M, Dobiasova M, Zlatohlavek L, et al. Biomarkers of cardiometabolic risk in obese/overweight children: effect of lifestyle intervention. Physiol Res. 2014. KQ6E5, KQ7E5. [pmid: 25157663].
498 Wadowski SJ, Karp RJ, Murray-Bachmann R, et al. Family history of coronary artery disease and cholesterol: screening children in a disadvantaged inner-city population. Pediatrics. 1994;93(1):109-13. KQ3E7. [pmid: 8265303].
499 Wallner A, Hirz A, Schober E, et al. Evolution of cardiovascular risk factors among 18-year-old males in Austria between 1986 and 2005. Wien Klin Wochenschr. 2010;122(42130):152-8. KQ3E6, KQ4E6. [pmid: 20361378].
500 Ward SD, Melin JR, Lloyd FP, et al. Determinants of plasma cholesterol in children--a family study. Am J Clin Nutr. 33(1):63-70. KQ3E13. [pmid: 7355782].
501 Wasay M, Saadatnia M, Venketasubramanian N, et al. Predictors of cerebral venous thrombosis and arterial ischemic stroke in young Asian women. J Stroke Cerebrovasc Dis. 2012;21(8):689-94. KQ8E5. [pmid: 21511496].
502 Weghuber D, Widhalm K. Effect of 3-month treatment of children and adolescents with familial and polygenic hypercholesterolaemia with a soya-substituted diet. Br J Nutr. 2008;99(2):281-6. KQ6E5, KQ7E5. [pmid: 17697400].
503 Wei M, Xiong P, Zhang L, et al. Perilla oil and exercise decrease expressions of tumor necrosis factor-alpha, plasminogen activator inhibitor-1 and highly sensitive C-reactive protein in patients with hyperlipidemia. J Tradit Chin Med. 2013;(2):170-5. KQ6E4, KQ7E4. [pmid: 23789212].
504 Weiss R, Otvos JD, Sinnreich R, et al. The triglyceride to high-density lipoprotein-cholesterol ratio in adolescence and subsequent weight gain predict nuclear magnetic resonance-measured lipoprotein subclasses in adulthood. J Pediatr. 2011;158(1):44-50. KQ1E13, KQ2E6, KQ3E13, KQ4E13, KQ5E13. [pmid: 20801459].
505 White J, Jago R. Fat distribution, physical activity and cardiovascular risk among adolescent girls. Nutr Metab Cardiovasc Dis. 2013;23(3):189-95. KQ3E6. [pmid: 22397881].
506 Wierzbicki AS, Viljoen A. Hyperlipidaemia in paediatric patients: the role of lipid-lowering therapy in clinical practice. Drug Safety. 2010;33(2):115-25. KQ6E2, KQ7E2. [pmid: 20082538].
507 Wiesen J, Adkins M, Fortune S, et al. Evaluation of pediatric patients with mild-to-moderate hypertension: yield of diagnostic testing. Pediatrics. 2008;122(5):e988-93. KQ3E5. [pmid: 18977966].
508 Wijnstok NJ, Twisk JW, Young IS, et al. Inflammation markers are associated with cardiovascular diseases risk in adolescents: the Young Hearts project 2000. J Adolesc Health. 2010;47(4):346-51. KQ1E13, KQ2E13, KQ3E6, KQ4E13, KQ5E13. [pmid: 20864003].
509 Wilcken DE, Blades BL, Dudman NP. A neonatal screening approach to the detection of familial hypercholesterolaemia and family-based coronary prevention. J Inherit Metab Dis. 1988:87-90. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 3141689].
510 Willi SM, Hirst K, Jago R, et al. Cardiovascular risk factors in multi-ethnic middle school students: the HEALTHY primary prevention trial. Pediatr Obes. 2012;7(3):230-9. KQ3E9, KQ4E6. [pmid: 22461375].
511 Williams CL, Bollella M, Spark A, et al. Soluble fiber enhances the hypocholesterolemic effect of the step I diet in childhood. J Am Coll Nutr. 1995;14(3):251-7. KQ1E13, KQ2E13, KQ3E13, KQ4E13, KQ5E13. [pmid: 8586774].
512 Williams DM, Fraser A, Sayers A, et al. Associations of childhood 25-hydroxyvitamin D2 and D3 and cardiovascular risk factors in adolescence: prospective findings from the Avon Longitudinal Study of Parents and Children. Eur J Prev Cardiol. 2014;21(3):281-90. KQ3E6. [pmid: 23185083].
513 Williams RR, Hunt SC, Barlow GK, et al. Prevention of familial cardiovascular disease by screening for family history and lipids in youths. Clinical chemistry. 1992;38(8B Pt 2):1555-60. KQ3E13. [pmid: 1643739].
514 Wilson DP, Gidding SS. Learning more about dyslipidemia in childhood. J Pediatr. 2013;164(3):442-4. KQ1E2. [pmid: 24373576].
515 Wong ND, Hei TK, Qaqundah PY, et al. Television viewing and pediatric hypercholesterolemia. Pediatrics. 1992;90(1 Pt 1):75-9. KQ3E13. [pmid: 1614784].
516 Yeste D, Chacon P, Clemente M, et al. Ezetimibe as monotherapy in the treatment of hypercholesterolemia in children and adolescents. J Pediatr Endocrinol Metab. 2009;22(6):487-492. KQ6E9, KQ7E9. [pmid: 19694195].
517 Yokokawa H, Yasumura S, Tanno K, et al. Serum low-density lipoprotein to high-density lipoprotein ratio as a predictor of future acute myocardial infarction among men in a 2.7-year cohort study of a Japanese northern rural population. J Atheroscler Thromb. 2011;18(2):89-98. KQ3E6, KQ4E6, KQ8E6. [pmid: 20972352].
518 Yoshinaga M, Sameshima K, Tanaka Y, et al. Association between the number of cardiovascular risk factors and each risk factor level in elementary school children. Circ J. 2008;72(10):1594-7. KQ3E6. [pmid: 18756035].
519 Yu CC, Li AM, Chan KO, et al. Orlistat improves endothelial function in obese adolescents: a randomised trial. J Paediatr Child Health. 2013;49(11):969-75. KQ6E5, KQ7E5. [pmid: 23735004].
520 Zachariah JP, Johnson PK. Pediatric lipid management: an earlier approach. Endocrinol Metab Clin North Am. 2014;43(4):981-92. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2. [pmid: 25432392].
521 Zung A, Shachar S, Zadik Z, et al. Soy-derived isoflavones treatment in children with hypercholesterolemia: a pilot study. J Pediatr Endocrinol Metab. 2010;(42006):133-41. KQ6E9, KQ7E6. [pmid: 20432816].