# Ongoing Studies

We identified one potentially relevant ongoing RCT through four registries: ClinicalTrials.gov (http://clinicaltrials.gov), Current Controlled Trials (http://www.controlled-trials.com), Australian New Zealand Clinical Trials Registry (http://www.anzctr.org.au) and the World Health Organization's International Clinical Trials Registry Platform (http://www.who.int/ictrp). We restricted our searches to dyslipidemia in children that met our inclusion criteria for any key question.

We found a study evaluating statins in obese teenagers with dyslipidemia that was completed in 2013 but whose results are not yet published.78 The obese teenagers with dyslipidemia were randomly assigned to receive either 10 mg of atorvastatin every day for 1 year or placebo. The main endpoint was change in carotid intima media thickness. Lipid profiles were measured at baseline, 6 months, and 12 months after the intervention.