# Detailed Methods

## Search Strategy

Sources searched:

Cochrane Central Register of Controlled Clinical Trials, via Wiley

Medline, via Ovid

PubMed, publisher-supplied

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- adj# = adjacent within x number of words
- pt = publication type
- * = truncation
- ae = adverse effects
- ci = chemically induced
- de=drug effects
- mo=mortality
- nm = name of substance

### Cochrane Central Register of Controlled Clinical Trials

#1 (hyperlipid*emia*:ti,ab,kw or dyslipid*emia*:ti,ab,kw or hypercholesterol*emia*:ti,ab,kw or hyperlipoprotein*emia*:ti,ab,kw or hypertriglycerid*emia*:ti,ab,kw or dysbetalipoprotein*emia*:ti,ab,kw)
#2 (familial next hypercholesterol*emi*):ti,ab,kw or (familial next hyperlipid*emi*):ti,ab,kw or (essential next hypercholesterol*emi*):ti,ab,kw or (familial near/3 apolipoprotein):ti,ab,kw
#3 “heterozygous fh”:ti,ab,kw or “homozygous fh”:ti,ab,kw
#4 (lipid next disorder*):ti,ab,kw or (lipid near/3 dysfunction*):ti,ab,kw
#5 (high or elevated or abnormal or aberr*):ti,ab,kw near/3 (cholesterol or lipid* or LDL*):ti,ab,kw
#6 (low or decrease* or deficien* or abnormal or aberr*):ti,ab,kw near/3 HDL*:ti,ab,kw
#7 (cholesterol or lipid* or lipoprotein* or LDL* or HDL*):ti,ab,kw near/3 (detect* or measure* or check* or assess* or analyz* or analys* or test* or panel* or profile*):ti,ab,kw
#8 (fasting or nonfasting or non-fasting):ti,ab,kw next (lipid* or lipoprotein* or cholesterol):ti,ab,kw
#9 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8
#10 (child*:ti,ab,kw or adolesc*:ti,ab,kw or teen:ti,ab,kw or teens:ti,ab,kw or teenage*:ti,ab,kw or youth:ti,ab,kw or youths:ti,ab,kw or p*ediatric*:ti,ab,kw)
#11 #9 and #10 from 2007 to 2014, in Trials

### MEDLINE

#### Dyslipidemia screening, screening harms

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <June 2, 2015>, Ovid MEDLINE(R) Daily Update <June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. or/1-23
25. Cholesterol/bl
26. Triglycerides/bl
27. Lipoproteins/bl
28. Cholesterol, HDL/
29. Cholesterol, LDL/
30. Apolipoprotein B-100/
31. Apolipoprotein B 100.ti,ab.
32. apob 100.ti,ab.
33. apo b 100.ti,ab.
34. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
35. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
36. or/25-35
37. Mass screening/
38. screen$.ti,ab.
39. ((cholesterol or lipid$ or lipoprotein$ or LDL$ or HDL$) adj3 (detect$ or measur$ or check$ or assess$ or analyz$ or analys$ or test$ or panel$ or profile$)).ti,ab.
40. (fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
41. (non-fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
42. 37 or 38 or 39 or 40 or 41
43. (24 or 36) and 42
44. adolescent/ or child/ or young adult/
45. 43 and 44
46. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
47. 43 and 46
48. limit 47 to (“in data review” or in process or “pubmed not medline”)
49. 45 or 48
50. limit 49 to english language
51. limit 50 to yr=“2007 -Current”
52. remove duplicates from 51

#### Dx yield/accuracy

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < June 2, 2015>, Ovid MEDLINE(R) Daily Update < June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. or/1-23
25. Cholesterol/bl
26. Triglycerides/bl
27. Lipoproteins/bl
28. Cholesterol, HDL/
29. Cholesterol, LDL/
30. Apolipoprotein B-100/
31. Apolipoprotein B 100.ti,ab.
32. apob 100.ti,ab.
33. apo b 100.ti,ab.
34. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
35. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
36. ((cholesterol or lipid$ or lipoprotein$ or LDL$ or HDL$) adj3 (detect$ or measur$ or check$ or assess$ or analyz$ or analys$ or test$ or panel$ or profile$)).ti,ab.
37. (fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
38. (non-fasting adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab.
39. or/25-38
40. “Sensitivity and Specificity”/
41. “Predictive Value of Tests”/
42. ROC Curve/
43. False Negative Reactions/
44. False Positive Reactions/
45. Diagnostic Errors/
46. “Reproducibility of Results”/
47. Reference Values/
48. Reference Standards/
49. Observer Variation/
50. Receiver operat$.ti,ab.
51. ROC curve$.ti,ab.
52. sensitivit$.ti,ab.
53. specificit$.ti,ab.
54. predictive value.ti,ab.
55. accuracy.ti,ab.
56. false positive$.ti,ab.
57. false negative$.ti,ab.
58. miss rate$.ti,ab.
59. error rate$.ti,ab.
60. 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59
61. (24 or 39) and 60
62. adolescent/ or child/ or young adult/
63. 61 and 62
64. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
65. 61 and 64
66. limit 65 to (“in data review” or in process or “pubmed not medline”)
67. 63 or 66
68. limit 67 to (english language and yr=“2007 -Current”)
69. remove duplicates from 68

#### Drug Tx Harms

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < June 2, 2015>, Ovid MEDLINE(R) Daily Update < June 2, 2015>

Search Strategy:

--------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
25. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
26. or/1-25
27. hypolipidemic agents/ or bezafibrate/ or butoxamine/ or clofenapate/ or clofibrate/ or clofibric acid/ or colestipol/ or fenofibrate/ or gemfibrozil/ or halofenate/ or meglutol/ or nafenopin/ or niacin/ or niceritrol/ or pyridinolcarbamate/ or simvastatin/ or triparanol/
28. anticholesteremic agents/ or azacosterol/ or chitosan/ or cholestyramine resin/ or clofibrate/ or clofibric acid/ or lovastatin/ or meglutol/ or pravastatin/ or probucol/ or simvastatin/ or “trans-1,4-bis(2-chlorobenzaminomethyl)cyclohexane dihydrochloride”/
29. hydroxymethylglutaryl-coa reductase inhibitors/ or lovastatin/
30. 3-hydroxy-3-methylglutaryl coenzyme A reductase inhibitor$.ti,ab.
31. hydroxymethylglutaryl coa reductase inhibitor$.ti,ab.
32. hydroxymethylglutaryl coa inhibitor$.ti,ab.
33. hydroxymethylglutaryl coenzyme a reductase.ti,ab.
34. hydroxymethylglutaryl coenzyme a inhibitor$.ti,ab.
35. hmg coa reductase inhibitor$.ti,ab.
36. hmg coa inhibitor$.ti,ab.
37. atorvastatin.ti,ab.
38. fluvastatin.ti,ab.
39. lovastatin.ti,ab.
40. pitavastatin.ti,ab.
41. pravastatin.ti,ab.
42. rosuvastatin.ti,ab.
43. simvastatin.ti,ab.
44. hypolipidemic$.ti,ab.
45. anticholesteremic$.ti,ab.
46. antilipidemic.ti,ab.
47. statin$.ti,ab.
48. lipid lower$.ti,ab.
49. (treat$ or therap$ or medicat$).ti.
50. or/27-49
51. ae.fs.
52. “Drug-Related Side Effects and Adverse Reactions”/
53. Mortality/
54. Morbidity/
55. Death/
56. mo.fs.
57. (harm or harms or harmful or harmed).ti,ab.
58. (adverse adj (effect$ or event$ or outcome$)).ti,ab.
59. safety.ti,ab.
60. overtreat$.ti,ab.
61. (death or deaths).ti,ab.
62. drug-induced liver injury/
63. drug-induced liver injury, chronic/
64. Liver Neoplasms/ci
65. Liver/de
66. Liver failure/ci
67. Liver failure, acute/ci
68. (liver adj3 (injur$ or dysfunction$ or failure$)).ti,ab.
69. (Hepatic adj3 (injur$ or dysfunction$ or failure$)).ti,ab.
70. (transaminase adj3 (elevat$ or abnormal$ or dysfunction$)).ti,ab.
71. Liver enzyme$.ti,ab.
72. alanine transaminase.ti,ab.
73. alanine aminotransferase.ti,ab.
74. aspartate transaminase.ti,ab.
75. aspartate aminotransferase.ti,ab.
76. (AST or ALT).ti,ab.
77. Muscular Diseases/ci
78. Myositis/
79. Myositis.ti,ab.
80. Dermatomyositis/
81. Dermatomyositis.ti,ab.
82. myositis ossificans.ti,ab.
83. Rhabdomyolysis/
84. rhabdomyolysis.ti,ab.
85. myotoxicity.ti,ab.
86. myopathy.ti,ab.
87. muscle enzyme$.ti,ab.
88. (creatine adj3 (high or elevat$ or abnormal$)).ti,ab.
89. Myalgia/
90. myalgia.ti,ab.
91. or/51-90
92. 26 and 50 and 91
93. adolescent/ or child/ or young adult/
94. 92 and 93
95. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
96. 92 and 95
97. limit 96 to (“in data review” or in process or “pubmed not medline”)
98. 94 or 97
99. limit 98 to english language
100. limit 99 to yr=“2007 -Current”

#### Drug and lifestyle treatment efficacy

Database: Ovid MEDLINE(R) without Revisions <1996 to June Week 1 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < June 2, 2015>, Ovid MEDLINE(R) Daily Update < June 2, 2015>

Search Strategy:

---------------------------------------------------------------------------------

1. Hyperlipidemias/
2. Dyslipidemias/
3. Hypercholesterolemia/
4. Lipid Metabolism Disorders/
5. Hyperlipoproteinemias/
6. Hypertriglyceridemia/
7. Hyperlipoproteinemia Type II/
8. Hyperlipidemia, Familial Combined/
9. Hypobetalipoproteinemias/
10. Abetalipoproteinemia/
11. hyperlipid?emia$.ti,ab.
12. dyslipid?emia$.ti,ab.
13. hypercholesterol?emia$.ti,ab.
14. hyperlipoprotein?emia$.ti,ab.
15. hypertriglycerid?emia$.ti,ab.
16. dysbetalipoprotein?emia$.ti,ab.
17. familial hypercholesterol$emi*.ti,ab.
18. familial hyperlipid?emi*.ti,ab.
19. essential hypercholesterol?emi*.ti,ab.
20. (familial adj3 apolipoprotein).ti,ab.
21. heterozygous fh.ti,ab.
22. homozygous fh.ti,ab.
23. lipid disorder$.ti,ab.
24. ((high or elevated or abnormal or aberr$) adj3 (cholesterol or lipid$ or LDL$)).ti,ab.
25. ((low or decrease$ or deficien$ or abnormal or aberr$) adj3 HDL$).ti,ab.
26. or/1-25
27. hypolipidemic agents/ or bezafibrate/ or butoxamine/ or clofenapate/ or clofibrate/ or clofibric acid/ or colestipol/ or fenofibrate/ or gemfibrozil/ or halofenate/ or meglutol/ or nafenopin/ or niacin/ or niceritrol/ or pyridinolcarbamate/ or simvastatin/ or triparanol/
28. anticholesteremic agents/ or azacosterol/ or chitosan/ or cholestyramine resin/ or clofibrate/ or clofibric acid/ or lovastatin/ or meglutol/ or pravastatin/ or probucol/ or simvastatin/ or “trans-1,4-bis(2-chlorobenzaminomethyl)cyclohexane dihydrochloride”/
29. hydroxymethylglutaryl-coa reductase inhibitors/ or lovastatin/
30. 3-hydroxy-3-methylglutaryl coenzyme A reductase inhibitor$.ti,ab.
31. hydroxymethylglutaryl coa reductase inhibitor$.ti,ab.
32. hydroxymethylglutaryl coa inhibitor$.ti,ab.
33. hydroxymethylglutaryl coenzyme a reductase.ti,ab.
34. hydroxymethylglutaryl coenzyme a inhibitor$.ti,ab.
35. hmg coa reductase inhibitor$.ti,ab.
36. hmg coa inhibitor$.ti,ab.
37. atorvastatin.ti,ab.
38. fluvastatin.ti,ab.
39. lovastatin.ti,ab.
40. pitavastatin.ti,ab.
41. pravastatin.ti,ab.
42. rosuvastatin.ti,ab.
43. simvastatin.ti,ab.
44. hypolipidemic$.ti,ab.
45. anticholesteremic$.ti,ab.
46. antilipidemic.ti,ab.
47. statin$.ti,ab.
48. lipid lower$.ti,ab.
49. (treat$ or therap$ or medicat$).ti.
50. or/27-49
51. diet/
52. diet, carbohydrate-restricted/
53. diet, fat-restricted/
54. diet, mediterranean/
55. diet, protein-restricted/
56. diet, reducing/
57. diet, vegetarian/
58. caloric restriction/
59. portion size/
60. Food habits/
61. Diet Therapy/
62. Soybean Proteins/
63. Fatty Acids, Omega-3/
64. Phytosterols/
65. Dietary Fiber/
66. Dietary Protein/
67. Dietary Carbohydrates/
68. Dietary Fats/
69. diet$.ti,ab.
70. ((reduce$ or reduction$ or manipulat$ or restrict$) adj3 (fat$ or carbohydrate$ or cholesterol)).ti,ab.
71. low fat.ti,ab.
72. lowfat.ti,ab.
73. fiber.ti,ab.
74. omega 3 fatty acid$.ti,ab.
75. n 3 polyunsaturated fatty acid$.ti,ab.
76. n 3 fatty acid$.ti,ab.
77. n 3 pufa.ti,ab.
78. soy$ protein$.ti,ab.
79. plant stanol$.ti,ab.
80. esters.ti,ab.
81. 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80
82. Exercise/
83. Exercise therapy/
84. Motor activity/
85. Physical fitness/
86. Plyometric Exercise/
87. Physical Conditioning, Human/
88. Running/
89. Jogging/
90. Swimming/
91. Walking/
92. Resistance training/
93. (exercise or exercising or exercises).ti,ab.
94. physical fitness.ti,ab.
95. physical conditioning.ti,ab.
96. (running or jog$ or swim$ or walk$).ti,ab.
97. (lifestyle$ or life style$).ti,ab.
98. 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97
99. 26 and (50 or 81 or 98)
100. Hyperlipidemias/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention & Control, Therapy]
101. Dyslipidemias/dh, dt, pc, th
102. Hypercholesterolemia/dh, dt, pc, th
103. Lipid Metabolism Disorders/dh, dt, pc, th
104. Hyperlipoproteinemias/dh, dt, pc, th
105. Hypertriglyceridemia/dh, dt, pc, th
106. Hyperlipoproteinemia Type II/dh, dt, pc, th
107. Hyperlipidemia, Familial Combined/dh, dt, pc, th
108. Hypobetalipoproteinemias/dh, dt, pc, th
109. Abetalipoproteinemia/dh, dt, pc, th
110. 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109
111. adolescent/ or child/ or young adult/
112. 110 and 111
113. (child$ or teen or teens or teenage$ or adolescen$ or youth or youths or young people or pediatric$ or paediatric$).ti,ab.
114. 110 and 113
115. limit 114 to (“in data review” or in process or “pubmed not medline”)
116. 112 or 115
117. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
118. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
119. Random$.ti,ab.
120. control groups/ or double-blind method/ or single-blind method/
121. clinical trial$.ti,ab.
122. controlled trial$.ti,ab.
123. meta analy$.ti,ab.
124. 117 or 118 or 119 or 120 or 121 or 122 or 123
125. 116 and 124
126. limit 125 to (english language and yr=“2007 -Current”)
127. remove duplicates from 126

### PubMed search strategy [publisher-supplied references only]

Search | Query
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #10 AND publisher[sb] Filters: Publication date from 2007/01/01 to 2015/06/02; English
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #8 AND #9
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search child*[tiab] OR teen[tiab] OR teens[tiab] OR teenage*[tiab] OR adolescen*[tiab] OR youth[tiab] OR youths[tiab] OR “young people”[tiab] OR pediatric*[tiab] OR paediatric*[tiab]
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 or #2 or #3 or #4 or #5 or #6 or #7
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (fasting[tiab] or non fasting[tiab] OR nonfasting[tiab]) AND (lipid*[tiab] OR lipoprotein*[tiab] OR cholesterol[tiab])
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (lipid[tiab] OR lipids[tiab] OR lipoprotein*[tiab] OR cholesterol[tiab] OR LDL*[tiab] OR HDL*[tiab]) AND (detect*[tiab] OR measur*[tiab] OR check*[tiab] OR assess*[tiab] OR analyz*[tiab] OR analys*[tiab] OR test*[tiab] OR panel*[tiab] OR profile*[tiab])
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (lipid[tiab] OR lipids[tiab] OR lipoprotein*[tiab] OR cholesterol[tiab] OR LDL*[tiab] OR HDL*[tiab]) AND (low[tiab] OR high[tiab] OR elevated[tiab] OR abnormal[tiab] OR aberr*[tiab])
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search lipid disorder*[tiab] OR lipid dysfunction*[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search familial[tiab] AND apolipoprotein[tiab]
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search familial hypercholesterolemia*[tiab] OR familial hypercholesterolaemia*[tiab] OR familial hyperlipidemi*[tiab] OR familial hyperlipidaemi*[tiab] OR essential hypercholesterolemi*[tiab] OR essential hypercholesterolaemi*[tiab] OR heterozygous fh[tiab] OR homozygous fh[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (hyperlipidemia*[tiab] OR hyperlipidaemia*[tiab] OR dyslipidemia*[tiab] OR dyslipidaemia*[tiab] OR hypercholesterolemia*[tiab] OR hypercholesterolaemia*[tiab] OR hyperlipoproteinemia*[tiab] OR hyperlipoproteinaemia*[tiab] OR hypertriglyceridemia*[tiab] OR hypertriglyceridaemia*[tiab] OR dysbetalipoproteinemia*[tiab] OR dysbetalipoproteinaemia*[tiab])

Appendix A Table 1 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the USPSTF methods76 | - Valid random assignment?; - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were measurements equal, valid, and reliable?; - Was there intervention fidelity?; - Was there adequate adherence to the intervention?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there evidence of selective reporting of outcomes?; - Was the device calibration and/or maintenance reported?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)77 | - Was the cohort systematically selected to avoid bias?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Was the outcome of interest not present at baseline?; - Were measurements equal, valid, and reliable?; - Were outcome assessors blinded?; - Was there acceptable followup?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?

Abbreviation: USPSTF=U.S. Preventive Services Task Force.

Appendix A Table 2 Inclusion and Exclusion Criteria

| Included | Excluded
Population | All KQs: Children and adolescents ages 0 to 20 years KQs 1–4: Asymptomatic children and adolescents ages 0 to 20 years KQs 5–8: Children and adolescents ages 0 to 20 years with dyslipidemia not due to familial hypercholesterolemia | KQs 1–4: Children and adolescents with any of the following:; - Known dyslipidemia; - Diagnosis associated with secondary dyslipidemia^*^; - Established family history of familial hypercholesterolemia; KQs 5–8: Children and adolescents with familial hypercholesterolemia
Diseases | KQs 5–8: Dyslipidemia, as defined by the National Cholesterol Education Program (i.e., ≥1 of the following lipid/lipoprotein values, measured either in a nonfasting state followed by fasting or by 2 fasting tests):; - Total cholesterol ≥200 mg/dL (5.2 mmol/L); - LDL cholesterol ≥130 mg/dL (3.4 mmol/L); - Non-HDL cholesterol ≥145 mg/dL (3.8 mmol/L); - HDL cholesterol <40 mg/dL (1 mmol/L); - Triglycerides (ages 0 to 9 years) ≥100 mg/dL (1.1 mmol/L); - Triglycerides (ages 10 to 19 years) ≥130 mg/dL (1.5 mmol/L); Abnormal values are >95th percentile, except for HDL cholesterol, which is <10th percentile. Non-HDL cholesterol includes LDL cholesterol, lipoprotein-a, intermediate-density lipoprotein, and very-low density lipoprotein | KQs 5–8:; - Familial hypercholesterolemia; - Secondary dyslipidemia^*^
Screening interventions | KQs 1–4:; - Lipid panel (fasting or nonfasting lipid measurement, total or LDL cholesterol alone or in combination with other lipid markers); - Comparison with no screening or usual care; - Universal or selective screening strategy (e.g., screening based on body mass index) | KQs 1–4:; - Genetic screening alone; - Cascade screening
Treatments | KQs 5–7:; - Lipid-lowering medications; - Lifestyle modifications, including diet or exercise | KQs 5–7: None
Outcomes | KQs 1, 5, 8:; - MI; - Ischemic stroke; KQ3:; - Diagnostic yield (true positives/number screened); - Positive predictive value (true positives/true positives + false positives); KQ4: All harms (e.g., false-positive or false-negative results, psychosocial effects, overdiagnosis) KQs 2, 6:; - Lipid levels (total, LDL, HDL, and non-HDL cholesterol; triglycerides); - Atherosclerosis markers (carotid intima–media thickness, calcium score, pathological findings); KQ7: All harms from:; - Medications (e.g., adverse events, long-term safety, overtreatment); - Lifestyle modifications (e.g., nutritional, psychosocial) | KQs 1, 5, 8:; - Diabetes; - Metabolic syndrome; - Hypothyroidism; - Renal failure; - Obstructive liver disease; - Nephrotic syndrome; - Lipodystrophy; - Other serum markers (e.g., apolipoprotein A1, C-reactive protein)
Study design | KQs 1, 2: RCTs, CCTs, and systematic reviews KQ3: RCTs, CCTs, systematic reviews, and cohort studies KQs 4, 7: RCTs, CCTs, systematic reviews, cohort studies, observational studies, systematically selected case-series, and qualitative studies KQs 5, 6: RCTs and systematic reviews KQ8: RCTs, CCTs, systematic reviews, cohort studies, registry studies, long-term trial followup, high-quality case-control studies | All KQs: Studies rated as poor quality KQs 1–3, 5, 6, 8: Qualitative studies, case reports, cost-effectiveness studies KQs 1, 2, 5, 6: Cohort studies KQs 4, 7: None
Settings | - Publication date of 2007 to present and studies included in prior USPSTF reviews on this topic; - Conducted in countries with a Human Development Index score of ≥0.9, as defined by the United Nations | Settings not generalizable to primary care

* Secondary causes of dyslipidemia include: renal (chronic renal disease, hemolytic uremic syndrome, nephrotic syndrome); infectious (acute viral or bacterial infections, HIV, hepatitis); hepatic (obstructive liver disease, cholestasis, biliary cirrhosis, Alagille syndrome); inflammatory (systemic lupus erythematosus, juvenile rheumatoid arthritis); storage (glycogen storage disease, Gaucher disease, cystine storage disease, Tay-Sachs disease, Niemann-Pick disease); and other (Kawasaki disease, anorexia nervosa, cancer, previous solid organ transplant, progeria, idiopathic hypercalcemia, Klinefelter syndrome, Werner syndrome, polycystic ovary syndrome, type 1 or 2 diabetes).

Abbreviations: KQ=key question, LDL-C=low-density lipoprotein cholesterol, HDL-C=high-density lipoprotein cholesterol, MI=myocardial infarction, CCT=controlled clinical trial, RCT=randomized, controlled trial, USPSTF=U.S. Preventive Services Task Force, HIV=human immunodeficiency virus.

Appendix A Figure 1 Literature Flow Diagram

^1^ Includes 122 articles that were reviewed for all KQs

^2^ Number of articles that were not included in the prior review: KQ1=0; KQ2= 0; KQ3=7; KQ4= 0; KQ5=0; KQ6=3; KQ7=3; KQ8=1

Appendix Figure 1 is a flow chart that summarizes the search and selection of articles. There were 7,503 citations identified through literature databases. An additional 711 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 7,137 unique citations were screened at the title/abstract stage. The full text of 537 citations were examined for inclusion for one or more of the eight Key Questions.