# Evidence Tables

Evidence Table 1. Case-control studies

Study, Year, Journal | Setting/ Population/ Dates | Cases | Controls | Exposure Assessment and Classification | Important Confounders not Adjusted for | Major findings- or multivariable, adjusted or (MAOR) | Major findings by duration use HRT (MAOR) | Time since last use of HRT (MAOR) | Time since starting HRT | Findings by other sub-group analyses (MAOR) | Comments
Newcomb '95 | Population based | All women with newly diagnosed BCA | Randomly chosen by drivers license lists and a list of Medicare beneficiaries (HCFA) n=3698 | Phone interview. | Good adjustment | 36% case exp HRT, 38% controls exp HRT, ever use HRT: | Any HRT: | Among recent users of HRT (w/in 2 yrs), < 5 yrs duration: 0.82(0.62–1.07) | | ERT: | 15% also used progesterone Increasing time since last use not associated with elevated BCA risk Subgroup analyses for use < or > 10 years showed no interaction with age menopause, BBD, FMH, alcohol, BMI, type menopause.
American Journal of Epidemiology | Wisconsin | n=3130 | Response rate 84% | Type estrogen, dose not evaluated; recent use=within 2 years; HRT=>3 mos consecutive use estrogen +/- prog | | 1.05(0.93–1.18), former use of HRT: | < 2 yrs: | > 5 yrs duration: 0.97(0.79–1.2) | | 0.97 (0.84–1.21) | No clinically or statistically significant finding.
| N.H. | 98% histologically confirmed Post-menopausal | | | | 1.12(0.98–1.29) | 1.02(0.85–1.21) | | | ever use CHRT: | When time since last use, women using HRT had more mammograms, more BBD
| Massachusetts | Overall response 81% Interviewed within 8–21 months of diagnosis | | | | | 2–4 yrs: | | | 1.01 (0.7–1.31) | Quality: good-excellent study
| Maine | | | | | | 1.09(0.89–1.33) | | | former use ERT:
| 4/89-12/91 | | | | | | 5–9 yrs: | | | 1.03 (0.87–1.21)
| | | | | | | 1.02(0.81–1.3) | | | former use CHRT:
| | | | | | | 10–14 yrs: | | | 1.25 (0.84–1.94)
| | | | | | | 0.99(0.74–1.32)
| | | | | | | > 15 yrs:
| | | | | | | 1.11(0.87–1.43)
Stanford '95 | Population based | All White women 50–64 diagnosed with histologically confirmed incident invasive or in situ breast cancer with phone n = 450 with invasive | Residents of King County | Dates | Excellent evaluation/control of confounders | ERT: | ERT: | ERT: | ERT: | OR 19. (1.8–199.4) for increased risk associated with E + P among women with ovaries removed. | Only those who had not died participated
JAMA | King County, Washington | n = 87 in situ | 50–64 years identified through random digit dialing matched within 5 years of age | duration | | 0.9(0.6–1.1 ) | 1–3 mos: 1.1(0.5–2.4) | current: 0.9(0.7–1.3) | < 5 yrs: 1.2(0.7–2.1) | No significant changes or risk associated with estrogen alone or E+ P by invasive vs. in situ disease | A higher proportion of HRT users had mammograms compared to non-users.
| SEER women | Not all post-menopausal | Response rate 73% | brand, dose estrogen or progesterone detailed in-person interview | | Progestin alone: | 4 mos-2.9 yrs: 1.0(0.6–1.6) | < 5 yrs: 0.6(0.3–1.3) | 5–9 yrs: 1.3(0.8–2.2) | | Control of mammography exposure did not alter findings. 12.1% pre-menopausal Increased RR among thinner women (RR 1.8) though not stat sig and not adjusted for other factors - with both ERT and CHRT No interaction with alcohol
| ages 50–64 | 81.4% response rate | | | | 0.5(0.1–2.0) | 3–4.9 yrs: 0.9(0.4–1.8) | > 5 yrs: 0.8(0.5–1.3) | 10–14 yrs: 0.9(0.5–1.5) | | Quality: good
| all Caucasian | | | | | CHRT: | 5–7.9 yrs: 1.2(0.7–2.2) | CHRT: | 15–19 yrs: 0.5(0.3–0.8)
| 1/88- 6/30/90 | | | | | 0.9(0.7–1.3) | 8–11.9 yrs: 0.5(0.3–0.9) | current: 0.9(0.6–1.2) | > 19 yrs: 0.3(0.1–0.9)
| | | | | | | 12–14.9 yrs: 0.5(0.3–0.9) | < 5 yrs: 1.4(0.7–2.7) | CHRT:
| | | | | | | 15–19.9 yrs: 0.5(0.3–1.0) | > 5 yrs: 0.5(0.1–1.7) | <5 yr: 1.0(0.7–1.4)
| | | | | | | > 20 yrs: 1.0(0.5–2.0) | | 5–9 yr: 1.2(0.6–2.2)
| | | | | | | CHRT: | | > 10 yr: 0.3(0.1–0.9)
| | | | | | | 1–3 mos: 1.9(0.7–4.7)
| | | | | | | 4 mos-2.9 yrs: 1.0(0.7–1.6)
| | | | | | | 3–4.9 yrs: 0.6(0.3–1.3)
| | | | | | | 5–7.9 yrs: 1.0(0.4–2.2)
| | | | | | | > 8 yrs: 0.4(0.2–1.0)
Grodstein '97 | Population based | All women who died from this cohort and were post-menopausal and provided information about hormone therapy | 10 controls per case randomly chosen from women alive at the time of the case subjects' death or diagnosis leading to death post-menopausal and free of cancer and/or cardiovascular disease at baseline or before menopause matched by age (2y), age at menopause and 2 yr period of case pts death | Mailed questionnaire | Alcohol | | | | | Mortality: | When HRT use evaluated among women with a 1st degree relative and BCA, MAOR all cause death
NEJM | Nurses Health Study cohort | n = 3637 deaths | | Hormone use ascertained 1976 and biennially through 1992 | Benign breast disease | | | | | current vs. never: | 0.65(0.47 0.90) in those with affected 1st degree relative and 0.60(0.54–0.68) among those without
| 1976 - 6/1994 | | | | | | | | | 0.76(0.56–1.02) | Quality: good
| | | | | | | | | | past vs. never
| | | | | | | | | | 0.83(0.63–1.09)
Ross 2000 | BCA patients | BCA cases identified by Cancer surveillance program and California cancer registry | Individually matched by age, race, neighborhood | Interviewed within 1 year of diagnosis demographics, physical characteristics, etc. detailed HRT/OCP pictures used. | Good control of risk factors | Any HRT: | Any HRT: | | | For ERT: | Explored data (but did not report) that increase risk associated with CHRT not only increased in current users but in those who had quit 2 years previously) *good discussion
JNCI | population based | English speaking | n=2429 | HRT = any hormones | | Per 5 yrs: 1.10 (1.02–1.18) | After 15 yrs: 1.36 (NR) | | | almost all excess risk due to in situ OR 1.41(1.18–1.69) (other types NS) | Women with hysterectomy without oopherectory before menopause excluded
| Los Angles County | 3 groups | Participation 78% | ERT = estrogen only | | ERT: | ERT: | | | HRT in situ: OR 1.41(1.18–1.69) localized and advanced | Majority used medroxy progesterone and most used sequentially Premarin 0.625 mg most common ERT
| 3/87–12/89 | 1) 3/87-12-89: | | CHRT = combination estrogen + progestin | | Per 5 yrs: 1.06 (0.97–1.15) | Risk only increased after 15 yrs: 1.24 (NR) | | | NS CHRT: All BCA OR 1.24 (1.04–1.45) | Quality: fair
| | white, ages 55–64 | | | | CHRT: | CHRT: | | | Localized: 1.26 (1.06–1.49)
| | 2) 1/92-12-92: | | | | Per 5 yrs: 1.24 (1.07–1.45) | After 5 years: 1.15 (NR) | | | Advanced: 1.22 (0.95–1.51)
| | white or AA ages 55–69 | | | | | > 10 yrs: 1.23 | | | Overall no increase with CHRT but with
| | 3) 9/95–4–96: | | | | | Sequential CHRT: | | | Sequential HRT: OR (all BCA) 1.38 (1.13–1.68) OR
| | white or AA ages 55–72 | | | | | >10 yrs: 1.79 | | | Localized: 1.44 (1.16–1.78) OR
| | Reviews completed in 2653–3976 (1070 had died or too ill) | | | | | Continuous CHRT: | | | Advanced: 1.32 (0.99–1.76)
| | 894 refused | | | | | >10 yrs: 1.23
| | 66% participation
Henrich '98 | All women who had screening mam through Yale | Post-menopausal women >45 yrs with BCA (invasive or in situ) | 5 controls per case matched by age (1 yr) screening site, prior mammogram and year of mammography, or the mobile unit, payment status | Computerized data file non user = never use | Benign breast disease | All BCA: | Any BCA: | All BCA: | All BCA: | All BCA: | Age menopause not known
Journal of Clinical Epidemiology | 1 facility hospital based, the other mobile. | initially identified with mammography and with biopsy proven BCA | n=654 | stopped before age 45 or use < 6 months | Reproductive risk factors | 26.6% cases exposed HRT, 19.6% of controls | <5 yr: 1.55(0.79–3.04) | Current:1.52(0.77–2.99) | Past: 1.50(0.78–2.88) | Conjugated ERT: | Computer files-no info reproduction Screening mam - population all had localized dis. No interaction with family history
| n=14, 454 | n=109 | | | Alcohol | HRT use: 1.54(0.94–2.82) | >5 yr:1.61(0.83–3.13) | Invasive BCA: | Invasive BCA: | 1.49(0.8–2.76) | Quality: fair
| Non-population based | ERT defined as use in women age >45 with 1 or both ovaries | | | | estrogen alone: 1.66(0.98–2.82) | >11 yr: 1.45(0.51–4.11) | Current:1.87(0.85–4.12) | Past: 2.09(0.93–4.66) | Non-Conjugated:
| 7/87– 3/92 | Non use = never or <6mos use or stopped age 45 | | | | estrogen + progesterone: 1.02(0.32–3.21) | Invasive BCA: | | | 1.86(0.89–3.91)
| | | | | | Invasive BCA only (unadj): 1.93(1.06–3.49) | <5 yr: 1.87(0.87–4.03) | | | Invasive Conjugated:
| | | | | | current use: 1.87(0.85–4.12) | >5yr: 2.27(0.98–5.29) | | | 1.91 (0.89–4.11)
| | | | | | past use: 2.09(0.93–4.99) | | | | Non-Conjugated:
| | | | | | conjugated: 1.91(0.89–4.11) | | | | 2.49 (1.04–5.93)
| | | | | | non-conjugated: 2.49(1.04–5.93)
| | | | | | ERT: 2.22(1.18–4.17)
| | | | | | estrogen + progesterone: 0.96(0.20–4.57)
Weinstein '93 | N.Y. State | Residents of 2 Long Island counties aged 20–79 diagnosed with breast cancer | Age and county matched by drivers license files | Telephone interview using structured questionnaire. | Good | Ever use unadjusted | [underlined: <1 yr: 1.22 (0.87–1.43)] | | | Increased OR in thinner (1.88*) but not adjusted for other factors | Small number reported progesterone use, 25–37% uncertain
Int Jnl of Epid | 1/84-12/86 | n = 1436 though only post-menopausal women used | n = 1419 | Interviewers not blind | | all ages: | [underlined: 1–5yrs: 1.12 (0.71–1.75)] | | | | Low proportion contacted controls participated
| | n = 837 | Initially n = 860 postmenopausal | | | 1.09 (0.86–1.38) | [underlined: >5 yrs: 0.88 (0.53–1.44)] | | | | Quality: fair
| | response rate 66% | response rate 41% | | | age 50–70:
| | | | | | 1.12 (0.86–1.46)
| | | | | | adjusted ever/never:
| | | | | | 1.14 (0.84–1.40)
Yang '92 | British Columbia | 699 women, <75 with BCA | Drawn from voters list matched in 5 year categories | Postal questionnaire, type, duration | Alcohol | Adjusted only for age and type menopause: | ERT: | ERT: | | | Women who first used HRT within 12 months prior to reference date considered non-users, decreased chance of association.
Cancer Causes Control | population based | post-menopausal identified through cancer registry | n=685 | | Good adjustment | ERT: 1.1 (0.8–1.4) | <1: 1.2 (0.7–1.7) | <1: 1.4 (1.0–2.) | | | Quality: fair (poor participation), misclassification of HRT use
| 6/88 - 6/89 | response 68.3 | response 68.2 | | | Any Prog: 1.2(0.6–2.2) | 1–4: 0.8 (0.5–1.1) | 1–4: 1.3 (0.8–2.2)
| | | | | | | 5–9: 1.0 (0.6–1.5) | 5–9: 0.7 (0.4–1.2)
| | | | | | | 10+: 1.6 (1.1–2.5) | >10: 1.0 (0.7–1.4)
Brinton '98 Menopause | Population based | All women in Atlanta < 55 with newly diagnosed in situ or invasive BCA | Frequency-matched by region | Record review and personal interviews. | Benign breast disease | 24% cases used HRT, 27% controls exp. HRT, Ever HRT 0.9(0.7–1.2) | [underlined: <3yrs: 0.86(0.6–1.2)] | [underlined: <1 yr: 0.91(0.7–1.2)] | <l3 yrs: 0.91(0.7–1.3) | CHRT: 0.99(0.7–1.3) | Includes in situ and invasive Authors state that control of related factors did not change OR HRT use significantly more common in women with frequent mammograms, history of breast disease Relatively low exposure given young age Significantly increased risk among users of OCP's >10 years and >3 years HRT use Not just menopausal, if menopausal, young with decreased risk of BCA
| Atlanta | n=1031 | n=919 | Ever/never dates, duration dosage | Alcohol | | [underlined: 3–5: 1.0(0.7–1.6)] | [underlined: +1 yr: 0.82(0.5–1.2)] | 3–5: 0.9(0.6–1.3) | ERT: 0.7(0.5–0.9) | Quality: fair
| 5/1/90-2/31/92 | 89.5% participation | 79% participation | | Family history BCA | | [underlined: 6+: 0.85(0.5–1.4)] | | 6+: 0.86(0.6–1.2)
| | Not all menopausal
Tavani '97 Cancer Epidemiology, Biomarkers and Prevention | Hospital-based Milan, 6 other Italian regions | All women with incident BCA admitted to major teaching hospital | n=5504 | In-hospital interview | Alcohol | Ever use HRT in cases = 6.1%, ever use HRT controls = 5.5%, or ever/never use = 1.2(1.0–1.4) | Age < 55 yrs: | [underlined: <15 yrs: 1.4] | <15 yrs: 1.2 (1.1–1.5) | By age: | Low prevalence HRT use (10%)
| 1/83-5/91 | n=5984 | ages 15–74 | Ever/never use of hormones | | | <5 yrs: 0.9(0.6–1.2) | [underlined: >15 yrs: 1.0] | >15 yrs: 1.2 (0.9–1.6) | <55: 0.8 (0.6–1.1) | Among women > 65 years
| 6/91-2/94 | ages 22–74 histologically confirmed | from same geographic regions admitted to major teaching hospital | | | | >5 yrs: 1.2 (0.5–3.1) | | women age > 65: | 55–64: 1.2 (0.9–1.5) | 1. Time since stopping HRT:
| | median age 54 | 27% orthopedic and fractures | | | | Ages 55–64 yrs: | | <15 yrs: 2.1 (0.9–4.7) | >65: 1.6 (1.2–2.3) | <10 yrs: 1.4 (0.4–4.7)
| | >90% response | 32% non-traumatic orthopedics | | | | <5 yrs: 1.3 (1.0–1.7) | | >15 yrs: 2.0(1.2–3.2) | Among those 65–74 ever use: 1.6(1.1–2.3) | >10 yrs: 1.7 (1.2–2.4)
| | | excluded: if admitted for gynecologic, hormonal, or neoplastic. | | | | > 5 yrs: 0.9 (0.5–1.7) | | | <60 mos: 1.6(1.1–2.3) | 2. Time since starting HRT:
| | | Unmatched | | | | Ages >65 yrs: | | | >60 mos: 2.2(1.0–4.7) | <15 years: 2.1 (0.9–4.7)
| | | >90% response | | | | <5yrs: 1.6 (1.1–2.3) | | | | >15 years: 1.5 (1.1–2.2)
| | | | | | | >5 yrs: 2.2(1.0–4.7) | | | | Quality: poor, bias in control selection, broad age range
La Vechia '95 British Journal of Cancer | Hospital-based 6 Italian regions | All women with incident BCA (within 1 year) admitted to major teaching hospital | n=2588 | In-hospital interview | Alcohol | 7.5% cases exposed, 7.5% control expose, ever/never 1.2(0.9–1.5) | <1 year: 1.0(0.8–1.4) | Current: 0.8(0.5–1.4) | <10 yrs: 1.2(0.9–1.8) | Conjugated estrogen: 1.3(0.8–1.6) | Point estimate for CHRT 1.6 (not stat sig)No increased risk among current users
| 1991-1994 | n=2569 | ages 20–74 | Ever/never use of hormones | | | 1–4: 1.3(0.9–1.9) | 10 yrs: 2.0(1.3–2.9) | 10–14 yrs: 1.3(0.8–2.2) | CHRT: 1.6 (0.4–6.3) | Trend towards increased risk with increased duration among those recently stopping HRT
| | ages 23–74 histologically confirmed | from same geographical region | | | | > 5: 1.5(0.8–2.6) | >10 yrs: 1.0 | >15 yrs: 1.1(0.8–1.5) | other estrogens: 0.9 (0.7–1.4) | Quality: poor, bias in control election, broad age range
| | | admitted for trauma, orthopedic, acute surgery, eye conditions
Fioretti '99 British Journal of Cancer | Hospital-based | 665 cases post-menopausal incident BCA (within 1 year) from 1041 nulliparous women | 582 controls post-menopausal from same geographic region admitted to hospital | In-hospital interview | Alcohol | 9% cases exp. HRT | >2 yrs use: 1.28(0.66–2.45), no duration effect noted. | | | | No separation estrogen and progesterone No differentiation invasive vs insitu Important confounders not adjusted for Only evaluated HRT in nulliparous women
| Milan, 6 other Italian regions | ages 22–80 | nuliparous | Ever/never | | 7.9% controls esp. HRT, ever/never 1.22 (0.8–1.84) | | | | | Quality: poor, bias in control selection
| | all admitted to hospital histologically confirmed | ages 15–80
| | histologically confirmed | admitted for variety of conditions
Lipworth '95 Int. J. Cancer | Hospital-based | All women with newly diagnosed BCA | 2 controls for each case, 1 derived from hospital visitors | In hospital interview by trained interviewer | Benign breast disease | ever use estrogen 9.7% cases 8.5% | ERT: | | | | Progesterone use not evaluated; orthopedic controls may have had less use estrogen resulting in false positive association CHRT rarely used in Greece; unclear how many were post-menopausal
| 1/83-5/91 | residents of Athens from 4 major hospitals | (n=795) and 1 form orthopedic patients | | Family history | controls ever use 1.52(1.24–2.25) | <11mos: 1.75(1.02–3.01) | | | | Quality: fair-poor
| 6/91-2/94 | n=820 | (n=753), matched +/- 5 yrs. | | | | 2–35 mos: 1.26(0.63–2.52)
| | (173 histololgically confirmed) | | | | | >36 mos: 1.42(0.62–3.27)
Persson '97 | Population-based of Swedish women attending mammography screening Upsala | 435 with incident BCA (75% detected by mammography) 379 invasive 56 in situ | Derived from same population frequency matched by 5 year age intervals n=1740 | Nurse interview. Estrogen use evaluated as ever/never, type, duration, age started, use of progesterone | Benign breast disease Alcohol | 21.4% cases ever use HRT, 19.8% controls ever use HRT, ever use HRT 1.1(0.8–1.4) | All types HRT: | | | Ever use by type: | Suggestion of increased risk with CHRT (above ERT) OR 1–10 years: 1.4 (0.9–2.2); OR > 10 years: 2.4 (0.7–8.6). When analyses restricted to only those diagnosed by mammography OR HRT 10 years=2.0(1.0–4.0) Not confined to post-menopausal
Inter. Journal of Cancer | 2/90-7/92 | | | | | | 1–2 yrs: 0.9(0.6–1.3) | | | Estradiol-Conjugated E: 0.5(0.3–1.0) CHRT: 1.4(0.9–2.1) | Quality: poor
| | | | | | | 3–5 yrs: 1.0(0.6–1.8) | | | Weak Estrogens: 1.0(0.6–1.2)
| | | | | | | 6–10 yrs: 0.9(0.5–1.6)
| | | | | | | 11+ yrs: 2.1(1.1–4.0)
Magnuson '99 International Journal of Cancer | Population based | Incident cases BCA | Randomly selected frequency matched population registry | Written questionnaire, dates, brand, dose, type, estrogen and progesterone, evaluated by estrogen potency. | Benign breast disease | 48.3% cases used HRT ever; 40.3% controls used HRTever; HRT | HRT: | Within 1 yr: 1.99(1.67–2.38) | | | No sig. elevated risk with low potency estrogens (treated as never users)–bias/misclassification Suggestion that testosterone derived progesterone elevated increased risk (vs. non-testosterone PG) Suggestion that continuous testosterone PG worse than cyclic Subgroup analyses (many) Greater risk among < BMI shown in other data U-shaped association with recency; formulations not specified. Findings not adjusted for family history, benign breast disease, alcohol
| Sweden | n=2563 (of which 45 in situ) | n=2845 | | Family history | 1.65(1.43–1.89) | 1–24 mos: 1.29(1.05–1.59) | 1–10 yrs: 1.13(0.84–1.52) | | | Quality: poor
| 10/93- 3/1/1995 | post-menopausal | post-menopausal | | Alcohol | ERT | 25–60 mos: 1.40(1.07–1.82) | >10 yrs: 1.4(1.05–1.87)
| | 84% participation | 82% participation | | | 1.94(1.47–2.55) | 61–120 mos: 2.32(1.74–3.09)
| | | | | | CHRT | >120 mos: 2.43(1.79–3.36)
| | | | | | 1.63(1.37–1.94) | ERT:
| | | | | | | 1–24 mos: 1.72(1.13–2.62)
| | | | | | | 25–60 mos: 1.49(0.85–2.63)
| | | | | | | 61–120 mos: 2.18 1.07–4.45)
| | | | | | | >120 mos: 2.70(1.47–4.96)
| | | | | | | CHRT:
| | | | | | | 1–24 mos: 1.25(0.96–1.63)
| | | | | | | 25–60 mos: 1.40(1.01–1.94)
| | | | | | | 61–120 mos: 2.43(1.72–3.44)
| | | | | | | >120 mos: 2.95(1.84–4.72)
Levi '96 | Vaud Switzerland | 230 cases incident BCA histologically confirmed admitted to university hospital | 507 women admitted for wide spectrum acute conditions | In-hospital interview | Alcohol | 27.8% cases exposed, 22.3% controls exposed, OR ever/never 1.2(0.86–1.8) | [underlined: < 10 yrs: 1.3(0.9–2.0)] | Current: 1.5(0.9–2.5) | <10 yrs: 1.7(1.1–2.9) | | ?Bias in eliminating HRT use in controls
European Journal of Cancer Prevention | Hospitalbased | ages 23–70 | ages 24–75 excluded women who had been admitted for breast, gynecological, hormonal, metabolic neoplasia. | Ever/never use HRT => 6 months use. | benign breast disease | | [underlined: > 10 yrs: 1.0 (0.4–2.4)] | [underlined: <10 yrs: 1.4(0.8–2.7)] | >10 yrs: 0.9(0.5–1.6) | | No evaluation for ERT versus CHRT Risk essentially confined to current users
| 1/90-8/95 | Response rate NR | Response rate NR | Type estrogen not reported. | | | | [underlined: >10 yrs: 0.8 (0.4–1.8)] | | | No duration effect
| | | | | | | | | | | OR increased among those >65 years suggesting interaction.
| | | | | | | | | | | Not all post-menopausal
| | | | | | | | | | | Quality: poor, hospital-based, small, bias in control selection

Evidence Table 2. Cohort studies

Author Date | Setting/ Study Population | Measurement of Hormone Exposure, Comorbidity, Other Risk Factors | Method of documenting Breast Cancer | F/u length and loss to f/u | Important Exposures/ Risk Factors Not Adusted for: | Breast Cancer Incidence Multivariate Adjusted Relative Risk | Breast Cancer Relative Risk by Duration (yrs) Multivariate Adjusted Relative Risk | Relative Risk Breast Cancer associated with current use and duration (yrs) | Relative Risk Breast Cancer associated with past use and duration (yrs) | Breast Cancer Mortality Multivariate Adjusted Relative Risk | Comments/ Quality of Study
Sourander 1998 | Prospective Study of women born between 1923-1930 living in Turku, Finland, 68–75 yrs at study beginning, and participating in free mammography screening in 1987-1980, n = 6433 | Validated, nurse-administered questionnaire, estrogen use characterized as never, former & current use and confirmed by nurses*formulation not specified | Finnish Cancer Registry, death certificates, national registry of hospital discharge data | 8 yrs (53,305 person-years) | Benign breast disease, alcohol use, prior breast cancer, reproductive risk factors | Never: 1.0 | | | | | Progesterone use not evaluated, duration of use not evaluated
| | | | 1947 lost to f/u | | Current: 0.57 (0.27–1.20) | | | | | Quality: fair-poor
| | | | | | Former: 0.94 (0.47–1.9)
Colditz 1995 | U.S. Nurses Health Study, 121,700 women ages 30–55, n = 69,586 | mailed questionnaire with biennial follow-up | National Death Index, pathology reports in 93% | 6/1/92 | | By formulation: | | <2 yrs: 1.14 (0.91–1.45) | <2 yrs: 0.90 (0.77–1.05) | Current Users: | 18% women taking progestin-almost all cyclic, dose evaluated 1990
| postmenopausal | | | 725,550 person-yrs | | Conjugated Estrogen: 1.36(1.14–1.54) | | 2–4 yrs: 1.20 (0.99–1.44) | 2–4 yrs: 0.86 (0.71–1.05) | RR death adjusted for FMH & BBD | Quality: good
| | | | | | Other Estrogen: 1.28(0.97–1.71) | | 5–9 yrs: 0.8 (0.6–1.0) | 5–9 yrs: 1.00 (0.80–1.26) | 1.14(0.85–1.51)
| | | | | | Estrogen + Progesterone: 1.41(1.15–1.74) | | 10 or more yrs: 1.46 (1.20–1.76) | 10 or more yrs: 1.03 (0.76–1.41) | Ever Users:
| | | | | | Progesterone alone: 2.24(1.26–3.98) | | Ages at use < 5 yrs: | | < 5 yrs: 0.99(0.66–1.48)
| | | | | | Estrogen + Testosterone: 1.64(0.53–5.09) | | 50–54: 1.46 (0.98–2.17) | | 5+ yrs: 1.45(1.01–2.09)
| | | | | | | | 55–59: 1.37 (1.07–1.76) | | Past Users:
| | | | | | | | 60–64: 1.13 (0.79–1.63) | | RR = 0.80(0.6–1.07)
| | | | | | | | Age at use 5+ yrs:
| | | | | | | | 50–54: 1.46 (0.91–2.33)
| | | | | | | | 55–59: 1.54 (1.19–2.0)
| | | | | | | | 60–64: 1.7 (1.34–2.18)
Persson 1996 | Prospective cohort study in Uppsala health care region, Sweden, study population consisting of all women who had ever received HRT between 1977-1980, mean age 54.5 at entry, n = 22,579 | Pharmacy records | record linkage to Swedish Cancer and Death Registries | mean =13.2 yrs | Benign breast disease, prior history breast cancer, family history breast cancer, reproductive risk factors | 624 incident breast cancers, 102 deaths | SIR | | | SMR: 0.5(0.4–0.6) | use of estrogen/ levonorgestrel compound associated with overall risk 1.3 (1.1–1.4), SMR: 0.6(0.4–0.9)
| | Estrogen categorized by type: | | (297,977 person-years) | | SIR: 1.0 (0.9–1.1) | <1 yr: 0.8 (0.5–1.0) | | | By duration use | Quality: poor
| | 1. estradiol only or conjugated estrogens | | | | | 1–4 yrs: 1.1 (0.9–1.3) | | | <5 yrs: 0.2(0.1–0.3)
| | 2. fixed estrogen/ progestin dose | | | | | 5–9 yrs: 0.9 (0.8–1.0) | | | 5–9 yrs: 0.7(0.5–0.9)
| | 3. other estrogens | | | | | 10+ yrs: 1.0 (0.9–1.2) | | | 10+ yrs: 0.7(0.5–0.9)
| | Mailed questionnaire sent to random subset (n = 795)
Sellers 1997 | Prospective cohort -- Iowa Women's Health Study, random sample of all post-menopausal women between age 55–69 yrs who had valid drivers license in 1986, n = 35,919 | Mailed questionnaire | State Health registry (SEER) | 8 yrs (275,000+ person-years) | benign breast disease | | Overall: | Overall: | No family hx BCA: | No family hx BCA: | Evaluated association with HRT in those with family history breast cancer. No significant increased risk, e.g., no interaction with family history
| | | | | | | 5 yrs or less: 1.04 | 5 yrs or less: 1.34(0.98–1.8) | 5 yrs or less: 1.01 (0.85–1.20) | Past vs never (duration 5 yrs or less): 0.86 (0.76–0.97) | Quality: good
| | | | | | | >5 yrs: 0.89 | >5 yrs: 1.17(0.9–1.51) | >5 yrs: 0.80 (0.53–1.19) | Past vs never (duration >5 yrs): 0.76 (0.57–1.00)
| | | | | | | | No family hx BCA: | Family hx BCA: | Current vs never(duration 5 yrs or less): 1.00 (0.75–1.35)
| | | | | | | | 5 yrs or less: 1.31(0.94–1.83) | 5 yrs or less: 1.19 (0.81–1.73) | Current vs never (duration >5 yrs): 0.84 (0.67–1.06)
| | | | | | | | >5 yrs: 1.13(0.86–1.50) | >5 yrs: 1.17(0.55–2.47) | Family hx BCA:
| | | | | | | | Family hx BCA: | | Past vs never (duration 5 yrs or less): 0.71(0.51–0.98)
| | | | | | | | 5 yrs or less: 1.37 (0.59–3.18) | | Past vs never (duration >5 yrs): 0.59(0.90–1.16)
| | | | | | | | >5 yrs: 1.35 (0.72–2.53) | | Current vs never (duration 5 yrs or less): 0.24(0.06–0.97)
| | | | | | | | | | Current vs never (duration >5 yrs): 0.55(0.28–1.07)
Gapstur 1995 | Post menopausal women 55–69 yrs at baseline (in 1986), n = 37,105 | Never/ever | Incident BRC: State Health registry | 7 yrs, 2.5% lost due to immigration | Age at menopause, exercise, SES, smoking, hx benign breast disease, parity/ nulliparity, education, other medical conditions | Among EtOH non-users | | | | Not reported | Increased risk of ER+/ PR+ (p= 0.03) and ER-/ PR-
| Prospective cohort -- Iowa Women's Health Study, to study relationship between HRT use and BRC | *formulation not specified | ER/ PR Status: from medical records, when available | | | ER+/ PR+ | | | | | (p= 0.04) tumors with increased alcohol intake, trend not as clear for ER+/ PR- (p= 0.19)
| | | | | | Never use: 126 | | | | | Quality:??
| | | | | | Ever use: 81
| | | | | | ER+/ PR-
| | | | | | Never use: 33
| | | | | | Ever use: 14
| | | | | | ER-/ PR-
| | | | | | Never use: 27
| | | | | | Ever use: 10
| | | | | | ER/ PR status unknown
| | | | | | Never use: 117
| | | | | | Ever use: 56
Gapstur 1999 | Prospective cohort -- Iowa Women's Health Study, population based, post-menopausal women 55–69 yrs at baseline (in 1986) randomly selected from 1985 Iowa Department of Motor Vehicles registry | Self-reported mailed questionnaire | Follow-up questionnaires, SEER network '87, '89, '92 and '97, National Death Index | 11 yrs (371,477 py) | benign breast disease | Ever use (all types BCA): | DCIS (age-adjusted): | DCIS: | DCIS | Not reported | Formulation not specified, progesterone use not evaluated, women using HRT had signivicantly greater use of mammography but adjustment did not change risk estimates.
JAMA | n = 37,105 | | | 1520 incident breast cancers | | <5 yrs: 1.07(0.94–1.22) | <5 yrs or less vs never:1.08(0.77–1.52) | <5 yrs: 0.94(0.41–2.16) | <5 yrs vs never: 0.91(0.61–1.34) | | Quality = good
| | | | | | >5 yrs: 1.11(0.92–1.35) | > 5 yrs vs never: 1.10 (0.68–1.77) | > 5 yrs: 1.35(0.77–2.36) | >5 yrs vs never: 0.29(0.07–1.18)
| | | | | | | Favorable histology (age-adjusted): | Favorable histology: | Favorable histology
| | | | | | | <5 yrs vs never: 1.67(1.02–2.71) | <5 yrs: 4.42(2.0–9.76) | <5 yrs: 1.44(0.8–2.58)
| | | | | | | > 5 yrs: 2.22(1.22–4.02) | >5 yrs: 2.63(1.18–5.89) | >5 yrs: 2.68(1.08–6.69)
| | | | | | | Invasive ductal and/ or lobular (age adjusted): | Invasive ductal and/ or lobular: | Invasive ductaland/ or lobular
| | | | | | | <5 yrs: 1.05 (0.92–1.20) | <5 yrs: 1.38(1.03–1.85) | <5 yrs: 1.01(0.87–1.18)
| | | | | | | > 5 yrs: 1.07 (0.88–1.28) | >5 yrs: 1.16(0.9–1.45) | >5 yrs: 0.92(0.66–1.28)
| | | | | | | Multivariate adjusted RR invasive breast cancer with favorable histology:
| | | | | | | <5 yrs:1.81 (1.07–3.07)
| | | | | | | >5 yrs: 2.65 (1.34–5.23)
Risch 1994 | Saskatchewan women ages 43–49 in 1976, n = 32,790 | Prescription database -- all prescriptions for estrogen and progestins between 1976 and 6/97 | Hospital reports and death certificates, Saskatchewan cancer registry | Vital status followed until 12/31/90 | | Estrogen alone: 1.33(1.11–1.59) | Estrogen only: | | | | ? latency times
American Journal of Epidemiology | | | | | | Progestin only: 0.93(0.51–1.68) | 6 mos or less: 1.039(0.78–1.38) | | | | Quality: poor
| | | | | | | 6–18 mos: 1.161(0.83–1.63)
| | | | | | | 18–36 mos: 1.041(0.66–1.63)
| | | | | | | 36 mos or more: 1.498(1.06–2.13)
| | | | | | | Estrogen + Progestins
| | | | | | | 12 mos: 1.196(0.71–2.01)
Schairer 1994 | Prospective cohort -- postmenopausal women who were participants in the US breast cancer screening program (BCDDP), 1973-1980, mean age 57.4 yrs at start of f/u, n = 42,020 | Baseline telephone interview and up to 6, usually 4, annual telephone interivews, mailed questionnaire | self-report, death certificates, path reports | mean f/u = 6.4 yrs, 86% of non-cases and 85% of cases completed f/u, 313,902 person yrs | Age at menarche, BMI, age at 1st birth, exercise, SES, smoking, hx benign breast disease, family hx BRC, parity/ nulliparity, other medical conditions | All Cases | Estrogen Only | Estrogen Only | Estrogen Only | | Small sample size for ES/ PG analysis, small # in situ cases, dose not evaluated, formulation not specified
Cancer Causes and Control | | 1987-1989 | (avail on 92% of identified BRC) | | | Ever use estrogen only: 1.0(0.9–1.2) | All Cases | All cases: 1.3(1.1–1.5) | All cases: 0.9(0.8–1.1) | | Quality: fair
| | Non-users | | | | Ever use estrogen + progestins: 1.2(1.0–1.6) | < 5 yrs: 1.0(0.9–1.2) | <5 yrs: 1.4(1.1–1.8) | <5 yrs: 1.0(0.8–1.2)
| | users (estrogens alone -- also includes ES w/ PG uncertain or unascertained) | | | | Invasive | 5–9 yrs: 1.0 (0.8–1.2) | 5–9 yrs: 1.2(0.9–1.7) | 5–9 yrs: 0.9(0.7–1.2)
| | estrogen plus progestins | | | | Ever use estrogen only: 1.0(0.9–1.1) | 10–14 yrs: 1.0(0.8–1.3) | 10–14 yrs: 1.2(0.8–1.6) | 10–14 yrs: 0.9(0.6–1.2)
| | current | | | | Ever use estrogen + progestins: 1.1(0.9–1.4) | 15–19 yrs: 1.2(0.9–1.6) | 15+ yrs: 1.4(1.1–1.8) | 15+ yrs: 0.9(0.6–1.4)
| | Duration | | | | In Situ | 20 + yrs: 1.2(0.8–1.6) | In Situ: 1.8(1.1–2.7) | In Situ: 1.3(0.9–1.9)
| | Never/ever for progestin use | | | | Ever use estrogen only: 1.0(0.9–1.1) | In situ cases | <5 yrs: 1.4(0.6–3.1) | <5 yrs: 1.0(0.6–1.6)
| | | | | | Ever use estrogen + progestins: 1.0(0.9–1.4) | < 5 yrs: 1.1(0.7–1.7) | 5–9 yrs: 1.3(0.5–3.2) | 5–9 yrs: 1.5(0.8–3.0)
| | | | | | | 5–9 yrs:1.5(0.8–2.6) | 10–14 yrs: 2.3(1.1–4.8) | 10–14 yrs: 2.3(1.1–4.7)
| | | | | | | 10–14 yrs: 2.1(1.2–3.7) | 15+ yrs: 2.4(1.2–4.9) | 15+ yrs: 1.8(0.7–4.4)
| | | | | | | 15–19 yrs: 1.8(0.9–3.9) | Invasive: 1.2(1.0–1.5) | Invasive: 0.9(0.8–1.1)
| | | | | | | 20 + yrs: 2.0(0.9–4.5) | <5 yrs: 1.4(1.1–1.9) | <5 yrs: 1.0(0.8–1.2)
| | | | | | | Invasive cases | 5–9 yrs: 1.2(0.9–1.7) | 5–9 yrs: 0.8(0.6–1.1)
| | | | | | | <5 yrs: 1.0(0.9–1.2) | 10–14 yrs: 1.0(0.7–1.5) | 10–14 yrs: 0.7(0.5–1.1)
| | | | | | | 5–9 yrs: 1.0(0.8–1.2) | 15+ yrs: 1.3(1.0–1.7) | 15+ yrs: 0.8(0.5–1.3)
| | | | | | | 10–14 yrs: 0.9(0.6–1.1) | Estrogen + Progestin | Estrogen + Progestin
| | | | | | | 15–19 yrs: 1.1(0.8–1.5) | All cases: 1.2(0.9–1.6) | All cases: 1.4(1.0–2.0)
| | | | | | | 20 + yrs: 1.1(0.8–1.5) | In Situ: 2.4(1.2–4.7) | In Situ: 2.3(1.0–5.4)
| | | | | | | Estrogen + Progestin | Invasive: 1.0(0.7–1.4) | Invasive: 1.3(0.9–1.9)
| | | | | | | All Cases
| | | | | | | <2 yrs: 1.5(1.1–2.1)
| | | | | | | 2–3 yrs: 1.0(0.6–1.8)
| | | | | | | 4+ yrs: 1.4(0.9–2.2)
| | | | | | | In situ cases
| | | | | | | <2 yrs: 3.3(1.7–6.3)
| | | | | | | 2–3 yrs: 3.9(1.5–9.7)
| | | | | | | 4+ yrs: 0.7(0.1–4.7)
| | | | | | | Invasive cases
| | | | | | | <2 yrs: 1.3(0.9–1.9)
| | | | | | | 2–3 yrs: 0.7(0.3–1.4)
| | | | | | | 4+ yrs: 1.5(0.9–2.4)
Willis 1996 | Cancer Prevention Study, U.S., n = 676,526, enrolled 1982 | self-administered questionnaire | personal inquiries 1984, '86, '88, National Death Index/ Death Certificate | Dec. 31, 1991 | | not assessed | | | | Ever vs never: 0.84 (0.75–0.94) | Women who take HRT more likely to have BBD, early menopause, surgical menopause, women who died of BRC tended to report later ages at 1st use than other estrogen users (p= 0.07), no discernible trend w/ duration of use, ever use w/ menarche at 14 yrs or later had decreased fatal BRC risk.
Cancer Causes and Control | | | | | | | | | | Current vs never: 0.90 (0.75–1.09) | Quality: good-fair
| | | | | | | | | | Past vs never: 0.78 (0.68–0.89)
| | | | | | | | | | Duration (vs never):
| | | | | | | | | | 1 yr or less: 0.85 (0.71–1.02)
| | | | | | | | | | 2–5 yrs: 0.78 (0.65–0.93)
| | | | | | | | | | 6–10 yrs: 0.78 (0.62–0.98)
| | | | | | | | | | 11+ yrs: 0.93 (0.75–1.15)
| | | | | | | | | | Age at first use
| | | | | | | | | | <40: 0.66 (0.51–0.85)
| | | | | | | | | | 40–49: 0.84 (0.73–0.97)
| | | | | | | | | | 50+: 0.89 (0.76–1.05)
Schuurman 1995 | Prospective study of 62,573 women ages 55–69 in the Netherlands beginning Sept. 1986 | mailed self-administered questionnaire | computerized record linkage with Dutch national database pathology reports | 3.3 yrs | family history of breast cancer, benign breast disease | [underlined: Ever use: 0.99 (0.68–1.43)] | never: 1.0 | | | not reported | No association shown with time since last use, time since first use or age at first use, in situ cases excluded.
Cancer Causes and Control | | | | | | | 1 yr or less: 0.8 (0.5–1.5) | | | | Quality: good-fair
| | | | | | | 2–4 yrs: 1.4 (0.7–2.7) | | | | Induced menopause: RR 1.72 (0.95–3.12) Non-induced 0.81 (0.54–1.21) Wt<70 kg RR ever 1.46 (0.99–2.16) Wt>70 RR 0.66 (0.38–1.14)
| | | | | | | 5+ yrs: 0.9 (0.4–2.1)
Schairer 2/1999 | Participants in BCDDP diagnosed with BCA 1973-1980 and postmenopausal | Mailed questionnaire determining vital status through 6/95, n = 2675, original exposures evaluated by annual questionnaire, in home interview and phone interview | Standard pathology reports, death certificates obtained for 92% | average 14.1 yrs | | | | | | Lymph node negative | See paper for comulative probabilities of death
Journal of the National Cancer Institute | n= 2675 | | | | | | | | | Current users | Quality: fair
| | | | | | | | | | 48 mos or less: 0.6(0.3–1.2) | Quality: good
| | | | | | | | | | 49–96 mos: 0.4(0.2–0.8)
| | | | | | | | | | 97–144 mos: 0.6 (0.2–1.5)
| | | | | | | | | | >145 mos: 2.2 (0.9–5.2)
| | | | | | | | | | Past non users
| | | | | | | | | | 48 mos or less: 0.8 (0.4–1.4)
| | | | | | | | | | 49–96 mos: 0.7 (0.4–1.2)
| | | | | | | | | | 97–144 mos: 1.2 (0.6–2.5)
| | | | | | | | | | >145 mos: 1.8 (0.8–4.3)
| | | | | | | | | | Lymph node positive
| | | | | | | | | | Current users
| | | | | | | | | | 48 mos or less: 0.5 (0.3–0.8)
| | | | | | | | | | 49–96 mos: 1.2 (0.6–2.2)
| | | | | | | | | | 97–144 mos: 0.8 (0.3–1.7)
| | | | | | | | | | >145 mos: 1.9 (0.6–5.7)
| | | | | | | | | | Past non-users
| | | | | | | | | | 48 mos or less: 0.5 (0.3–0.9)
| | | | | | | | | | 49–96 mos: 1.6 (0.9–2.8)
| | | | | | | | | | 97–144 mos: 1.2 (0.6–2.4)
| | | | | | | | | | >145 mos: 4.4 (1.7–11.8)
Folsom 1995 | Iowa | Questionnaire, risk factors anthropometric measures, HRT -- ever use and duration, not formulation | Cancer registry | Not given | Not adjusted for benign breast disease or family history | HRT (formulation not known) | | [underlined: <5 yrs: 1.45 (1.03–2.06)]
American Journal of Public Health | 41,837 | | | | | Former use: 0.96(0.81–1.14) | | [underlined: > 5 yrs: 1.21 (0.92–1.60)]
| ages 55–69 | | | | | Current use: 1.24(0.99–1.56)
Schairer 2000 | BCDDP participants | | 2082 BCA | 10.2 yrs | | [underlined: Ever use:] | Time since last use: | | | | Subcategory analysis
JAMA | | | 82% had path reports review, of the 82% , 255 in situ, 1456 invasive | 473,687 person-yrs | | [underlined: Estrogen Only: 1.1 (1.0–1.3)] | Estrogen Only | | | | women with BMI 24.4 or higher had increased risk with Estrogen only (RR 1.6 (1.2–2.2)) at 4 or more years duration, and Estrogen + Progestin at 4 or more yrs RR 2.0 (1.3–3.0)
| | | | | | [underlined: Estrogen + Progestin: 1.3 (1.0–1.6)] | current: 1.1(1.0–1.3) | | | | Quality: fair
| | | | | | [underlined: Estrogen alone + Prog/Est: 1.2 (1.0–1.5)] | 1–2 yrs: 1.4(1.1–1.8)
| | | | | | [underlined: Progestin only 0.9 (0.5–1.6)] | >2–4 yrs: 1.2(0.9–1.6)
| | | | | | [underlined: Estrogen (progestin unknown) 1.3 (1.0–1.5)] | >4–6 yrs: 0.9(0.6–1.3)
| | | | | | | >6 yrs: 1.1(0.9–1.2)
| | | | | | | Estrogen + Progestin
| | | | | | | current: 1.4(1.1–1.9)
| | | | | | | 1–2 yrs: 1.2(0.6–2.4)
| | | | | | | >2–4 yrs: 1.2 (0.5–2.5)
| | | | | | | >4–6 yrs: 0.6(0.2–2.6)
| | | | | | | >6 yrs: 0.6(0.3–1.6)
Schairer 1994 | Prospective study of health care region study population consisting of all women who had received HRT 1977-80 | Pharmacy records | Linkage to national causes of death registry | 3/77-12/86 | BBD, FMLT, alcohol | | | | | RR death | 56% estradiol compounds
| age | Estrogen categorized: | | n=1472 | repreductive risk factors | | | | | (SMR) 0.72 (0.58–0.89) | 22% conjugated
| n=23.246 | 1. Estrdial or conjuaged estrogen. | | deaths | | | | | | | 22% other comparison group external
| | 2. Combined E/P | | 199,811 person-year | | | | | | | Quality: fair
| | 3. Other estrogen
Ettinger 1996 | Kaiser SF 1969-73 | Prescription records | Death BCA | 12/1992 or Death | Family | | | | | RR 1.89 (0.43 – 8.36) | Poor study design
Obstetrics & Gynecology | women who had used HRT >5 years and women with <1yr. | medical records | | | BBD, Reproductive risk factors Alcohol | | | | | | comparing longterm users mean daily does 0.9 mg.
| Date menopause known with HRT begun within 3 years of menopause | | | | | | | | | | Quality: poor
| n=245 estrogen users
| n=232 age matched non-users
| age 55–69
Lando 1999 | NHANES | Baseline exam and 4 follow-up interviews by phone. | Record, Review and NCI review | Average 12.71 yrs. Follow-up. | Alcohol | 219 incident cases | [underlined: <3 yrs: 0.9(0.6–1.4)] | | | | Good methodology. No interaction with family history. No interaction with type menopause.
American Journal of Preventive Medicine | I Epidemiologic follow-up Study | HRT use ever/never and length. | | 73,253 person/yrs, | benign breast disease | ever/never 0.8 (0.6–1.1) | [underlined: 3–9yrs: 0.5(0.3–0.9)] | | | | Quality: good-fair
| Post-menopausal women interveiwed | Confounders well characterized | | | | | [underlined: >10yrs: 0.8(0.5–1.3)]
| 1971-1974
| n = 5761