# Addendum

This report was completed in December 2001. On May 31, 2002 after approximately 5.2 years of follow-up, the Women's Health Initiative (WHI) randomized controlled trial was stopped on the recommendation of the data safety and monitoring board because the test statistic for invasive breast cancer exceeded the stopping boundary for this outcome. At the time the study was stopped, the hazard ratio for invasive breast cancer associated with the use of estrogen 0.625mg and medroxyprogesterone acetate 2.5mg per day in 1 tablet was 1.26 (95% nominal CI; 1.00–1.59). When the confidence interval was adjusted for multiple analyses over time it was 0.83–1.92. No significant difference for in situ breast cancer was shown. Three breast cancer deaths occurred in the combined therapy group (n=8506) and 2 in the placebo group (n=8102). Subgroup analyses indicated that women reporting prior postmenopausal hormone use had higher hazard ratios for breast cancer associated with CHRT use in the trial than women who had not previously used hormones (HR 1.06 [95% CI; 0.81–1.38]). When duration of prior hormone use was evaluated, women with less than 5 years of prior use had increased risk (HR 2.13 [95% CI; 1.15–3.94]). Prior use of 5–10 years among those randomized to CHRT showed a hazard ratio of 4.61 (95% CI; 1.01–21.02) and greater than 10 years of prior use was associated with a hazard ratio of 1.81 (95% CI; 0.60–5.43) among women randomized to CHRT use in the trial. No interactions were identified with known breast cancer risk factors.

A separate arm of the WHI evaluating whether oral estrogen prevents cardiovascular disease among women with prior hysterectomy (n=10,739) was not terminated so the association between ERT and breast cancer in this trial remains uncertain, with results expected in 2005.

These findings are consistent with some, but not all, of the observational studies which specifically evaluated CHRT use and are reported in our evidence review. In addition, they are consistent with prior meta-analyses of observational studies which have evaluated the HRT - breast cancer relationship, though have not specifically evaluated CHRT use. The findings from the WHI trial evaluating estrogen use alone will help clarify whether the increase in breast cancer risk is associated with the estrogen or progesterone components of the therapy, or both.