# References

1 Keating N L, Cleary P D, Rossi A S, Zaslavsky A M, Ayanian J Z. use of hormone replacement therapy by postmenopausal women in the United States. Ann Intern Med. 1999;130(7):545-553. [pmid: 10189323].
2 Snedeker S M, Diaugustine R P. Hormonal and environmental factors affecting cell proliferation and neoplasia in the mammary gland. Progress in Clinical & Biological Research. 1996;394:211-253. [pmid: 8778798].
3 Hankinson S E, Willett W C, Manson J E, et al. Plasma sex steroid hormone levels and risk of breast cancer in postmenopausal women. J Natl Cancer Inst. 1998;90(17):1292-1299. [pmid: 9731736].
4 Toniolo P G, Levitz M, Zeleniuch-Jacquotte A, et al. A prospective study of endogenous estrogens and breast cancer in postmenopausal women [see comments]. J Natl Cancer Inst. 1995;87(3):190-197. [pmid: 7707406].
5 Kuller L H, Cauley J A, Lucas L, Cummings S, Browner W S. Sex steroid hormones, bone mineral density, and risk of breast cancer. Environ Health Perspect. 1997;105(Suppl 3):593-599. [pmid: 9168001]. [pmcid: 1469888].
6 Thomas H V, Reeves G K, Key T J. Endogenous estrogen and postmenopausal breast cancer: a quantitative review. Cancer Causes & Control. 1997;8(6):922-928. [pmid: 9427435].
7 Wysowski D K, Comstock G W, Helsing K J, Lau H L. Sex hormone levels in serum in relation to the development of breast cancer. Am J Epidemiol. 1987;125(5):791-799. [pmid: 3565354].
8 Key T J, Wang D Y, Brown J B, et al. A prospective study of urinary oestrogen excretion and breast cancer risk. Br J Cancer. 1996;73(12):1615-1619. [pmid: 8664140].
9 Brinton L A, Schairer C, Hoover R N, Fraumeni J F Jr. Menstrual factors and risk of breast cancer. Cancer Invest. 1988;6(3):245-254. [pmid: 3167610].
10 Pike M C, Krailo M D, Henderson B E, Casagrande J T, Hoel D G. ‘Hormonal’ risk factors, ‘breast tissue age’ and the age-incidence of breast cancer. Nature. 1983;303(5920):767-770. [pmid: 6866078].
11 Hulka B S, Liu E T, Lininger R A. Steroid hormones and risk of breast cancer. Cancer. 1994;74(3 Suppl):1111-1124. [pmid: 8039146].
12 Collaborative Group on Hormonal Factors in Breast Cancer. Breast cancer and hormone replacement therapy: collaborative reanalysis of data from 51 epidemiological studies of 52,705 women with breast cancer and 108,411 women without breast cancer. Collaborative Group on Hormonal Factors in Breast Cancer. Lancet. 1997;350(9084):1047-1059. [pmid: 10213546].
13 Lucas F L, Cauley J A, Stone R A, et al. Bone mineral density and risk of breast cancer: differences by family history of breast cancer. Study of Osteoporotic Fractures Research Group. Am J Epidemiol. 1998;148(1):22-29. [pmid: 9663400].
14 Goldhirsch A, Wood W C, Senn H, Glick J H, Gelber R D. Meeting Highlights: International Consensus Panel on the Treatment of Primary Breast Caner. J Natl Cancer Inst. 1995;87(19):1441-1445. [pmid: 7674331].
15 Fisher B, Constantino J P, Wickerham D L, et al. Tamoxifen for Prevention of Breast Cancer: Report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90(18):1371-1388. [pmid: 9747868].
16 Longacre T A, Bartow S A. A correlative morphologic study of human breast and endometrium in the menstrual cycle. Am J Surg Pathol. 1986;10(6):382-393. [pmid: 3717495].
17 Bergkvist L, Adami H O, Persson I, Hoover R, Schairer C. The risk of breast cancer after estrogen and estrogen-progestin replacement [see comments]. N Engl J Med. 1989;321(5):293-297. [pmid: 2546079].
18 Fisher B, Redmond C, Brown A, et al. Influence of tumor estrogen and progesterone receptor levels on the response to tamoxifen and chemotherapy in primary breast cancer. J Clin Oncol. 1983;1(4):227-241. [pmid: 6366135].
19 Wold L E, Ingle J N, Pisansky T M, Johnson R E, Donohue J H. Prognostic factors for patients with carcinoma of the breast. Mayo Clin Proc. 1995;70(7):678-679. [pmid: 7791392].
20 Colditz G A, Hankinson S E, Hunter D J, et al. The use of estrogens and progestins and the risk of breast cancer in postmenopausal women. N Engl J Med. 1995;332(24):1589-1593. [pmid: 7753136].
21 Schairer C, Lubin J, Troisi R, Sturgeon S, Brinton L, Hoover R. Menopausal estrogen and estrogen-progestin replacement therapy and breast cancer risk [see comments]. JAMA. 2000;283(4):485-491. [pmid: 10659874].
22 Ross R K, Paganini-Hill A, Wan P C, Pike M C. Effect of hormone replacement therapy on breast cancer risk: estrogen versus estrogen plus progestin. J Natl Cancer Inst. 2000;92(4):32-332.
23 Force UPST. Guise to Clinical Preventive Services. 2nd ed. Alexandria, VA: Internation Medical Publishing; 1996.
24 Warner E, Lockwood G, Tritchler D, Boyd N F. The risk of breast cancer associated with mammographic parenchymal patterns: a meta-analysis of the published literature to examine the effect of method of classification. Cancer Detection & Prevention. 1992;16(1):67-72. [pmid: 1532349].
25 Laya M B, Larson E B, Taplin S H, White E. Effect of estrogen replacement therapy on the specificity and sensitivity of screening mammography [see comments]. J Natl Cancer Inst. 1996;88(10):643-649. [pmid: 8627640].
26 Nachtigall L E, Nachtigall R H, Nachtigall R D, Beckman E M. Estrogen replacement therapy II: a prospective study in the relationship to carcinoma and cardiovascular and metabolic problems. Obstet Gynecol. 1979;54(1):74-79. [pmid: 221871].
27 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force. Am J Prev Med. 2001 2001;20(3S):in press.
28 Slavin R. Best-evidence synthesis: an alternative to meta-analytic and traditional reviews. Educational Researcher. 1986;15(5–11).
29 Colditz G A, Egan K M, Stampfer M J. Hormone replacement therapy and risk of breast cancer: results from epidemiologic studies. Am J Obstet Gynecol. 1993;168(5):1473-1480. [pmid: 8498430].
30 Dupont W D, Page D L. Menopausal estrogen replacement therapy and breast cancer [see comments]. Arch Intern Med. 1991;151(1):67-72. [pmid: 1824675].
31 Sillero-Arenas M, Delgado-Rodriguez M, Rodigues-Canteras R, Bueno-Cavanillas A, Galvez-Vargas R. Menopausal hormone replacement therapy and breast cancer: a meta-analysis. Obstet Gynecol. 1992;79(2):286-294. [pmid: 1530988].
32 Steinberg K K, Smith S J, Thacker S B, Stroup D F. Breast cancer risk and duration of estrogen use: the role of study design in meta-analysis. Epidemiology. 1994;5(4):415-421. [pmid: 7918811].
33 Armstrong B K. Oestrogen therapy after the menopause--boon or bane?. Med J Aust. 1988;148(5):213-214. [pmid: 3343947].
34 Grady D, Rubin S M, Petitti D B, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992;117(12):1016-1037. [pmid: 1443971].
35 Hemminki E, McPherson K. Impact of postmenopausal hormone therapy on cardiovascular events and cancer: pooled data from clinical trials. Br Med J. 1997;315(7101):149-153. [pmid: 9251544]. [pmcid: 2127109].
36 Gapstur S M, Morrow M, Sellers T A. Hormone replacement therapy and risk of breast cancer with a favorable histology: results of the Iowa Women's Health Study [see comments]. JAMA. 1999;281(22):2091-2097. [pmid: 10367819].
37 Schuurman A G, van den Brandt P A, Goldbohm R A. Exogenous hormone use and the risk of postmenopausal breast cancer: results from The Netherlands Cohort Study. Cancer Causes & Control. 1995;6(5):416-424. [pmid: 8547539].
38 Sourander L, Rajala T, Raiha I, Makinen J, Erkkola R, Helenius H. Cardiovascular and cancer morbidity and mortality and sudden cardiac death in postmenopausal women on oestrogen replacement therapy (ERT). Lancet. 1998;352(9145):1965-1969. [pmid: 9872245].
39 Lando J F, Heck K E, Brett K M. Hormone replacement therapy and breast cancer risk in a nationally representative cohort. Am J Prev Med. 1999;17(3):176-180. [pmid: 10987632].
40 Persson I. Cancer risk in women receiving estrogen-progestin replacement therapy. Maturitas. 1996;23(Suppl):S37-45. [pmid: 8865138].
41 Risch H A, Howe G R. Menopausal hormone usage and breast cancer in Saskatchewan: a record-linkage cohort study. Am J Epidemiol. 1994;139(7):670-683. [pmid: 8166128].
42 Yang C P, Daling J R, Band P R, Gallagher R P, White E, Weiss N S. Noncontraceptive hormone use and risk of breast cancer. Cancer Causes & Control. 1992;3(5):475-479. [pmid: 1525328].
43 Brinton L A, Brogan D R, Coates R J, Swanson C A, Potischman N, Stanford J L. Breast cancer risk among women under 55 years of age by joint effects of usage of oral contraceptives and hormone replacement therapy. Menopause. 1998;5(3):145-151. [pmid: 9774759].
44 Tavani A, Braga C, La Vecchia C, Negri E, Franceschi S. Hormone replacement treatment and breast cancer risk: an age-specific analysis. Cancer Epidemiol Biomarkers Prev. 1997;6(1):11-14. [pmid: 8993791].
45 Weinstein A L, Mahoney M C, Nasca P C, Hanson R L, Leske M C, Varma A O. Oestrogen replacement therapy and breast cancer risk: a case-control study. Int J Epidemiol. 1993;22(5):781-789. [pmid: 8282455].
46 Persson I, Thurfjell E, Bergstrom R, Holmberg L. Hormone replacement therapy and the risk of breast cancer. Nested case-control study in a cohort of Swedish women attending mammography screening. Int J Cancer. 1997;72(5):758-761. [pmid: 9311590].
47 Newcomb PA, Longnecker MP, Storer BE, et al. Long-term hormone replacement therapy and risk of breast cancer in postmenopausal women [see comments][published erratum appears in Am J Epidemiol 1996 Mar 1;143(5);527]. Am J Epidemiol. 1995;142(8):788–795.
48 Stanford J L, Weiss N S, Voigt L F, Daling J R, Habel L A, Rossing M A. Combined estrogen and progestin hormone replacement therapy in relation to risk of breast cancer in middle-aged women [see comments]. JAMA. 1995;274(2):137-142. [pmid: 7596001].
49 Lipworth L, Katsouyanni K, Stuver S, Samoli E, Hankinson S E, Trichopoulos D. Oral contraceptives, menopausal estrogens, and the risk of breast cancer: a case-control study in Greece. Int J Cancer. 1995;62(5):548-551. [pmid: 7665225].
50 La Vecchia C, Negri E, Franceschi S, et al. Hormone replacement treatment and breast cancer risk: a cooperative Italian study. Br J Cancer. 1995;72(1):244-248. [pmid: 7599060].
51 Levi F, Lucchini F, Pasche C, La Vecchia C. Oral contraceptives, menopausal hormone replacement treatment and breast cancer risk. Eur J Cancer Prev. 1996;5(4):259-266. [pmid: 8894563].
52 Henrich J B, Kornguth P J, Viscoli C M, Horwitz R I. Postmenopausal estrogen use and invasive versus in situ breast cancer risk. J Clin Epidemiol. 1998;51(12):1277-1283. [pmid: 10086820].
53 Magnusson C, Baron J A, Correia N, Bergstrom R, Adami H O, Persson I. Breast-cancer risk following long-term oestrogen- and oestrogen-progestin-replacement therapy. Int J Cancer. 1999;81(3):339-344. [pmid: 10209946].
54 Fioretti F, Tavani A, Bosetti C, et al. Risk factors for breast cancer in nulliparous women. Br J Cancer. 1999;79(1112):1923-1928. [pmid: 10206315].
55 Shapiro S. Meta-analysis/Shmeta-analysis. Am J Epidemiol. 1994;140(9):771-778. [pmid: 7977286].
56 Colditz G A, Stampfer M J, Willett W C, Hennekens C H, Rosner B, Speizer F E. Prospective study of estrogen replacement therapy and risk of breast cancer in postmenopausal women. JAMA. 1990;1990(264):2648-2653.
57 Tavani A, Braga C, La Vecchia C, Negri E, Russo A, Franceschi S. Attributable risks for breast cancer in Italy: education, family history and reproductive and hormonal factors. Int J Cancer. 1997;70(2):159-163. [pmid: 9009154].
58 La Vecchia C. Oestrogens and progestins and breast cancer risk in post-menopausal women. Pharmacol Res. 1995;32(6):323-324. [pmid: 8736479].
59 The Writing Group for the PEPI Trail. Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. [see comments][published erratum appears in JAMA 1995 Dec 6;274(21):1676]. JAMA. 1995;273(3):199–208.
60 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998;280(7):605-613. [pmid: 9718051].
61 Grodstein F, Stampfer M J, Colditz G A, et al. Postmenopausal hormone therapy and mortality. N Engl J Med. 1997;336(25):1769-1775. [pmid: 9187066].
62 Ettinger B, Friedman G D, Bush T, Quesenberry C P Jr. Reduced mortality associated with long-term postmenopausal estrogen therapy. Obstet Gynecol. 1996;87(1):6-12. [pmid: 8532268].
63 Willis D B, Calle E E, Miracle-McMahill H L, Heath C W Jr. Estrogen replacement therapy and risk of fatal breast cancer in a prospective cohort of postmenopausal women in the United States. Cancer Causes & Control. 1996;7(4):449-457. [pmid: 8813433].
64 Persson I, Yuen J, Bergkvist L, Schairer C. Cancer incidence and mortality in women receiving estrogen and estrogen-progestin replacement therapy--long-term follow-up of a Swedish cohort. Int J Cancer. 1996;67(3):327-332. [pmid: 8707404].
65 Sellers T A, Mink P J, Cerhan J R, et al. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer [see comments]. Ann Intern Med. 1997;127(11):973-980. [pmid: 9412302].
66 Schairer C, Gail M, Byrne C, et al. Estrogen replacement therapy and breast cancer survival in a large screening study. J Natl Cancer Inst. 1999;91(3):264-270. [pmid: 10037105].
67 Gapstur S M, Potter J D, Sellers T A, Folsom A R. Increased risk of breast cancer with alcohol consumption in postmenopausal women. Am J Epidemiol. 1992;136(10):1221-1231. [pmid: 1476144].
68 Katsouyanni K, Trichopoulou A, Stuver S, et al. Ethanol and breast cancer: an association that may be both confounded and causal. Int J Cancer. 1994;58(3):356-361. [pmid: 8050817].
69 Saftlas A F, Szklo M. Mammographic parenchymal patterns and breast cancer risk. Epidemiol Rev. 1987;9:146-174. [pmid: 3315715].
70 Oza A M, Boyd N F. Mammographic parenchymal patterns: a marker of breast cancer risk. Epidemiol Rev. 1993;15(1):196-208. [pmid: 8405204].
71 Boyd M E. The risks and benefits of hormone replacement therapy [see comments]. Can J Surg. 1995;38(5):415-419. [pmid: 7553464].
72 Laya M B, Gallagher J C, Schreiman J S, Larson E B, Watson P, Weinstein L. Effect of postmenopausal hormonal replacement therapy on mammographic density and parenchymal pattern. Radiology. 1995;196(2):433-437. [pmid: 7617857].
73 Greendale G A, Reboussin B A, Sie A, et al. Effects of estrogen and estrogen-progestin on mammographic parenchymal density. Postmenopausal Estrogen/Progestin Interventions (PEPI) Investigators. Ann Intern Med. 1999;130(4 Pt 1):262-269. [pmid: 10068383].
74 Marugg R C, van der Mooren M J, Hendriks J H, Rolland R, Ruijs S H. Mammographic changes in postmenopausal women on hormonal replacement therapy. Eur Radiol. 1997;7(5):749-755. [pmid: 9166577].
75 O'Connor I F, Shembekar M V, Shousha S. Breast carcinoma developing in patients on hormone replacement therapy: a histological and immunohistological study. J Clin Pathol. 1998;51(12):935-938. [pmid: 10070338]. [pmcid: 501032].
76 Magnusson C, Holmberg L, Norden T, Lindgren A, Persson I. Prognostic characteristics in breast cancers after hormone replacement therapy. Breast Cancer Research & Treatment. 1996;38(3):325-334. [pmid: 8739086].
77 Bonnier P, Bessenay F, Sasco A J, et al. Impact of menopausal hormone-replacement therapy on clinical and laboratory characteristics of breast cancer. Int J Cancer. 1998;79(3):278-282. [pmid: 9645351].
78 Harding C, Knox WF, Faragher EB, Baildam A, Bundred NJ. Hormone replacement therapy and tumour grade in breast cancer: prospective study in screening unit [published erratum appears in BMJ 1996 Jul 27;313(7051):198]. Br Med J. 1996;312(7047):1646–1647.
79 Stolier A J, Mera R, Schapira D. The impact of current use of hormone replacement therapy on prognostic factors and surgical treatment of new breast cancers. Oncology Reports. 1998;5(1):61-64. [pmid: 9458294].
80 Holli K, Isola J, Cuzick J. Low biologic aggressiveness in breast cancer in women using hormone replacement therapy. J Clin Oncol. 1998;16(9):3115-3120. [pmid: 9738583].
81 Squitieri R, Tartter P I, Ahmed S, Brower S T, Theise N D. Carcinoma of the breast in postmenopausal hormone user and nonuser control groups. J Am Coll Surg. 1994;178(2):167-170. [pmid: 8173728].
82 Bilimoria M M, Winchester D J, Sener S F, Motykie G, Sehgal U L, Winchester D P. Estrogen replacement therapy and breast cancer: analysis of age of onset and tumor characteristics. Ann Surg Oncol. 1999;6(2):200-207. [pmid: 10082047].
83 Jones C, Ingram D, Mattes E, Hahnel R. The effect of hormone replacement therapy on prognostic indices in women with breast cancer. Med J Aust. 1994;161(2):106-110. [pmid: 8028534].
84 Cobleigh M A, Norlock F E, Oleske D M, Starr A. Hormone replacement therapy and high S phase in breast cancer. JAMA. 1999;281(16):1528-1530. [pmid: 10227323].
85 LeBlanc E S, Viscoli C M, Henrich J B. Postmenopausal edstrogen replacment therapy is associated with adverse breast cancer prognostic indices. Journal of Women's Health & Gender-Based Medicine. 1999;8(6):815-823. [pmid: 10495262].
86 Pike M C, Ross R K, Spicer D V. Problems involved in including women with simple hysterectomy in epidemiologic studies measuring the effects of hormone replacement therapy on breast cancer risk. Am J Epidemiol. 1998;147(8):718-721. [pmid: 9554412].
87 Schairer C, Byrne C, Keyl P M, Brinton L A, Sturgeon S R, Hoover R N. Menopausal estrogen and estrogen-progestin replacement therapy and risk of breast cancer (United States). Cancer Causes & Control. 1994;5(6):491-500. [pmid: 7827235].
88 Bonnier P, Romain S, Giacalone P L, Laffargue F, Martin P M, Piana L. Clinical and biologic prognostic factors in breast cancer diagnosed during postmenopausal hormone replacement therapy. Obstet Gynecol. 1995;85(1):11-17. [pmid: 7800305].
89 Key T J, Pike M C. The role of oestrogens and progestagens in the epidemiology and prevention of breast cancer. European Journal of Cancer & Clinical Oncology. 1988;24(1):29-43. [pmid: 3276531].
90 Cline J M, Soderqvist G, von Schoultz E, Skoog L, von Schoultz B. Effects of hormone replacement therapy on the mammary gland of surgically postmenopausal cynomolgus macaques [see comments]. Am J Obstet Gynecol. 1996;174(1 Pt 1):93-100. [pmid: 8572040].
91 Foidart J M, Colin C, Denoo X, et al. Estradiol and progesterone regulate the proliferation of human breast epithelial cells. Fertility & Sterility. 1998;69(5):963-969. [pmid: 9591509].
92 Ginsburg E S, Mello N K, Mendelson J H, et al. Effects of alcohol ingestion on estrogens in postmenopausal women. JAMA. 1996;276(21):1747-1751. [pmid: 8940324].
93 Longnecker M P, Paganini-Hill A, Ross R K. Lifetime alcohol consumption and breast cancer risk among postmenopausal women in Los Angeles. Cancer Epidemiol Biomarkers Prev. 1995;4(7):721-725. [pmid: 8672988].
94 Folsom A R, Mink P J, Sellers T A, Hong C P, Zheng W, Potter J D. Hormonal replacement therapy and morbidity and mortality in a prospective study of postmenopausal women. Am J Public Health. 1995;85(8 Pt 1):1128-1132. [pmid: 7625511]. [pmcid: 1615815].
95 Matthews K A, Kuller L H, Wing R R, Meilahn E N, Plantinga P. Prior to use of estrogen replacement therapy, are users healthier than nonusers? [see comments]. Am J Epidemiol. 1996;143(10):971-978. [pmid: 8629615].
96 Gruchow H W, Anderson A J, Barboriak J J, Sobocinski K A. Postmenopausal use of estrogen and occlusion of coronary arteries. Am Heart J. 1988;115(5):954-963. [pmid: 3364352].
97 Sullivan J M, Vander Zwaag R, Hughes J P, et al. Estrogen replacement and coronary artery disease. Effect on survival in postmenopausal women. Arch Intern Med. 1990;150(12):2557-2562. [pmid: 2244772].
98 McFarland K F, Boniface M E, Hornung C A, Earnhardt W, Humphries J O. Risk factors and noncontraceptive estrogen use in women with and without coronary disease. Am Heart J. 1989;117(6):1209-1214. [pmid: 2729050].