# Research Priorities

1. Use data from ongoing randomized controlled trials of estrogen and estrogen-progesterone use to further evaluate the risk of breast cancer associated with hormone use.
2. Further evaluate the role of exogenous progesterone by type and by dosing schedule in breast cancer development in epidemiologic studies, as well as in basic science research.
  Attempt to clarify subpopulations of women who might be at increased risk of developing breast cancer in association with hormone use, particularly considering genetic risk factors, alcohol use, body mass index, and age.
3. Given the large number of women needed for a clinical trial or cohort study, and the relatively urgent need for information, utilize multicenter prospective, current case-control studies, especially in HMO settings, where drug records are available to further evaluate the association.
4. Use epidemiologic methods to evaluate whether HRT has different effects in women with BRCA 1 and/or BRCA 2 tumor suppressor gene mutations. Are women with these mutations at any higher risk of BCA if they use HRT?
5. Further evaluate the association of estrogen and progesterone with BCA tumors at the basic science level, particularly its effect/relationship with the BRCA tumor-suppressor genes.
6. Evaluate childhood and adolescent exposures and their association with breast cancer. Large databases such as NHANEs might be useful in this evaluation.