# Discussion

The biological plausibility that the use of either ERT or CHRT might increase the incidence of breast cancer is strong and supported by experimental, clinical, and epidemiologic studies. However, the studies evaluating the relationship between postmenopausal ERT or CHRT and BCA risk have had inconsistent findings. In general, the findings are as follows:

1. The vast majority of recent studies, including several of good quality, show no increase in risk of BCA in association with short-term use of ERT.
2. Current use of ERT has been shown to be associated with an increase in risk of BCA in several studies and 3 meta-analyses with relative risks in the range of 1.2 to 1.5.
3. The results of studies evaluating the long-term use of ERT are mixed. With the exception of the NHS and a subset from the IWHS, the strongest studies show no statistically significant association. Many studies of good to poor quality have had slightly elevated, though non-statistically significant point estimates, so that when studies are combined in meta-analyses, all suggest increased risks of 20–50% with 5–20 years duration of HRT.
4. Fewer studies have evaluated the use of postmenopausal CHRT, particularly long-term use. The majority show no statistically significant increase in risk with ever use.
5. Long-term use of CHRT is associated with elevated risks of BCA in 3 of the 5 studies evaluating its use. The risk appears to be disproportionately increased among lean CHRT users and/or women using progesterone sequentially.
6. Recent data support an important interaction with HRT and CHRT among women who are lean. Whether this is due to a biological effect, confounding, selection bias, or detection bias in leaner women, is unclear.
7. HRT use may increase the risk of BCA more among women who use alcohol than among those who do not use alcohol.
8. Increased breast density is a risk factor for BCA, and ERT is associated with significant increases in mammographic breast density. CHRT seems to result in even greater increases in breast density than ERT.
9. The majority of studies show decreased BCA mortality among women who use HRT, although this finding may reflect selection bias among HRT users.
10. Past use of HRT is not associated with increased risk of BCA.

Most recent evidence shows no increase in BCA risk associated with short-term HRT/ERT/CHRT use. In evaluating this finding it is important to consider potential flaws in the data. The most prominent of these is the possibility of selection bias in the use of ERT or CHRT. Do women at higher or lower risk of BCA differentially use short-term HRT? Many studies support the contention that women who take HRT are different from those who do not in ways that affect BCA risk. For example, women who use HRT tend to be wealthier, to have fewer children, to be more educated, and to use more alcohol, all epidemiologically associated with increased rates of BCA. On the other hand, particularly in Europe, women often use HRT for the relief of menopausal symptoms, and women with more menopausal symptoms often have physical characteristics associated with a lower risk of breast cancer, such as lower body mass index. Also, very often HRT is used for symptoms in women who undergo surgical menopause, which, if performed prior to natural menopause, is associated with lower risk of breast cancer. Both of these situations may artificially result in biases toward less measured effect of estrogen on breast cancer than might truly be the case.

Another concern in evaluating negative results among studies is that inclusion of women with simple hysterectomy in analyses may have led to a systematic underestimate in risk of BCA associated with HRT. This concern was initially raised in a study by Pike, ^86^ who suggested that because age at menopause is strongly negatively correlated with use of ERT, and younger age at menopause decreases risk of BCA, including women with simple hysterectomy with an estimated age of menopause may systematically result in relative risk estimates which are artificially low. This issue was evaluated in the Nurses Health Cohort by comparing relative risk estimates among the full cohort with relative risk estimates when women with a simple hysterectomy were excluded. In this analysis, relative risk was 1.05 (95% CI, 1.03–1.07) for each year of estrogen use when women with simple hysterectomy were excluded and 1.04 (95% CI, 1.02–1.06) when all women were included and age at menopause was calculated as the time when 90% of women would have achieved menopause. Only a randomized controlled trial can eliminate selection bias in the use of HRT and validly evaluate the HRT and BCA relationship.

Of the studies showing increased risk of breast cancer associated with hormone replacement therapy, several show it with current use, ^12,^ ^20,^ ^29,^ ^31,^ ^53^ and few show increased risk with past use. This finding may be explained by estrogen acting as a promoter or co-carcinogen of breast cancer rather than an initiator, and fits with hypothesized models of carcinogenesis. In this model, estrogen may acutely raise breast cancer risk, which then decreases when estrogen is stopped. Pregnancy and its association with short-term increased breast cancer risk is a natural model that fits the conceptualization of risk associated with current HRT use. After a full-term pregnancy, women have increased rates of breast cancer, which persist for 1 to 2 years and then return to baseline, suggesting a late-stage promoting effect of pregnancy. However, the association of current hormone replacement therapy use and BCA might also be explained by other factors, such as surveillance bias, increased cancer detection in an unscreened population becoming screened, and, more recently, if progesterone truly is associated with increased risk (above that of estrogen alone), the addition of progesterone to more current hormone regimens.

The results of the meta-analyses reviewed and point-estimates from some of the case-control studies and cohort studies suggest that long-term ERT or CHRT use may be associated with an increase in BCA risk of 20–50% after 5 or more years of use. Very few of the studies have shown a graded risk with duration of use, which argues against a dose-response relationship, though several studies have shown increased risk after at least 5 years of use, suggesting a threshhold effect. Newcomb has raised the issue that users of long-duration estrogen are more likely to be current users, and that the increased risk identified with increased duration actually reflects recency of use. ^47^ The lack of association of breast cancer with past use of HRT, even of long duration, is suggestive of explanations other than a dose-response relationship. As discussed above, this may reflect that estrogen acts as a promoter or co-carcinogen rather than an initiator of BCA. In addition, although some of the studies have attempted to evaluate levels of screening, women on HRT may have more opportunity for the diagnosis of BCA because of increased surveillance. This increase in surveillance among hormone replacement therapy users has been documented in a number of studies, including the Nurses Health Study ^56^ and the Iowa Women's Health Study. ^36^

In evaluating the observational data, it becomes evident that many of the studies that show an increased risk of breast cancer associated with HRT show it only among recent or current users and not among past users, even of long duration. This may reflect surveillance bias among current users or, alternatively, may reflect estrogen's postulated role as a promoter in the etiology of breast cancer. There has been a marked increase in the diagnosis of ductal carcinoma in situ since mammography use has become more widespread. This suggests a pool of prevalent breast cancer that can be diagnosed with mammography, and increased surveillance among hormone replacement therapy users may artificially elevate breast cancer incidence rates. Increased surveillance is supported by data from some of the observational studies showing that women taking hormone replacement therapy have an increased incidence of in situ carcinoma and/or earlier stage tumors. ^12,^ ^87^

Further supporting the observation that HRT use and its association in some studies with increased incidence of breast cancer may reflect surveillance or over-diagnosis bias, are data from 4 of the 6 recent cohort studies evaluating mortality from breast cancer among hormone replacement therapy users. These data show that breast cancer mortality rates are reduced among women who were taking hormone replacement therapy at the time of diagnosis. Alternatively, it has been postulated that the observed decrease in BCA mortality among HRT users may be due to the promoting effects of estrogen on estrogen-sensitive tumors, which have a better prognosis than non-estrogen-sensitive tumors. This possibility is supported by studies showing that even after adjustment for the stage and size of breast tumors, women on HRT had a prognosis as good or better than women not taking estrogen. ^17,^ ^88^ However, these studies can also be interpreted to suggest that women who take estrogen differ from those who do not in characteristics that influence prognosis. Lower mortality from breast cancer in the setting of increased incidence rates may also reflect the propensity of hormone replacement therapy users to undergo more intense surveillance and screening for breast cancer with increased detection of early stage and/or in situ breast cancers of good prognosis.

Until recently, there have been few data on progesterone use. As the addition of progestational agents to estrogen use has become the standard of care among women with an intact uterus, more data have accumulated regarding risks associated with estrogen combined with progestins and/or with progestins alone. The issue is an important one, since clinical evidence among premenopausal women shows that rates of mitoses in breast epithelial tissue are highest when endogenous progesterone levels are highest. ^89^ Also, when progesterone is applied to breast tissue from postmenopausal women in vitro, rates of mitoses in breast epithelial tissue are increased. This suggests that progesterone may have an important etiologic role in breast cancer. ^89^

However, studying the risk of breast cancer associated with progestational agents is even more difficult than evaluating the risks associated with estrogen alone, for several reasons. First, the type of progestational agent varies among studies. The most commonly studied formulation has been medroxyprogesterone acetate. Second, the dose varies among studies. Finally, progestins have been given in varying schedules, though typically either continuously or sequentially, which may affect the risk of breast cancer associated with them. Two of the recent cohort studies and 2 of the recent case-control studies suggest significant increases in risk of BCA above that of ERT/HRT, associated with the addition of progesterone to estrogen. One study reports that this risk was increased only among women using sequential progesterone (versus continuous). ^22^ Some experimental evidence suggests that continuous progesterone may inhibit breast epithelial cell proliferation but that sequential progesterone may stimulate it in association with estrogen. ^90,^ ^91^ Finally, some studies evaluating the role of HRT and changes in breast density indicate that while estrogen alone increases breast density, the combination of estrogen and progesterone leads to greater increases. ^73,^ ^74^ Because increased breast density has been shown to be a risk factor for breast cancer independent of other risk factors, this is a concern.

Three studies suggest an increased risk of breast cancer among women who use alcohol and hormone replacement therapy that is higher than that among women who do not drink alcohol and use HRT. ^56,^ ^67,^ ^68^ In addition, the study of mammographic density changes using data from the PEPI trial showed significantly greater increases in breast density in association with HRT among women who drank alcohol than among those who did not. ^73^ A biological mechanism is suggested by the finding that blood estradiol levels are elevated in women taking hormone replacement therapy and increase markedly (to preovulatory levels) in women who take estrogen and drink alcohol. ^92^ In women who do not use hormone replacement therapy, baseline estradiol levels are lower and unchanged by using alcohol. ^92^ Other data suggesting increased exposure to estrogen among women who use alcohol come from the osteoporosis literature, where moderate alcohol use has been shown to decrease fracture risk, and fractures and osteoporosis have been thought to be markers for prior estrogen exposure. Not all studies have shown this interaction. ^93^

A finding reported in a number of studies ^12,^ ^21,^ ^45,^ ^48,^ ^53^ is an increase in BCA risk among lean women who use HRT, but not among heavier women using HRT. In one study, which stratified by type of HRT, ^21^ CHRT seemed to confer more risk than ERT in lean women. The reason for this interaction is unclear. The issue is complicated by the already complex interaction between weight and BCA risk, where premenopausal women who are lean have higher risks of BCA than heavier women, and where postmenopausal women who are heavier have higher rates of BCA than leaner women. ^12^ Thus, a biological explanation is plausible. One suggestion has been that overweight postmenopausal women already have relatively high endogenous estrogen levels and that adding exogenous estrogen does little to change risk, whereas adding exogenous estrogen to women with lower endogenous estrogen levels results in a substantial increase in risk relative to heavier women. This theory fits with a threshold-type effect of ERT and/or CHRT. Methodologic explanations for the increased risk of BCA observed in leaner women using HRT include confounding by other breast cancer risk factors, inclusion of premenopausal women (whose risk of BCA is increased if lean) in analyses, and/or increased detection of BCA in leaner women.

In the absence of controlled trials, evaluating a causal role for estrogen and/or progestational agents in the development of breast cancer is fraught with problems. Observational studies are subject to significant biases. Most prominent of these biases in the area of HRT is that almost all studies have shown that women who use estrogen are different from those who do not. ^20,^ ^56,^ ^94^ Longitudinal data among women who are premenopausal and followed into menopause also show that women who take estrogen postmenopausally are different in significant ways from those who do not prior to menopause. Women who take estrogen on average are better educated, drink more alcohol, have fewer children and later pregnancies, are leaner, exercise more, and have less co-morbidity, ^95^ and several of these characteristics have been shown to be epidemiologically linked to increased rates of breast cancer. It has also been suggested that physicians may prescribe HRT to women at lower risk of BCA, which could result in underestimates of BCA risk associated with HRT. This may have been particularly true during the years of many of these studies when the significant risk of endometrial cancer in association with unopposed estrogen was identified.

Thus, the role of estrogen in breast cancer may be confounded by its relationship with these other important known risk factors for breast cancer. These factors can be adjusted for analytically when they are measured. What cannot be adjusted for statistically, however, are lifestyle and/or environmental exposures and/or genetic characteristics that are not measured or may not yet be identified as risk factors for breast cancer. A very good example of the limitations of observational studies comes from the HERS trial. To date, most epidemiologic studies evaluating the relationship between HRT and coronary disease incidence have shown significantly reduced risks among women using HRT. However, in the HERS study of secondary prevention of CHD with CHRT, women randomized to CHRT actually had increased rates of CHD events in the first 2 years of the study. ^60^ These findings were surprising and contradictory to a significant body of observational studies showing reduced risk of CHD among women with known CHD who used HRT. ^96–98^ This example illustrates the importance of randomized controlled trials.

Breast cancer is a multietiologic disease and most BCA occurs in women without known major risk factors. Studies have shown that only a relatively small proportion of breast cancer is explained by known risk factors. This indicates that other important risk factors might work alone or in aggregate with others that are as yet unknown, and emphasizes the important metholdologic problem in observational studies of BCA and HRT in which not all risk factors can be adjusted for. It is plausible, and even likely, that risk of BCA is influenced by childhood and adolescent exposures, such as diet, exercise, body weight or other environmental exposures, and little attention has been given to premenopausal exposures that might be associated with HRT and BCA risk.

Clarifying the role of exogenous estrogen and/or progesterone in the development of breast cancer will require randomized controlled trials so that potential confounders that may be associated with breast cancer risk are randomly distributed among users and non-users. The Women's Health Initiative is a randomized controlled trial of HRT involving approximately 27,000 women that began in 1992 and has several goals, one of which was to evaluate HRT and breast cancer risk. Data were to be published from this study in approximately 2005. However, it was recently reported in the lay press that women using hormone replacement therapy had elevated rates of myocardial infarction, stroke, and blood clots. Although the study was not stopped, this finding may affect compliance and may limit the ability of the study to evaluate the association of hormone replacement therapy and breast cancer. As the life expectancy of women continues to increase, and the “baby boom” generation enters menopause, valid answers to the questions posed above are critical, given the relatively high incidence of BCA and the common use of HRT. We are hopeful that the Women's Health initiative will provide answers to these difficult questions.