# Results

The findings in the Results section will be presented for each key question by study type. Most emphasis will be given to findings from studies of good quality, utilizing a “best evidence” approach to the literature. ^28^ Each of the original studies was rated in quality according to standardized criteria developed by the USPSTF ^27^ (described in Appendix 3). Each study is described in detail in Appendix 4, which is organized by study type. Only meta-analyses from 1992 on are described in Appendix 4, although 2 earlier ones are listed in Table 1.

## Does short-term use of exogenous postmenopausal estrogen increase the risk of breast cancer?

In most published studies, short-term use of estrogen has been variably defined but almost always analyzed as “ever” use and compared to “never” use. Generally, the average duration of use of ERT is not reported, and it can range significantly from weeks to years. Not all studies evaluate the relationship by duration of use. Also, many of the studies rely on the use of pharmacy records, so that “ever” use is defined by filling a prescription, though nothing is known about compliance in this setting. Therefore, the analytic category of “ever” use of ERT represents a broad category of duration of use. We have chosen to include the results from studies that evaluated only “hormone use” or in which the type of hormone use was not specified (HRT) in the results section describing estrogen (ERT) use because we believe that the majority of patients would have had the greatest exposure to estrogen alone, rather than CHRT, based on the study dates. We recognize this may result in some misclassification of type of exposure, but wanted to include this information in this review. All of the original studies that included a description of “short” duration in their paper are displayed in Table 4. Notably “short” duration varies among the studies.

Table 4. “Short-term” ERT or CHRT and Breast Cancer Incidence

Study, Year | Duration | Status | Subanalysis | RR
| ERT/HRT (y) | ERT/HRT
Yang '92 | ≤1 | | | 1.20
Weinstein '93 | ≤1 | ever | | 1.22
Colditz '95 | ≤2 | current | ___ | 1.14
| ≤2 | past | | 0.90
Newcomb '95 | ≤2 | ever | | 1.02
| ≤5 | recent | | 0.82
Stanford '95 | 1–3 months | ever | | 1.10
| 3 month-2.9 years | ever | | 1.00
Lipworth '95 | ≤11 months | | | 1.75*
Persson '96 | ≤1 | ever | | 0.80
Henrich '98 | ≤5 | ever | Ever BCA | 1.55
| ≤5 | | Invasive BCA | 1.87
Lando '99 | ≤3 | ever | | 0.09
Gapstur '99 | <5 | Ever | | 1.07
Ross 2000 | Per 5 years | ever | | 1.10

* = P≤0.05

### Meta-analyses

Among the 8 meta-analyses evaluating this association, ^12,^ ^29–35^ only the most recent study by the Collaborative Group on Hormonal Factors in Breast Cancer, which included data from 51 case-control studies involving 52,705 breast cancer patients, ^12^ showed an elevated risk of BCA associated with ever use of HRT (OR 1.14, p < 0.001). Seven other meta-analyses have not identified increased risk associated with ever use. The discrepancy between the most recent study and the prior meta-analyses may reflect differences in surveillance among users and nonusers, since mammography has become more commonly used. This is supported by the finding that the most recent study found the excess risk of breast cancer to be largely due to localized disease, with an associated deficit in advanced disease during the first 5 years of HRT use. Another explanation of why the Collaborative Study results may differ from the other 7 meta-analyses is that it incorporated data from more recent studies in which CHRT use has become more common, and CHRT may be associated with greater breast cancer risk than ERT alone. This is supported by the finding in this study of an elevated RR of 1.15 (SE 0.19) for the use of CHRT or progestin alone among users with duration under 5 years and a relative risk of 0.99 (SE 0.08) for ERT alone.

Since the risk factors for breast cancer in women who take HRT differ in many ways from those of women who do not, the most useful information from meta-analyses may come from a study that pooled data from several randomized controlled trials of HRT for outcomes other than BCA, where BCA rates were evaluated among women randomized to HRT or placebo. ^35^ This study identified no increase in BCA risk associated with short-term ERT exposure (RR 0.85; 95% CI, 0.38–1.89), but the analysis involves fewer than 2000 women and few cases of BCA, and has limited power to evaluate the relationship.

### Cohort Studies

Since 1992, 8 cohorts studies have evaluated the relationship between short-term or “ever” use of ERT or HRT, and BCA incidence. The most recent results from these cohorts are summarized here and in Table 2. All studies are described in Appendix 4. Six of the 7 cohort studies showed no overall increase in risk of breast cancer associated with ever use of ERT or HRT where the formulation was not specifically evaluated. ^21,^ ^36–40^ These studies included the Iowa Women's Health Study (IWHS), ^36^ the NHANES I follow-up study, ^39^ and the Breast Cancer Detection Demonstration Project (BCDDP) study, ^21^ all good quality studies, as well as 1 study of fair quality ^37^ and 2 of poor quality. ^38,^ ^40^ These studies are described in detail in Section 4 in the Appendix and in Evidence Table 1. The only cohort study showing an increased risk of breast cancer among ever-users was the Saskatchewan cohort study. ^41^ This study is of poor quality because there was no assessment of important breast cancer risk factors in the study and the women were between ages 43–49—not representative of a postmenopausal cohort. Thus, it contributes little to the evaluation of short-term ERT use and breast cancer, and the best evidence from cohort studies indicates that short-term use of estrogen is not associated with an increased incidence of BCA. However, although the IWHS did not show an overall increased risk of BCA with ever use of less than 5 years (RR 1.07), increased risk of favorable histology BCA among ever users of 5 or fewer years (RR 1.81) was shown and statistically significant. ^36^ When only studies with a defined length of short-term ever use were reviewed, none of the studies showed increased risk (Table 4).

Table 2. Incidence Cohort Summary Table Studies 1992-2000

| ERT | | | CHRT | | | HRT
| | Duration of Use | | | Duration of Use | | | Duration of Use
Study/Year | Ever Use | Years | RR | Ever Use | Years | RR | Ever Use | Years | RR
Risch '94 | 1.33* | ≥3 | 1.50* | 0.93 | 1 | 1.196
n=32,790
Colditz '95 | 1.32 ¶¶ * | | | 1.41¶¶ * | | | | 10+ | 1.46*
n=69,586
Schuurman '95 | | | | | | | 1.0 | ≥5 | 0.9
n=62,573
Perrson '96 | | | | | | | 1.0 | >10 | 1.0
n=22,579
Sourander '98 | | | | | | | 0.57 ¶¶
n=6433 | | | | | | | 0.94 former
Gapstur '99 | | | | | | | ≤5y 1.07 | ≥5 | 1.11
n=37,105
Lando '99 | 0.8 | ≥10 | 0.8
n=5761
Schairer 2000 | 1.1 | | 1.5 (lean)* | 1.3 | | 2.0 (lean)*
n=40,020 | | | >8 | | | ≥4
| | | 1.0 (non-lean) | | | 1.3 (non-lean)

* = P ≤ 0.05

¶¶ = current use

### Case-control Studies

Fourteen case-control studies ^22,^ ^42–54^ published since 1992 evaluated breast cancer risk (incidence) in association with short-term ERT (see Evidence Table 1). Eight studies, including 2 good population-based studies from the United States, ^47,^ ^48^ have shown no increase in breast cancer risk associated with ever use of estrogen. Two of the 14 recent case-control studies evaluating incidence, ^52,^ ^53^ each rated of fair quality, have shown elevated risks associated with ever use of ERT. One study of poor quality, in which the hormone composition was unspecified but presumably mostly estrogen because the authors state that little CHRT was used at the time, also showed an increase in risk associated with ever use (Tables 3 and 4). ^49^

Table 3. Case-control Summary Table Studies 1992-2000

Study Number | ERT | Duration | | CHRT | Duration | | HRT | Duration
| Ever use OR | Years | OR | Ever use OR | Years | OR | Ever use OR | Years | OR
Yang '92 | 1.1 | ≤1 | 1.2 | 1.2
n=699 | | 1–4 | 0.8
| | 5–9 | 1.0
| | 10+ | 1.6*
Weinstein '93 | | | | | | | | | 1.14 | ≤1 | 1.22
n=837 | | | | | | | | 1–5 | 1.12
| | | | | | | | ≥5 | 0.88
Lipworth '95 | | | | | | | 1.52* | ≤1 | 1.75
n=820 | | | | | | | | 1–3 | 1.26
| | | | | | | | ≥3 | 1.42
Newcomb '95 | 0.97 | | | 1.01 | | | 1.05 | ≤2 | 1.02
n=3130 | | | | | | | | 2–4 | 1.09
| | | | | | | | 5–9 | 1.02
| | | | | | | | 10–14 | 0.99
| | | | | | | | ≥15 | 1.11
Lavechia '95 | | | | 1.6 | | | 1.2 | ≤1 | 1.0
n=2569 | | | | | | | | 1–4 | 1.3
| | | | | | | | ≥5 | 1.5
Stanford '95 | 0.9 | 1–3 mos. | 1.1 | 0.9 for CHRT or HRT | 1–3 mos. | 1.9
n=537 | | 4mos-2.9yrs. | 1.0 | 0.5 progesteron e alone | 3mos-2.9yrs. | 1.0
| | 3–4.9 | 0.9 | | 3–4.9 | 0.6
| | 5–7.9 | 1.2 | | 5–7.9 | 1.0
| | 8–11.9 | 0.5* | | ≥8 | 0.4
| | 12–14.9 | 0.5*
| | 15–19.9 | 0.5
| | ≥20 | 1.0
Levi '96 | | | | | | | 1.2 | ≥10 | 1.0
n=230
Persson '97 | | | | | | | 1.1 | 1–2 | 0.9
n=435 | | | | | | | | 3–5 | 1.0
| | | | | | | | 6–10 | 0.9
| | | | | | | | 11+ | 2.1*
Tavani '97 | | | | | | | 1.2 | <5 | 1.2
n=5984 | | | | | | | | ≥5 | 1.3
Henrich '98 | 1.66 | | | 1.02 | | | 1.54 | ≤5 | 1.55
n=109 | ¶1.93 | | | | | | | ≥5 | 1.61
| | | | | | | | ≥11 | 1.45
Brinton '98 | 0.7 | | | 0.99 | | | 0.9 | ≤3 | 0.86
n=1031 | | | | | | | | 3–5 | 1.0
| | | | | | | | ≥6 | 0.85
Magnuson '99 | 1.94* | <2 | 1.72* | 1.63* | ≤2 | 1.25 | 1.65* | ≤2 | 1.29*
n=2563 | | 2–5 | 1.49* | | 2–5 | 1.40* | | 2–5 | 1.40*
| | >5 | 2.18* | | ≥5 | 2.43* | | ≥5 | 2.32*
| | >10 | 2.70* | | ≥10 | 2.95* | | ≥10 | 2.43*
Fioretti '99 | | | | | | | 1.22 | ≥2 | 1.28
n=655
Ross 2000 | | Every 5yrs. | 1.06 | | Each 5yrs | 1.24* | | Every 5yrs. | 1.10*
n=2653 | | 15+ | 1.24 | | ≥5 | 1.15 | | >15 | 1.36

* = P≤0.05

¶ = Invasive breast cancer only

### Summary

- Seven of 8 meta-analyses have shown no increase in risk of breast cancer associated with ever use of postmenopausal HRT. The most recent meta-analysis involving observational studies showed a statistically significant elevated risk of 1.14 for short-term use, which was attributed to an excess risk of localized disease and a deficit in advanced disease, suggesting increased surveillance among users.
- A meta-analysis using pooled data from 9 small randomized controlled trials of estrogen therapy and reporting breast cancer incidence as a complication of short-term therapy showed no increase in risk of breast cancer among short-term ERT users. ^35^
- The majority (7 of 8) of cohort studies, including the 2 best-quality studies, ^20,^ ^21,^ ^36–40^ show no overall increase in breast cancer risk with short-term postmenopausal ERT or HRT use, though the IWHS suggested increased risk of favorable histology BCA among short-term users.
- The majority of case-control studies, including the best quality studies, show no association between short-term use of ERT or HRT and breast cancer.

## Does long-term use of postmenopausal estrogen increase the risk of breast cancer?

Many of the recent studies evaluating postmenopausal estrogen use have evaluated risk by duration of use of ERT and HRT. The issue has been analyzed in a variety of ways, as can be seen in the tables (Tables 2 and 3 and Evidence Tables 1 and 2). For example, duration may be evaluated only among current users in some studies, or among ever users in other studies, making comparison of studies difficult. Also, duration has been evaluated in past users by time since quitting or by time since beginning ERT.

### Meta-analyses

Among the 8 meta-analyses reviewed, 5 evaluated risk of breast cancer by duration of use and all identified increased risk with longer duration of use. ^12,^ ^29,^ ^31,^ ^32,^ ^34^ The relative risks are remarkably similar and range from 1.23 to 1.51 for periods of use from 5 to 20 years. The use of estrogen only (ERT) is not specifically analyzed, though it likely represents the vast majority of formulations, based on the dates of the studies pooled for the meta-analyses. Several of these meta-analyses are very well done. However, they are all limited by several factors, including limitations of the design and methodology of the pooled studies, heterogeneity among the studies, and changes in practice patterns such that including older data may be irrelevant to current practice. Even in the most recent meta-analyses, the mean year of diagnosis of BCA was 1985, when doses of estrogen tended to be higher and little progesterone was used. A problem in all of the observational studies, and compounded in the meta-analyses that pool studies, is lack of control for important confounders. This problem significantly limits interpretation of the meta-analyses results. Epidemiologists have also argued that combining data from observational studies in meta-analyses does not provide useful information. ^55^

### Cohort Studies

Four of the 7 recent cohort studies that evaluated breast cancer risk by duration of ERT showed no increase in rates of breast cancer (of any histology) with increased duration of ERT use. Studies showing no overall increase in risk include the IWHS ^36^ and the NHANES I study, ^39^ which are both good quality studies, a cohort study from Finland, ^38^ and one from the Netherlands. ^37^ However, the IWHS investigators also evaluated incidence rates by histological type of breast cancer. Although there was no overall increase in risk of breast cancer with increasing duration of ERT or HRT in the IWHS, there was an increased risk of invasive breast cancer of favorable histology with increased duration (RR ≤5 years 1.81; RR > 5 years 2.65) of HRT use, which was statistically significant, although based on only 82 cases. Unfortunately, the formulation of the HRT in this study is not specified, though it is likely that much of it was ERT.

Two cohort studies showing increased breast cancer risk with increasing duration specifically evaluated risk associated with ERT. One is the Saskatchewan cohort study, ^41^ which showed a relative risk of 1.50 for more than 3 years of ERT use. However, the study failed to assess confounding variables and relied on population comparisons to determine risk which limits the validity of the finding.

Another study of good quality evaluating risk among women enrolled in the Breast Cancer Detection Demonstration Project (BCDDP) ^21^ showed an increase in BCA risk with increasing duration of ERT use, but only among lean women, for whom the relative risk was 1.6 (95% CI, 1.2–2.2) for 4 or more years of use. The relative risk among non-lean women using ERT for more than 8 years was 1.0. Interestingly, as will be discussed below, this interaction was also shown among CHRT users in this study. This effect modification with ERT and body weight has also been observed in other studies, including the recent Collaborative Study meta-analyses. ^12^ Whether this finding reflects biological differences, unassessed confounding among leaner women, or detection bias (with improved breast cancer detection in leaner women) is uncertain and will be discussed below.

The Nurses Health Study ^20,^ ^56^ is an important study showing an increase in risk of breast cancer with long duration of HRT use. Among all current users, the risk of breast cancer was not increased until after 10 years of use (RR 1.46; 95% CI, 1.20–1.76). There was no gradation in risk or dose-response relationship by duration among current users. There was no association between duration of ERT use and risk of BCA among past users. When duration was evaluated by age categories, current users ages 55–64 had significantly increased risk of breast cancer after 5 years of use (RR 1.54–1.70). Women ages 55–59 who were current users also had an elevated risk of breast cancer with less than 5 years use (RR 1.37).

The reasons for different findings in overall BCA rates by duration between the NHS and the other good quality studies, particularly the IWHS, are unclear. Each involved large numbers of postmenopausal women, had study designs that were similar in implementation, and evaluated confounding variables very well. Because the IWHS began more recently than the NHS, the ERT/HRT formulations may differ, although little information is given in either study about formulations or doses of estrogen or HRT. The NHS study has longer follow-up, however (>10 years), which may partially explain the different findings between these good-quality cohort studies. Another consideration is that women in the IWHS are older and nearly 100% postmenopausal, which may be associated with different BCA risks in association with ERT/HRT than a cohort of younger postmenopausal women such as those enrolled in the NHS. However, the increase in rate of favorable histology BCA in the IWHS is consistent with the NHS findings.

### Case-control Studies

Fourteen case-control studies have been published since 1992 evaluating the relationship between duration of postmenopausal ERT and risk of breast cancer. ^22,^ ^42–54^ Twelve studies have been published evaluating duration of HRT use, where the formulation is not characterized, and BCA risk. ^9,^ ^22,^ ^45–53,^ ^57,^ ^58^ As above, we have chosen to evaluate unspecified HRT in the estrogen category. Three of the studies involve the same cases, so only the most recent publication is reviewed. Eight of the 12 studies evaluating duration of ERT or HRT have shown no statistically significant increase in risk in association with duration. Among the 12 case-control studies, the two studies of best quality ^47,^ ^48^ showed no association between duration of ERT or HRT use and BCA risk. In fact, the Stanford study ^48^ shows statistically significant reduced risk of breast cancer among users of 8–15 years duration (OR 0.5).

It is interesting to compare the estimates from studies specifically indicating that the patient took ERT with studies where the components of the HRT were not specifically characterized; the point estimates for HRT generally tend to be higher than those for ERT, although most are not statistically significant. Of the 4 case-control studies specifically evaluating ERT duration and BCA risk, 2 showed statistically increased risk with long duration of use. The Yang study, ^42^ of fair quality, showed no increase in risk until 10 or more years (OR 1.6; 95% CI, 1.1–2.5). The Magnusson study ^53^ showed a dose-response relationship with increasing duration of use with an odds ratio of 2.7 for more than 10 years of use (95% CI, 1.47–4.96). The Magnusson study, however, is of poor quality because of lack of control for important confounders and possible misclassification of estrogen use, so its results must be viewed with caution. The best-quality case-control study evaluating ERT use by duration and the risk of BCA was the Stanford study, ^48^ which showed statistically significant reduced risks of BCA with 8–15 years of ERT use (OR 0.5).

Of the 12 case-control studies evaluating HRT of unknown formulation, but presumed to be largely estrogen based on the dates of case diagnoses, 3 have shown statistically significant increases in breast cancer with increased duration of use. ^22,^ ^46,^ ^53^ One of these 3 studies includes the fair-quality Swedish study by Persson, ^46^ which identified an odds ratio of 2.1 (95% CI, 1.1–4.0) after 11 years of HRT use. The most recently published case-control study ^22^ did not show a statistically significant increased risk of BCA associated with long duration ERT use (OR 1.24 for over 15 years use), but did find an increase in risk of 10% for each 5 years of use of HRT (OR 1.10; 95% CI, 1.02–1.18), though some of these cases likely used progesterone. Finally, the Swedish study by Magnuson, ^53^ which showed increasing risk with increasing duration of ERT use, also evaluated risk by duration in association with HRT, where the composition was not specified, and found a dose-response relationship between duration of use of HRT and breast cancer with odds ratios ranging from 1.29 for fewer than 2 years of use to 2.43 for over 10 years, all statistically significant. For the reasons discussed above, this study is of poor quality and its results should be interpreted with caution. The good quality population-based case-control study by Newcomb ^47^ showed no increase in BCA risk with increasing duration of HRT.

Nine of the recent case-control studies evaluated breast cancer incidence by time since last use. ^42–44,^ ^47,^ ^48,^ ^50–53^ The findings were variable, with no consistent pattern among the studies. Six of the 15 case-control studies evaluated time since starting hormone replacement therapy and duration of use and breast cancer risk. ^43,^ ^44,^ ^48,^ ^50–52^ Of these, 3 showed no significant findings, ^43,^ ^50,^ ^52^ 2 showed a statistically increased risk with shorter time since beginning HRT, ^44,^ ^51^ and a good-quality US study showed a statistically reduced risk of breast cancer associated with greater time since first use and greater duration of use. ^48^

Two of the recent case-control studies evaluated hormone replacement therapy and breast cancer by type of estrogen (conjugated versus non-conjugated). ^50,^ ^52^ Only one study indicated a higher odds ratio associated with non-conjugated estrogen use (OR 1.89) than with conjugated (OR 1.49), although the findings were not statistically significant. ^52^

### Summary

- All 5 of the meta-analyses evaluating breast cancer risk and duration of HRT (formulations unspecified) show increased risk with “long-term” (>5 years) HRT use (RR 1.23–1.51). No analysis specifically evaluated ERT use.
- The findings of the cohort studies evaluating risk of BCA by duration of ERT or HRT use are inconsistent. Four of the 7 recent cohort studies evaluating duration have shown no statistically significant increase in overall risk of breast cancer in association with longer duration of therapy. One of these 4, however, did show significantly increased risk of favorable histology BCA. Of the 4, 2 specifically evaluated ERT use and 2 did not specify formulation.
- Of the cohort studies suggesting increased risk with increased duration, one is of poor quality and its results are therefore of questionable validity. One is of good quality and showed increased risk of BCA only in association with long duration ERT in lean women (RR 1.5) after 8 years of use. The NHS, which is of good quality, showed increased risk (RR 1.46) with duration of 10 or more years, which was statistically significant, and increased risk of BCA after 5 years use of ERT in women ages 55–64. Finally, the IWHS showed an increased risk of favorable histology BCA with increasing duration of use.
- Eight of the 12 recent case-control studies evaluating duration of ERT or HRT, including the 2 of best quality, showed no increase in risk of breast cancer with increased duration of use.
- None of the studies shows any consistent relationship with past use of any duration.

## Is combination therapy with estrogen and progesterone (CHRT) associated with increased risk of breast cancer?

The issue of combination therapy and its association with breast cancer risk is an important one to address, since it is now the standard of care to use CHRT in women with an intact uterus to prevent endometrial hyperplasia and cancer. However, this is a relatively recent practice, and the research in this area is more limited and largely confined to studies conducted in the last 10 years. The second USPSTF found little evidence that adding progestins to estrogen influenced the risk of breast cancer associated with CHRT.

Although there are no trials, useful information on short-term use of CHRT comes from 2 recent randomized controlled trials: one evaluating the role of CHRT in the secondary prevention of coronary artery disease and the other its association with lipids. In the Postmenopausal Estrogen/Progestin Interventions (PEPI trial), which evaluated CHRT use and lipids, 3 women among the 174 (1.72%) randomized to placebo and 5 among the 701 (0.71%) randomized to treatment with CHRT developed breast cancer over the 3-year study period. ^59^ In the HERS trial, 32 out of 1,380 (2.32%) women randomized to CHRT and 25 of the women randomized to placebo (1.81%) developed BCA after 4 years of study. ^60^

### Meta-analyses

None of the meta-analyses conducted to date has specifically evaluated CHRT use and breast cancer risk.

### Cohort Studies

Three of the recent cohort studies have specifically evaluated the relationship between breast cancer and CHRT. These include the NHS, ^20^ the BCDDP screening cohort study, ^21^ and the Saskatchewan cohort. ^41^ The NHS showed a statistically significant elevated relative risk of 1.41 (95% CI, 1.15–1.74) for current use of CHRT and a relative risk of 2.24 for current use of progesterone alone, but did not specifically evaluate ever or long-term CHRT use. The study from the BCDDP ^21^ is an important one for its subgroup analysis. For ever use of CHRT, the relative risk was 1.3, but not statistically significant. Current use of CHRT was associated with a relative risk of 1.4 (95% CI, 1.1–1.9). When risk was evaluated by duration of 4 or more years, an increase in risk was shown only among lean women (RR 2.0, 95% CI, 1.3–3.0). Non-lean women had a relative risk of 1.3 associated with CHRT, which was not statistically significant. Risk was not evaluated by dose schedule of progesterone (continuous or cyclic) in this study. Finally, the large cohort study from Saskatchewan ^41^ reported on CHRT of ≥1 years duration and found no increase in risk, but its results should be interpreted cautiously because the relative risk is only adjusted for age.

### Case-control Studies

Eight of the 14 recent case-control studies evaluating incidence specifically evaluated the association between breast cancer and CHRT. ^22,^ ^42,^ ^43,^ ^47,^ ^48,^ ^50,^ ^52,^ ^53^ See Table 3 for summary findings. Of these 8, only the Magnusson study showed a statistically significant increase in risk of BCA with ever use of CHRT (RR 1.63; 95% CI, 1.37–1.94). ^53^ Seven of the case-control studies showed no association between ever use of CHRT and breast cancer risk, with odds ratios ranging from 0.9–1.6 and not statistically significant. It is notable that the case-control studies of highest quality had point estimates of relative risk of 0.9–1.01. ^47,^ ^48^

Three of the case-control studies evaluated risk of BCA by duration of CHRT. The good-quality study by Stanford ^48^ showed no association between duration of CHRT and BCA. The Magnusson study ^53^ showed increased risk with increasing duration of CHRT therapy, with relative risks ranging from 1.4 (95% CI, 1.01–1.94) for 2–5 years' use, to 2.95 (95% CI, 1.84–4.72) for more than 10 years use of CHRT, as well as a dose-response relationship. When the types of progesterone were evaluated, there was a suggestion that testosterone-derived progesterone was associated with increased risk when compared with regimens containing non-testosterone-derived progesterone. This study, however, is limited by poor control of BCA risk factors, as well as by possible misclassification of estrogen exposure.

The other case-control study showing increased risk of BCA with increasing duration of CHRT use was the Ross study, published in 2000, ^22^ which identified an odds ratio of 1.24 (95% CI, 1.07–1.45) for each 5 years of CHRT use. Risk also increased from an odds ratio of 1.11 for < 5years use to 1.51 for over 5 years use; the statistical significance is not reported. The majority of women taking CHRT in this study were using medroxyprogesterone sequentially. The study is important because it also evaluated risk associated with different dose schedules for progesterone, and found that the increased risk of BCA associated with combination therapy was primarily due to an increase in risk associated with cyclic use of progesterone in CHRT (OR 1.38, 95% CI, 1.13–1.68) for each 5 years of use. The risk associated with continuous combined therapy was OR 1.09 (95% CI, 0.88–1.35) per 5 years of use. This is the first published study to evaluate risk of BCA associated with combination therapy by dosing schedule. Increasing duration of sequential CHRT was also associated with increasing risk of breast cancer, with OR ranging from 1.19 for fewer than 5 years use to 1.79 for more than 10 years use. Among women using continuous CHRT, even of long duration, there was no increase in risk of BCA (OR 1.23).

### Summary

- The addition of progesterone to estrogen therapy for women with an intact uterus is a relatively recent practice and the current standard of care. Consequently, fewer studies evaluate this practice, and studies have less power to evaluate the relationship.
- No randomized trials have specifically evaluated CHRT, although data from 2 trials of CHRT in other outcomes does not indicate increased risk.
- No meta-analyses have specifically evaluated combination therapy.
- Among the 3 cohort studies evaluating CHRT use, none showed statistically significant increases in risk associated with ever or short-term use of CHRT, though 2 had elevated point estimates (RR 1.3–1.41).
- Two cohort studies evaluated duration of CHRT use and breast cancer risk; only one showed statistically increased risk (RR 2.0) for duration over 4 years and only among lean women.
- Seven of the 8 case-control studies evaluating risk of BCA and CHRT use, including the study of highest quality, showed no increase in risk with ever or short-term use of CHRT.
- Two of the 3 case-control studies evaluating risk of breast cancer by duration of CHRT showed increased risk with increasing duration. One of these 2 studies showed a greater risk of BCA with the use of sequential progesterone CHRT compared to continuous progesterone CHRT use. The best quality study showed no association between long-term CHRT and BCA.

## Does current ERT or CHRT increase the risk of Breast Cancer?

### Meta-analyses

Among the 8 meta-analyses conducted to date, 3 have evaluated current use of estrogen, ^12,^ ^29,^ ^31^ and all have shown statistically significant increases in risk (RR 1.21–1.40) of BCA with current use. The Collaborative Study meta-analysis ^12^ is unique in this area because it defined current use as use within the last 12 months. The other 2 meta-analyses reported current use based on studies that reported use at the time the study evaluated exposure, which could reflect any duration of use. Data on current HRT/ERT/CHRT use and BCA are displayed in Table 5.

Table 5. Current Use of Estrogen or Estrogen/Progesterone Hormone Replacement Therapy and Breast Cancer Incidence

Study Quality | Hormone Formulation | Duration if described | Type of Breast Cancer if described | RR | 95% CI
Colditz '95 | HRT | ≤ 2 years | — | 1.14 | 0.91–1.45
Good | ERT | — | — | 1.32 | 1.14–1.54
| CHRT | — | — | 1.41 | 1.15–1.74
| Progesterone only | — | — | 2.24 | 1.26–3.98
LaVechia '95 | — | — | — | 0.8 | 0.50–1.40
Poor
Stanford '95 | ERT | — | — | 0.9 | 0.70–1.30
Good | CHRT | — | — | 0.9 | 0.60–1.20
Sourander '98 | | | | 0.57 | 0.27–1.70
Poor
Heinrich '98 | — | — | All BCA | 1.52 | 0.77–2.99
Fair | — | — | Invasive BCA | 1.87 | 0.85–4.12
Gapstur '99 | — | ≤ 5 years | Ductal carcinoma in situ | 0.94 | 0.41–2.16
Good | — | ≤ 5 years | Favorable Histology | 4.42 | 2.00–9.76
| — | ≤ 5 years | Invasive Ductal and/or Lobular | 1.38 | 1.03–1.85
Schairer 2000 | ERT | — | — | 1.1 | 1.00–1.30
Good | CHRT | — | — | 1.4 | 1.10–1.90

* = P [underlined: <] 0.05

### Cohort Studies

Four of the recent cohort studies evaluated BCA risk in association with current use of ERT or CHRT. Three good quality studies ^20,^ ^21,^ ^36^ show elevations in risk associated with current use. The NHS divided current use by type of HRT and found increased risks of 1.32, 1.41 and 2.24 associated with ERT, CHRT and progesterone alone, respectively, all statistically significant. In the NHS, however, current use could be of any duration and overall, no significantly increased risk was observed until after 10 or more years of use (RR 1.46; 95% CI, 1.20–1.76). However, current use of less or greater than 5 years duration was associated with a statistically significant increased risk among women aged 55–59 (RR 1.37–1.54). In the IWHS, only current use of 5 or fewer years was evaluated and the risk of both favorable histology and invasive ductal or lobular cancer was significantly increased with relative risks of 4.42 and 1.38, respectively. The BCDDP study also showed increased risk, but only with current CHRT (RR 1.4; 95% CI, 1.1–1.9). A study of poor quality found no association.

### Case-control Studies

Four case-control studies evaluated BCA risk among current users. The best study ^48^ showed relative risks of 0.9 for both ERT and CHRT. A fair-quality study from the New Haven area ^52^ showed a non-statistically-significant relative risk of 1.52 for current use and any type of cancer, and 1.87 for current use and invasive cancer only. Two poor quality studies also evaluated current HRT use; one suggested increased risk (RR 1.5) ^51^ and one suggested decreased risk, ^50^ although neither was statistically significant. These data are displayed in Table 5.

### Summary

- Current use of HRT reflects a broad duration of use.
- All 3 meta-analyses evaluating risk of BCA among current users of HRT have shown statistically significant increases in risk (RR 1.21–1.40).
- Three good quality cohort studies have shown elevated risk in association with current HRT, ERT, and CHRT use.
- The findings were inconsistent among the 4 case-control studies evaluating current HRT use. The best study showed no association.

## Does exogenous estrogen and/or estrogen plus progesterone increase the risk of fatal breast cancer?

### Cohort Studies

Six recent observational cohort studies evaluated mortality as an outcome, but none identified the components of the hormone replacement therapy in their analyses (see Table 6). The NHS showed an elevated incidence of breast cancer among hormone replacement therapy users, but there was not a statistically significant increased risk of death among current or past users of hormone replacement therapy. ^20^ However, among ever users of 5 or more years duration, the relative risk of death from breast cancer was elevated at 1.45 (95% CI, 1.01–2.09). Case-control analysis of data from this cohort published in 1997 had point estimates for risk of death from breast cancer of 0.76 among current users. ^61^ The Kaiser cohort study ^62^ did show an elevated relative risk of death among long-term HRT users but it was not statistically significant. However, the study is of poor quality and contributes little to the evidence.

Table 6. Mortality-Cohort Summary Table: Studies 1992-2000

| HRT**
Study | Ever Use | | | Duration of Use
| | | | Years | RR
Colditz '95 | 1.14 current | | | <5 | 0.99
| | | | ≥ 5 | 1.45*
Persson '96 | 0.5* | | | <5 | 0.2*
| | | | 10+ | 0.7*
Willis '96 | 0.84 | | | ≥1 | 0.85*
| | | | 2–5 | 0.78*
| | | | 6–10 | 0.78*
| | | | 11+ | 0.93
Ettinger '96 | | | | >5 | 1.89
Sellers '97 | [underlined: No family history] | | | [underlined: No family history]
| past | ≤5 | 0.86* | past | >5 | 0.76
| current | ≤5 | 1.00 | current | >5 | 0.84
| [underlined: Family history] | | | [underlined: Family history]
| past | ≤5 | 0.71* | past | >5 | 0.59
| current | ≤5 | 0.24* | current | >5 | 0.55
Schairer '99 | Lymph node negative | | | Lymph node negative
| past use | | | [underlined: current use]
| ≤4 yrs | 0.8 | | ≤4 | 0.6
| | | | ≥12 | 2.2
| Lymph node positive | | | lymph node positive
| past use | | | [underlined: current use]
| ≤4 yrs | 0.5* | | ≤4 | 0.5*
| | | | ≥12 | 1.9

* = P [underlined: <] 0.05

** = All mortality data based on HRT

Four cohort studies report reduced mortality rates among estrogen users. ^63–66^ The large cohort study from Sweden involving 22,579 women identified a significant decrease in standardized mortality ratio of 0.5 (95% CI, 0.4–0.6) among HRT users, though this is a poor quality study because of the use of external controls and no adjustment for confounding. ^64^

The Iowa Women's Health Study, ^65^ which found no overall association with hormone replacement therapy and incident breast cancer, found significant reductions in breast cancer mortality in women using HRT. Among women without a family history of breast cancer, past users of hormone replacement therapy for fewer than 5 years had a reduced risk of death (RR 0.86; 95% CI, 0.76–0.97). Among women with a family history of breast cancer, current versus never use of hormone replacement therapy for 5 or fewer years was associated with a relative risk for breast cancer death of 0.24 (95% CI, 0.06–0.97), and past versus never use for 5 or fewer years use was associated with a relative risk of 0.71 (95% CI, 0.51–0.98).

A cohort study by Willis ^63^ evaluated deaths among a cohort of women enrolled in a cancer-prevention study. This study enrolled 422,373 post-menopausal women in 1982 and followed them until December 1991. Breast cancer risk factors, co-morbidity, and hormone use were evaluated at entry with a self-administered mailed questionnaire. Hormone use was characterized as ever, current, or former use, and by duration of use, age at first use, and years since last use. Vital status was determined by phone queries using volunteers and by consulting the National Death Index. Breast cancer deaths were defined as those with breast cancer as the underlying diagnosis. Within this cohort, the overall risk of breast cancer among ever versus never users was reduced, with a relative risk of 0.84 (95% CI, 0.75–0.94). Past versus never use also had reduced risk, with relative risk of 0.78 (95% CI, 0.68–0.89). When duration and risk of death were evaluated, there was not a significant duration effect.

In the large BCDDP trial, ^66^ women with node-positive breast cancer who were current users for 4 or fewer years had a statistically significant decrease in risk of death of 0.5 (95% CI, 0.3–0.8). Point estimates of relative risk of death among current users (node-negative or node-positive) of more than 12 years duration were elevated at 1.9–2.2, but were not statistically significant. A statistically significant increase in risk of death associated with hormone replacement therapy use was observed among lymph node-positive women with more than 12 years of past use (RR 4.4; 95% CI, 1.7–11.8)).

### Case-control Studies

Of the 15 case control studies, only the large Nurses Health Study evaluated risk of death from breast cancer among women using hormone replacement therapy. In this nested case control study, 3,637 women died and were randomly matched to 10 controls each by age at menopause and 2-year period near the case patient's death. The multivariate-adjusted relative risk of death associated with current versus never hormone replacement therapy use was 0.76 (0.56–1.02), and past hormone replacement therapy use versus never (RR 0.83; 95% CI, 0.63–1.09). ^61^ Risk of death by duration of use was not evaluated.

### Summary

- No mortality studies specifically evaluated risk of death by composition of HRT.
- Four of the 6 studies published since 1992 show statistically significant reduced mortality among “ever” users of HRT.
- For long-term HRT users, only the NHS showed an increase in risk of death from BCA for ≥5 years use (RR 1.45; 95% CI 1.01–2.09).

## Are there subpopulations of women at higher risk of breast cancer in association with hormone replacement therapy?

### Family History

Women with a family history of breast cancer have an elevated baseline risk of breast cancer. The interaction of family history and hormone replacement therapy has been evaluated in several studies. In the Iowa Women's Health Study, ^65^ no differences in risk of developing breast cancer or dying from breast cancer were identified among individuals with or without a family history of breast cancer. A meta-analysis did not identify increased breast cancer risk among users of hormone replacement therapy in women with a family history of breast cancer. ^29^ In contrast, another meta-analysis reported a significantly elevated risk of breast cancer among women using hormone replacement therapy who had a family history of breast cancer (RR 3.4) compared to women using hormone replacement therapy without such a family history (RR 1.5). ^32^ The most recent meta-analysis, using data from 52,705 women worldwide with breast cancer, identified no significant difference in breast cancer risk among women using HRT with a family history of breast cancer. ^12^

### Body Mass Index

An important interaction identified in some studies is an increased risk of breast cancer among thinner women who use hormone replacement therapy. ^12,^ ^21,^ ^45,^ ^48,^ ^53^ Among premenopausal women, lower body mass index (BMI) is associated with a higher risk of breast cancer. ^65^ However, in postmenopausal women, higher BMI is associated with increased rates of breast cancer. ^12^ Thus, epidemiologic data suggest an important relationship or interaction between body mass index and BCA independent of HRT, which makes evaluation of the HRT/BMI interaction more difficult. Whether BMI is causally related to breast cancer or represents confounding by another factor is unclear. The identified interaction of HRT with lower BMI identified in some studies may be related to increased detection rates among thinner women, particularly given that current or recent use has the strongest association.

### Benign Breast Disease

Because certain types of benign breast disease are associated with breast cancer either as part of the pathologic pathway or etiologically, the interaction of hormone replacement therapy and benign breast disease is of interest and concern. This relationship was evaluated in 3 meta-analyses, and no relationship was identified. ^29,^ ^30,^ ^32^

### Alcohol

Although each study evaluated the role of estrogen in different ways, 2 studies suggested an important interaction of estrogen with alcohol use. The observation that hormone replacement therapy use in women who drink alcohol increases risk of breast cancer has been made in the Nurses Health Study and the Iowa Women's Study, both good-quality, well-conducted cohort studies from the United States involving large groups of women. ^56,^ ^67^ The interaction was also suggested in a Greek case-control study, but was not statistically significant. ^68^ The interaction was initially described in a 1990 report from the Nurses Health Study. In this study, women who did not consume alcohol had no increase in breast cancer risk with use of hormone replacement therapy (RR 0.99; 95% CI 0.62–1.60), and women who drank alcohol and were current hormone replacement therapy users had an elevated risk of breast cancer (RR 1.56; 95% CI 1.2–2.0). Similarly, the IWHS showed an elevated relative risk of breast cancer associated with HRT only among women who drank alcohol.

### Summary

- There is no current evidence of an important interaction between HRT and benign breast disease.
- There is good evidence from 2 well-conducted cohort studies of an interaction between HRT and alcohol, resulting in higher risk among women who drink alcohol and use HRT than among women using HRT who do not drink alcohol.
- The data evaluating HRT risk and interaction among women with a family history of breast cancer are inconsistent.
- Five studies using different methodologies have suggested increased risk of developing BCA among lean women taking HRT.

## Does hormone replacement therapy change breast density on mammograms?

In several studies, mammographic density has been shown to be a strong, independent risk factor for the development of breast cancer. ^24,^ ^69–71^ Several studies of mammographic breast density and use of hormone replacement therapy have had conflicting results. The most recent and important will be briefly reviewed.

Mammograms of 41 postmenopausal women enrolled in a clinical trial of hormone replacement therapy were blindly evaluated before they began estrogen replacement therapy and continuous progesterone of 2.5 to 5 mg per day and one year following the commencement of hormone replacement therapy. In this study, mammographic density increased significantly from baseline in 73% of the women randomized to hormone replacement therapy. ^72^

A second study performed subset analyses on 307 women involved in the Postmenopausal Estrogen/Progestin Interventions trial. ^73^ Participants were those who had a baseline mammogram and at least one follow-up mammogram, were compliant with therapy, had not used estrogen in the 5 years prior to the baseline mammogram, and did not have breast implants. Treatments included placebo, conjugated equine estrogens (0.625 mg/day), conjugated equine estrogen plus cyclic medroxyprogesterone, conjugated equine estrogen plus continuous medroxyprogesterone acetate, or conjugated equine estrogen plus cyclic micronized progesterone. Overall, 12.2% of the 295 women who were not at the highest baseline breast density had increases in breast density. Over the 3 years of follow-up, this increase in density was more prominent among those using CHRT, with increases ranging between 19 and 24%. In addition, CHRT was associated with the greatest density increase (5- to 7-fold increase among CHRT compared to ERT). In the logistic regression, the relative odds of an increase in density for CHRT was 13.1 for conjugated equine estrogen plus cyclic medroxyprogesterone acetate, 9.0 for conjugated equine estrogen plus daily medroxyprogesterone acetate, and 7.2 for conjugated equine estrogen plus cyclic micronized progesterone. In the logistic regression, age and alcohol had important effects on changes in mammographic density. For each 5-year increase in age, the odds of increasing mammographic density were 2 times greater. Women who drank alcohol were 3.6-fold more likely to have an increase in density than those who did not drink in association with use of HRT.

A hospital-based study ^74^ evaluated 81 postmenopausal women in a screening program before and after beginning hormone replacement therapy. In this study, 31% of patients treated with CHRT showed increased density compared to 8.7% in women treated with ERT.

### Summary

- Well-conducted studies have shown that HRT increases mammographic breast density.
- Compared to ERT, CHRT causes greater and more frequent increases in breast density. Evidence suggests that the increase in density associated with CHRT is greater when progesterone is administered cyclically (compared to continuously).
- One study shows that the increase in breast density among women using HRT is significantly higher among women who drink alcohol.

## Does hormone replacement therapy influence prognostic characteristics?

A number of studies have evaluated the prognostic characteristics of breast cancer detected in women taking hormone replacement therapy. Characteristics evaluated have included stage at diagnosis, presence or absence of estrogen and/or progesterone receptors, cathepsin D, histology, and cell kinetics. In general, HRT has been associated with increased rates of estrogen receptor positive, early stage, and more favorable histology tumors, ^75–81^ although this has not been shown in all studies. ^82–85^ Because mortality data are available from 4 well-conducted cohort studies, these factors were not extensively reviewed.